# Appendix A Summary of Evidence From Reviewed Studies

Table A1 Narrative summaries of evidence regarding KQ1 and KQ3

Table A2 Study characteristics