# Acronyms

AHRQ: Agency for Healthcare Research and Quality
AMSTAR: assessment of multiple systematic reviews
CMG: case mix group
CMS: Centers for Medicare and Medicaid Services
DPU: distinct part unit hospital
DRF: designated receiving facilities
DRG: diagnosis-related groups
DTC: diagnosis treatment combination
EPC: evidence-based practice center
FIM: functional independence measure
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HCFA: Health Care Financing Administration
HH: home health
HHA: home health agency
HHRG: home health resource group
IHA: Integrated Healthcare Association
IOL: interocular lens
IPPS: inpatient prospective payment system
IRF: inpatient rehabilitation facility
KQ: Key Question
LTACH: long-term acute hospital
MBHO: managed behavioral healthcare organization
MD: medical doctor
nd:YAG: neodymium-doped yttrium aluminum garnet
NHS: National Health Service
PBR: payment by results
PPS: prospective payment system
PROMETHEUS: Provider Payment Reform for Outcomes, Margins, Evidence, Transparency Hassle-reduction, Excellence, Understandability and Sustainability
RAM: resource allocation methodology
rHuEPO: recombinant human erythropoetin
RN: registered nurse
RUG: resource utilization group
SES: socioeconomic status
SNF: skilled nursing facility
TEFRA: Tax Equity and Fiscal Responsibility Act
VA: United States Department of Veterans Affairs