# Acknowledgments

The authors gratefully acknowledge the Task Order Officer for this project, Elisabeth Kato, and Bernard Friedman of the Agency for Healthcare Research and Quality. We would also like to thank Reema Singh and Kate Barker of RAND for research assistance and project support.