# References

1 U.S. Government Accountability Office (GAO). Web site: Strengthening Preparedness for Large Scale Public Health Emergencies. www.gao.gov/highrisk/risks/national-challenges-public-health/. Accessed on Oct. 8 2010.
2 U.S. Government Accountability Office (GAO). Emergency Preparedness: States are Planning for Medical Surge, but Could Benefit from Shared Guidance for Allocating Scarce Medical Resources, GAO-08-668. Washington, D.C. June. 2008.
3 Institute of Medicine (U.S.) Committee on the Future of Emergency Care in the United States Health System. Hospital-based emergency care: at the breaking point. Washington, DC. National Academies Press. 2007.
4 Institute of Medicine Committee on the Future of Emergency Care in the US Health System. Emergency Medical Services: At the Crossroads. Washington, D.C. The National Academies Press. 2006.
5 Institute of Medicine. Committee on the Future of Emergency Care in the US Health System Pediatric Emergency Care: Growing Pains. Washington, D.C. The National Academies Press. 2006.
6 U.S. Department of Health And Human Services, Office of the Assistant Secretary for Preparedness and Response. Framework for the NHSS. www.phe.gov/Preparedness/planning/authority/nhss/Pages/framework.aspx. Accessed on October 24 2011.
7 Department of Homeland Security. National Response Framework. January. 2008.
8 Department of Homeland Security. National Incident Management System. December. 2008.
9 National Center for Injury Prevention and Control. In a Moment’s Notice Surge Capacity for Terrorist Bombings. Atlanta (GA). Centers for Disease Control and Prevention. 2007.
10 Centers for Disease Control and Prevention. FluSurge. http://www.cdc.gov/flu/flusurge.htm. Accessed April 19, 2011.
11 Kaji AH, Koenig KL, Lewis RJ. Current hospital disaster preparedness. JAMA-Journal of the American Medical Association. Nov. 2007;298(18):2188-90. [pmid: 18000203].
12 Salinsky E. Strong as the Weakest Link: Medical Response to a Catastrophic Event. National Health Policy Forum Background Paper – No. 65. August. 8. 2008.
13 Altevogt BM. Institute of Medicine (US) Committee on Guidance for Establishing Standards of Care for Use in Disaster Situations. Guidance for Establishing Crisis Standards of Care for Use in Disaster Situations: a Letter Report. Washington, DC. National Academies Press. 2009.
14 Chang E, Backer H, Bey T, et al. Maximizing medical and health outcomes after a catastrophic disaster: Defining a new “crisis standard of care”. Western Journal of Emergency Medicine. 2008;9(3).
15 Phillips SJ, Knebel A. Mass medical care With scarce resources: a community planning guide. 2007. [pmid: 20083157128].
16 Phillips SJ, Knebel A, editors. Providing Mass Medical Care with Scarce Resources: A Community Planning Guide. Prepared by Health Systems Research, Inc., under contract No. 290-04-0010. AHRQ Publication No. 07-0001. Agency for Healthcare Research and Quality. Rockville, MD. 2006.
17 Phillips SJ, Knebel A, Johnson K, et al. Mass Medical Care With Scarce Resources: The Essentials. AHRQ Publication No. 09-0016. Agency for Healthcare Research and Quality. Rockville, MD. 2009.
18 U.S. Department of Transportation. Preparing for Pandemic Influenza: Recommendations for Protocol Development for 9-1-1 Personnel and Public Safety Answering Points. May. 3. 2007.
19 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. Jul. 21. 2009;6(7):e1000097. [pmid: 19621072].
20 Forum on Medical and Public Health Preparedness for Catastrophic Events, Institute of Medicine of the National Academies. IOM Letter Report Crisis Standards of Care: Summary of a Workshop Series. National Academies Press. Washington, DC. November. 2009.
21 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
22 Mays N, Pope C. Qualitative research in health care Assessing quality in qualitative research. BMJ. Jan. 1. 2000;320(7226):50-2. [pmid: 10617534].
23 Lincoln YS, Guba EG. Naturalistic Inquiry. Newbury Park, CA. Sage Publications. 1985.
24 NREPP. SAMHSA’s National Registry of Evidence-based Programs and Practices. Quality of Research. available at: http://nrepp.samhsa.gov/ReviewQOR.aspx.
25 Brandeau ML, McCoy JH, Hupert N, et al. Recommendations for modeling disaster responses in public health and medicine: a position paper of the society for medical decision making. Med Decis Making. Jul–Aug. 2009;29(4):438-60. [pmid: 19605887].
26 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
27 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality. J Clin Epidemiol. May. 2010;63(5):513-23. Also available at http://effectivehealthcare.ahrq.gov/repFiles/2009_0805_grading.pdf. [pmid: 19595577].
28 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. Also available at http://effectivehealthcare.ahrq.gov/. [pmid: 21463926].
29 Lee EK, Maheshwary S, Mason J, et al. Large-scale dispensing for emergency response to bioterrorism and infectious-disease outbreak. Interfaces. Nov–Dec. 2006;36(6):591-607.
30 Koh HK, Elqura LJ, Judge CM, et al. Implementing the cities readiness initiative: lessons learned from Boston. Disaster Med Public Health Prep. Mar. 2008;2(1):40-9. [pmid: 18388657].
31 Ablah E, Scanlon E, Konda K, et al. A large-scale points-of-dispensing exercise for first responders and first receivers in Nassau County, New York. Biosecur Bioterror. Mar. 2010;8(1):25-35. [pmid: 20230230].
32 Arora N, Raghu TS, Vinze A. Resource allocation for demand surge mitigation during disaster response. Decision Support Systems. Dec. 2010;50(1):304-15.
33 Bravata DM, Zaric GS, Holty JEC, et al. Reducing mortality from anthrax bioterrorism: Strategies for stockpiling and dispensing medical and pharmaceutical supplies. Biosecurity and Bioterrorism-Biodefense Strategy Practice and Science. 2006;4(3):244-62.
34 Cahill BP, Collins RD, Jurko RC, et al. Collaborative risk-based preparedness for pandemic influenza in Southeastern Virginia. 2008.
35 Glasser J, Taneri D, Feng ZL, et al. Evaluation of Targeted Influenza Vaccination Strategies via Population Modeling. Plos One. Sep. 2010;5(9).
36 McCaw JM, Wood JG, McCaw CT, et al. Impact of emerging antiviral drug resistance on influenza containment and spread: influence of subclinical infection and strategic use of a stockpile containing one or two drugs. PLos One. 2008;(June):e2362. [pmid: 18523549].
37 McVernon J, McCaw JM, Nolan TM. Modelling strategic use of the national antiviral stockpile during the CONTAIN and SUSTAIN phases of an Australian pandemic influenza response. Australian and New Zealand Journal of Public Health. Apr. 2010;34(2):113-9. [pmid: 23331352].
38 Medlock J, Galvani AP. Optimizing influenza vaccine distribution. Science (Washington). 2009;325(5948):1705-8. [pmid: 19696313].
39 Savoia E, Biddinger PD, Fox P, et al. Impact of tabletop exercises on participants’ knowledge of and confidence in legal authorities for infectious disease emergencies. Disaster Med Public Health Prep. Jun. 2009;3(2):104-10. [pmid: 19491605].
40 Schull MJ, Stukel TA, Vermeulen MJ, et al. Effect of widespread restrictions on the use of hospital services during an outbreak of severe acute respiratory syndrome. CMAJ. Jun. 19. 2007;176(13):1827-32. [pmid: 17576979].
41 Wein LM, Craft DL, Kaplan EH. Emergency response to an anthrax attack. Proc Natl Acad Sci U S A. Apr. 1. 2003;100(7):4346-51. [pmid: 12651951].
42 Zaric GS, Bravata DM, Cleophas Holty JE, et al. Modeling the logistics of response to anthrax bioterrorism. Medical Decision Making. 2008;28(3):332-50. [pmid: 18349432].
43 Zenihana T, Ishikawa H. Effectiveness assessment of countermeasures against bioterrorist smallpox attacks in Japan using an individual-based model. Environmental Health and Preventive Medicine. 2010;15(2):84-93. [pmid: 19784718].
44 Epley EE, Stewart RM, Love P, et al. A regional medical operations center improves disaster response and inter-hospital trauma transfers. Am J Surg. Dec. 2006;192(6):853-9. [pmid: 17161107].
45 Simon R, Teperman S. The World Trade Center attack. Lessons for disaster management. Crit Care. Dec. 2001;5(6):318-20. [pmid: 11737917].
46 Eastman AL, Rinnert KJ, Nemeth IR, et al. Alternate site surge capacity in times of public health disaster maintains trauma center and emergency department integrity: Hurricane Katrina. J Trauma. Aug. 2007;63(2):253-7. [pmid: 17693820].
47 Blackwell T, Bosse M. Use of an innovative design mobile hospital in the medical response to Hurricane Katrina. Ann Emerg Med. May. 2007;49(5):580-8. [pmid: 17141134].
48 Balch D, Taylor C, Rosenthal D, et al. Shadow Bowl 2003: a collaborative exercise in community readiness, agency cooperation, and medical response. Telemed J E Health. Fall. 2004;10(3):330-42. [pmid: 15650528].
49 Zerwekh T, McKnight J, Hupert N, et al. Mass medication modeling in response to public health emergencies: outcomes of a drive-thru exercise. J Public Health Manag Pract. Jan–Feb. 2007;13(1):7-15. [pmid: 17149094].
50 Asten Lv, Lubben Mvd, Wijngaard Cvd, et al. Strengthening the diagnostic capacity to detect Bio Safety Level 3 organisms in unusual respiratory viral outbreaks. Journal of Clinical Virology. 2009;45(3):185-90. [pmid: 19515608].
51 Sandlin CS, Johnson RC, Swaim L, et al. Technology reviews. Laboratory information management system for emergency response: validation and quality assurance of analytical methodologies. JALA: Journal of the Association for Laboratory Automation. 2009;14(3):126-32. Language: English. Entry Date: 20090731. Revision Date: 20090731. Publication Type: journal article.
52 Irvin CB, Atas JG. Management of evacuee surge from a disaster area: solutions to avoid non-emergent, emergency department visits. Prehosp Disaster Med. May–Jun. 2007;22(3):220-3. [pmid: 17894216].
53 Weddle M, Prado-Monje H. The use of deployable military hospitals after hurricanes: lessons from the Hurricane Marilyn response. Mil Med. May. 2000;165(5):411-7. [pmid: 10826391].
54 Kellermann AL, Isakov AP, Parker R, et al. Web-Based Self-Triage of Influenza-Like Illness During the 2009 H1N1 Influenza Pandemic. Annals of Emergency Medicine. Sep. 2010;56(3):288-94. [pmid: 20605260].
55 Etienne M, Powell C, Amundson D. Healthcare ethics: the experience after the Haitian earthquake. Am J Disaster Med. May–Jun. 2010;5(3):141-7. [pmid: 20701171].
56 U.S. Department of Health and Human Services, U.S. Department of Homeland Security. Guidance on Allocating and Targeting Pandemic Influenza Vaccine.
57 Adini B, Peleg K, Cohen R, et al. A national system for disseminating information on victims during mass casualty incidents. Disasters. Apr. 2010;34(2):542-51. [pmid: 20002707].
58 Erwin PC, Sheeler L, Lott JM. A shot in the rear, not a shot in the dark: application of a mass clinic framework in a public health emergency. Public Health Reports. 2009;124(2):212-6. [pmid: 19320362].
59 Hupert N, Xiong W, King K, et al. Uncertainty and operational considerations in mass prophylaxis workforce planning. Disaster Medicine and Public Health Preparedness. 2009;3(Suppl 2):S121-31. [pmid: 19797960].
60 Romm H, Wilkins RC, Coleman CN, et al. Biological Dosimetry by the Triage Dicentric Chromosome Assay: Potential Implications for Treatment of Acute Radiation Syndrome in Radiological Mass Casualties. Radiat Res. 2011. Jan. 4.
61 Xiong W, Bair A, Sandrock C, et al. Implementing Telemedicine in Medical Emergency Response: Concept of Operation for a Regional Telemedicine Hub. J Med Syst. 2010. Dec. 14. [pmid: 21161569].
62 Kilner TM, Brace SJ, Cooke MW, et al. In ‘big bang’ major incidents do triage tools accurately predict clinical priority?: A systematic review of the literature. Injury. May. 2011;42(5):460-8. [pmid: 21130438].
63 Amlot R, Larner J, Matar H, et al. Comparative analysis of showering protocols for mass-casualty decontamination. Prehosp Disaster Med. Sep–Oct. 2010;25(5):435-9. [pmid: 21053192].
64 Satterthwaite PS, Atkinson CJ. Using ‘reverse triage’ to create hospital surge capacity: Royal Darwin Hospital’s response to the Ashmore Reef disaster. Emerg Med J. 2010. Oct. 28. [pmid: 21030549].
65 Rehn M, Andersen JE, Vigerust T, et al. A concept for major incident triage: full-scaled simulation feasibility study. BMC Emerg Med. 2010;10:17. [pmid: 20701802].
66 Hirshberg A, Frykberg ER, Mattox KL, et al. Triage and trauma workload in mass casualty: a computer model. J Trauma. Nov. 2010;69(5):1074-81. discussion 81–2. [pmid: 20693920].
67 Nie H, Tang SY, Lau WB, et al. Triage during the week of the Sichuan earthquake: a review of utilized patient triage, care, and disposition procedures. Injury. Jul. 2010;41(7):866-71. [pmid: 20153857].
68 Lerner EB, Schwartz RB, Coule PL, et al. Use of SALT triage in a simulated mass-casualty incident. Prehosp Emerg Care. Jan–Mar. 2010;14(1):21-5. [pmid: 19947863].
69 Cone DC, Serra J, Burns K, et al. Pilot test of the SALT mass casualty triage system. Prehosp Emerg Care. Oct–Dec. 2009;13(4):536-40. [pmid: 19731169].
70 Wolf S, Partenheimer A, Voigt C, et al. Primary care hospital for a mass disaster MANV IV. Experience from a mock disaster exercise. Unfallchirurg. Jun. 2009;112(6):565-74. [pmid: 19436981].
71 Vincent DS, Burgess L, Berg BW, et al. Teaching mass casualty triage skills using iterative multimanikin simulations. Prehosp Emerg Care. Apr–Jun. 2009;13(2):241-6. [pmid: 19291564].
72 Einav S, Schecter WP, Matot I, et al. Case managers in mass casualty incidents. Ann Surg. Mar. 2009;249(3):496-501. [pmid: 19247040].
73 Vincent DS, Sherstyuk A, Burgess L, et al. Teaching mass casualty triage skills using immersive three-dimensional virtual reality. Acad Emerg Med. Nov. 2008;15(11):1160-5. [pmid: 18699829].
74 Cone DC, MacMillan DS, Parwani V, et al. Pilot test of a proposed chemical/biological/radiation/nuclear-capable mass casualty triage system. Prehosp Emerg Care. Apr–Jun. 2008;12(2):236-40. [pmid: 18379923].
75 Raiter Y, Farfel A, Lehavi O, et al. Mass casualty incident management, triage, injury distribution of casualties and rate of arrival of casualties at the hospitals: lessons from a suicide bomber attack in downtown Tel Aviv. Emerg Med J. Apr. 2008;25(4):225-9. [pmid: 18356360].
76 Kuniak M, Azizova T, Day R, et al. The Radiation Injury Severity Classification system: an early injury assessment tool for the frontline health-care provider. Br J Radiol. Mar. 2008;81(963):232-43. [pmid: 18180264].
77 Kanter RK. Strategies to improve pediatric disaster surge response: potential mortality reduction and tradeoffs. Crit Care Med. Dec. 2007;35(12):2837-42. [pmid: 17901842].
78 Zoraster RM, Chidester C, Koenig W. Field triage and patient maldistribution in a mass-casualty incident. Prehosp Disaster Med. May–Jun. 2007;22(3):224-9. [pmid: 17894217].
79 Aylwin CJ, Konig TC, Brennan NW, et al. Reduction in critical mortality in urban mass casualty incidents: analysis of triage, surge, and resource use after the London bombings on July 7, 2005. Lancet. Dec. 23. 2006;368(9554):2219-25. [pmid: 17189033].
80 Korner M, Krotz M, Kanz KG, et al. Development of an accelerated MSCT protocol (Triage MSCT) for mass casualty incidents: comparison to MSCT for single-trauma patients. Emerg Radiol. Jul. 2006;12(5):203-9. [pmid: 16733685].
81 Hsu EB, Jenckes MW, Catlett CL, et al. Training to hospital staff to respond to a mass casualty incident. Evid Rep Technol Assess (Summ). Apr. 2004;(95):1-3. [pmid: 15526398].
82 Vardi A, Berkenstadt H, Levin I, et al. Intraosseous vascular access in the treatment of chemical warfare casualties assessed by advanced simulation: proposed alteration of treatment protocol. Anesth Analg. Jun. 2004;98(6):1753-8. table of contents. [pmid: 15155341].
83 Janousek JT, Jackson DE, De Lorenzo RA, et al. Mass casualty triage knowledge of military medical personnel. Mil Med. May. 1999;164(5):332-5. [pmid: 10332171].
84 Cohen M, Kluger Y, Klausner J, et al. Recommended guidelines for optimal design of a plastic surgery service during mass casualty events. J Trauma. Nov. 1998;45(5):960-8. [pmid: 9820709].
85 Beyersdorf SR, Nania JN, Luna GK. Community medical response to the Fairchild mass casualty event. Am J Surg. May. 1996;171(5):467-70. [pmid: 8651386].
86 Sarkisian AE, Khondkarian RA, Amirbekian NM, et al. Sonographic screening of mass casualties for abdominal and renal injuries following the 1988 Armenian earthquake. J Trauma. Feb. 1991;31(2):247-50. [pmid: 1994085].
87 Gao T, Massey T, Selavo L, et al. The Advanced Health and Disaster Aid Network: A Light-Weight Wireless Medical System for Triage. Ieee Transactions on Biomedical Circuits and Systems. Sep. 2007;1(3):203-16. [pmid: 23852414].
88 Jarvis S, de Freitas S. Evaluation of an Immersive Learning Programme to Support Triage Training In-game Feedback and its effect on Learning Transfer. 2009.
89 Rodriguez-Noriega E, Gonzalez-Diaz E, Morfin-Otero R, et al. Hospital Triage System for Adult Patients Using an Influenza-Like Illness Scoring System during the 2009 Pandemic-Mexico. Plos One. May. 2010;5(5).
90 Andreatta PB, Maslowski E, Petty S, et al. Virtual reality triage training provides a viable solution for disaster-preparedness. Academic Emergency Medicine. 2010;17(8).
91 Loeb M, Dafoe N, Mahony J, et al. Surgical mask vs N95 respirator for preventing influenza among health care workers: a randomized trial. JAMA, Journal of the American Medical Association. 2009;302(17):1865-71.
92 Adeniji KA, Cusack R. The Simple Triage Scoring System (STSS) successfully predicts mortality and critical care resource utilization in H1N1 pandemic flu: A retrospective analysis. Critical Care. 2011;15(1).
93 Beck-Razi N, Fischer D, Michaelson M, et al. The utility of focused assessment with sonography for trauma as a triage tool in multiple-casualty incidents during the second Lebanon war. Journal of Ultrasound in Medicine. 2007;26(9):1149-56. [pmid: 17715308].
94 Cancio LC, Wade CE, West SA, et al. Prediction of mortality and of the need for massive transfusion in casualties arriving at combat support hospitals in Iraq. The Journal of trauma. 2008;64(2 Suppl):S51-5. discussion S5–6. [pmid: 18376172].
95 Cryer HG, Hiatt JR, Eckstein M, et al. Improved trauma system multicasualty incident response: Comparison of two train crash disasters. Journal of Trauma - Injury, Infection and Critical Care. 2010;68(4):783-8.
96 Gutsch W, Huppertz T, Zollner C, et al. Results of the mSTaRT triage from mass casualty incident exercises. Initiale sichtung durch rettungsassistenten: Ergebnisse bei übungen zum massenanfall von verletzten. 2006;9(4):384-8.
97 Leiba A, Halpern P, Priel IE, et al. A Terrorist Suicide Bombing at a Nightclub in Tel Aviv: Analyzing Response to a Nighttime, Weekend, Multi-Casualty Incident. Journal of Emergency Nursing. 2006;32(4):294-8. [pmid: 16863874].
98 Navin DM, Sacco WJ, McGili G. Application of a new resource-constrained Triage method to military-age victims. Military Medicine. 2009;174(12):1247-55. [pmid: 20055064].
99 Sanddal TL, Loyacono T, Sanddal ND. Effect of JumpSTART training on immediate and short-term pediatric triage performance. Pediatric Emergency Care. 2004;20(11):749-53. [pmid: 15502656].
100 Schenker JD, Goldstein S, Braun J, et al. Triage accuracy at a multiple casualty incident disaster drill: The Emergency Medical Service, Fire Department of New York City experience. Journal of Burn Care and Research. 2006;27(5):570-5. [pmid: 16998387].
101 Sacco WJ, Navin DM, Waddell RK 2nd, et al. A new resource-constrained triage method applied to victims of penetrating injury. J Trauma. Aug. 2007;63(2):316-25. [pmid: 17693830].
102 Guest T, Tantam G, Donlin N, et al. An observational cohort study of triage for critical care provision during pandemic influenza: ‘clipboard physicians’ or ‘evidenced based medicine’?. Anaesthesia. Nov. 2009;64(11):1199-206. [pmid: 19825055].
103 Gunal AI, Celiker H, Dogukan A, et al. Early and vigorous fluid resuscitation prevents acute renal failure in the crush victims of catastrophic earthquakes. J Am Soc Nephrol. Jul. 2004;15(7):1862-7. [pmid: 15213274].
104 Korner M, Geyer LL, Wirth S, et al. 64-MDCT in Mass Casualty Incidents: Volume Image Reading Boosts Radiological Workflow. American Journal of Roentgenology. Sep. 2011;197(3):W399-404. [pmid: 21862765].
105 Scarfone RJ, Coffin S, Fieldston ES, et al. Hospital-based pandemic influenza preparedness and response: strategies to increase surge capacity. Pediatr Emerg Care. Jun. 2011;27(6):565-72. [pmid: 21642799].
106 Casagrande R, Wills N, Kramer E, et al. Using the Model of Resource and Time-Based Triage (MORTT) to Guide Scarce Resource Allocation in the Aftermath of a Nuclear Detonation. Disaster Medicine and Public Health Preparedness. Mar. 2011;5:S98-110. [pmid: 21402818].
107 Van Cleve WC, Hagan P, Lozano P, et al. Investigating a pediatric hospital’s response to an inpatient census surge during the 2009 H1N1 influenza pandemic. Joint Commission Journal on Quality and Patient Safety. 2011;37(8):376-82. [pmid: 21874973].
108 Corvino TF, Nahata MC, Angelos MG, et al. Availability, stability, and sterility of pralidoxime for mass casualty use. Ann Emerg Med. Mar. 2006;47(3):272-7. [pmid: 16492495].
109 Merin O, Ash N, Levy G, et al. The Israeli field hospital in Haiti--ethical dilemmas in early disaster response. N Engl J Med. Mar. 18. 2010;362(11):e38. [pmid: 20200362].
110 Dhar SA, Bhat MI, Mustafa A, et al. ‘Damage control orthopaedics’ in patients with delayed referral to a tertiary care center: experience from a place where Composite Trauma Centers do not exist. J Trauma Manag Outcomes. 2008;2:2. [pmid: 18271951].
111 Labeeu F, Pasuch M, Toussaint P, et al. External fixation in war traumatology: report from the Rwandese war (October 1, 1990 to August 1, 1993). J Trauma. Mar. 1996;40(3 Suppl):S223-7. [pmid: 8606415].
112 Dan D, Mingsong L, Jie T, et al. Ultrasonographic applications after mass casualty incident caused by Wenchuan earthquake. J Trauma. Jun. 2010;68(6):1417-20. [pmid: 20234325].
113 Mazur SM, Rippey J. Transport and use of point-of-care ultrasound by a disaster medical assistance team. Prehosp Disaster Med. Mar–Apr. 2009;24(2):140-4. [pmid: 19591309].
114 Ma OJ, Norvell JG, Subramanian S. Ultrasound applications in mass casualties and extreme environments. Crit Care Med. May. 2007;35(5 Suppl):S275-9. [pmid: 17446788].
115 Korner M, Krotz MM, Wirth S, et al. Evaluation of a CT triage protocol for mass casualty incidents: results from two large-scale exercises. European Radiology. Aug. 2009;19(8):1867-74. [pmid: 19277671].
116 Malik ZU, Pervez M, Safdar A, et al. Triage and management of mass casualties in a train accident. J Coll Physicians Surg Pak. Feb. 2004;14(2):108-11. [pmid: 15228876].
117 Okumura T, Kondo H, Nagayama H, et al. Simple triage and rapid decontamination of mass casualties with colored clothes pegs (STARDOM-CCP) system against chemical releases. Prehosp Disaster Med. May–Jun. 2007;22(3):233-6. [pmid: 17894219].
118 Probst C, Hildebrand F, Flemming A, et al. Hospital emergency plan for external disasters - Training experience with mass casualties of injured, contaminated and burn patients. Der notfallplan des krankenhauses bei externen gefahrenlagen - Übungserfahrungen beim massenanfall von verletzten, kontaminierten und verbrennungspatienten. 2008;45(5):292-300.
119 Zhao X, Rafiq A, Hummel R, et al. Integration of information technology, wireless networks, and personal digital assistants for triage and casualty. Telemed J E Health. Aug. 2006;12(4):466-74. [pmid: 16942419].
120 Jokela J, Simons T, Kuronen P, et al. Implementing RFID technology in a novel triage system during a simulated mass casualty situation. Int J Electron Healthc. 2008;4(1):105-18. [pmid: 18583298].
121 Gunawan LT, Oomes AHJ, Yang ZK. Navigation Support for the Walking Wounded. Staphanidis C, editor. Universal Access in Human-Computer Interaction: Applications and Services. 2009;5616(Iii):197-206.
122 Curtis DW, Pino EJ, Bailey JM, et al. SMART-An Integrated Wireless System for Monitoring Unattended Patients. Journal of the American Medical Informatics Association. 2008;15(1):44-53. [pmid: 17947629].
123 Bouman JH, Schouwerwou RJ, Van der Eijk KJ, et al. Computerization of patient tracking and tracing during mass casualty incidents. Eur J Emerg Med. Sep. 2000;7(3):211-6. [pmid: 11142274].
124 Young D. Pharmacist’s software design aids mass dispensing clinics. Am J Health Syst Pharm. Mar. 1. 2006;63(5):400-2. [pmid: 16484510].
125 Levy G, Blumberg N, Kreiss Y, et al. Application of information technology within a field hospital deployment following the January 2010 Haiti earthquake disaster. J Am Med Inform Assoc. Nov. 1. 2010;17(6):626-30. [pmid: 20962123].
126 Roth LH, Criss K, Stewart X, et al. PrepLink: a novel web-based tool for healthcare emergency planning and response. Biosecur Bioterror. Mar. 2009;7(1):85-91. [pmid: 19379107].
127 Urban B, Meisel C, Lackner CK, et al. Alerting of clinical staff in mass casualty incidents. Implementation of an alerting system and results of test alarms. Alarmierung der Klinikmitarbeiter bei Größeren Schadenslagen: Implementierung eines Alarmierungssystems und Ergebnisse der Probealarme im Rahmen der Alarm-und Einsatzpläne. 2008;11(1):28-36.
128 Nilsson H, Rüter A. Management of resources at major incidents and disasters in relation to patient outcome: A pilot study of an educational model. European Journal of Emergency Medicine. 2008;15(3):162-5. [pmid: 18460958].
129 Neyman G, Irvin CB. A single ventilator for multiple simulated patients to meet disaster surge. Acad Emerg Med. Nov. 2006;13(11):1246-9. [pmid: 16885402].
130 Paladino L, Silverberg M, Charchaflieh JG, et al. Increasing ventilator surge capacity in disasters: ventilation of four adult-human-sized sheep on a single ventilator with a modified circuit. Resuscitation. Apr. 2008;77(1):121-6. [pmid: 18164798].
131 Williams D, Flory S, King R, et al. A low oxygen consumption pneumatic ventilator for emergency construction during a respiratory failure pandemic. Anaesthesia. Mar. 2010;65(3):235-42. [pmid: 20064146].
132 Automatic gas-powered resuscitators: what is their role in mass critical care?. Healthc Hazard Manage Monit. Mar. 2009;22(7):1-5. [pmid: 19507382].
133 Automatic gas-powered resuscitators. What is their role in mass critical care?. Health Devices. Aug. 2008;37(8):246-53. [pmid: 19058440].
134 Little CM, Merritt M, Wentworth A. An Improvised Oxygen Supply System for Pandemic and Disaster Use. Academic Emergency Medicine. Jun. 2009;16(6):558-63. [pmid: 19388910].
135 Lin JY, Bhalla N, King RA. Training medical students in bag-valve-mask technique as an alternative to mechanical ventilation in a disaster surge setting. Prehosp Disaster Med. Sep–Oct. 2009;24(5):402-6. [pmid: 20066642].
136 Hanley ME, Bogdan GM. Mechanical ventilation in mass casualty scenarios. Augmenting staff: project XTREME. Respir Care. Feb. 2008;53(2):176-88. discussion 89. [pmid: 18218149].
137 Barillo DJ, Cancio LC, Stack RS, et al. Deployment and operation of a transportable burn intensive care unit in response to a burn multiple casualty incident. Am J Disaster Med. Jan–Feb. 2010;5(1):5-13. [pmid: 20349698].
138 Voelker R. Mobile hospital raises questions about hospital surge capacity. JAMA. Apr. 5. 2006;295(13):1499-503. [pmid: 16595745].
139 Chung S, Monteiro S, Hogencamp T, et al. Pediatric Alternate Site of Care During the 2009 H1N1 Pandemic. Pediatric Emergency Care. Jun. 2011;27(6):519-26. [pmid: 21629143].
140 Bjornsson HM, Kristjansson M, Moller AD. Converted charter plane for mass transport of patients after a tsunami. Air Med J. Nov–Dec. 2008;27(6):293-8. [pmid: 18992689].
141 Chen J, Zhao W, Xian M, et al. Trans-province transfer of 10,373 patients injured in Wenchuan earthquake. Journal of Evidence-Based Medicine. 2009;2(4):270-6. [pmid: 21349026].
142 Fuzak JK, Elkon BD, Hampers LC, et al. Mass transfer of pediatric tertiary care hospital inpatients to a new location in under 12 hours: lessons learned and implications for disaster preparedness. J Pediatr. Jul. 2010;157(1):138-43. e2. [pmid: 20334875].
143 Baldwin S, Robinson A, Barlow P, et al. Moving Hospitalized Children All Over the Southeast: Interstate Transfer of Pediatric Patients During Hurricane Katrina. Pediatrics. May. 2006;117(5):S416-20. [pmid: 16735276].
144 Cryer HG, Hiatt JR. Trauma system: The backbone of disaster preparedness. Journal of Trauma - Injury, Infection and Critical Care. 2009;67(SUPPL 2):S111-3.
145 Jacobs LM, Burns KJ. Terrorism preparedness: Web-based resource management and the TOPOFF 3 exercise. J Trauma. Mar. 2006;60(3):566-71. discussion 71–72. [pmid: 16531855].
146 Hamilton J. An Internet-based bar code tracking system: coordination of confusion at mass casualty incidents. Disaster Manag Response. Jan–Mar. 2003;1(1):25-8. [pmid: 12688307].
147 Killeen JP, Chan TC, Buono C, et al. A wireless first responder handheld device for rapid triage, patient assessment and documentation during mass casualty incidents. AMIA Annu Symp Proc. 2006:429-33. [pmid: 17238377].
148 Noordergraaf GJ, Bouman JH, van den Brink EJ, et al. Development of computer-assisted patient control for use in the hospital setting during mass casualty incidents. Am J Emerg Med. May. 1996;14(3):257-61. [pmid: 8639196].
149 Wireless medical sensor networks in emergency response: Implementation and pilot results. 2008 IEEE International Conference on Technologies for Homeland Security, HST’08. 2008. Waltham, MA.
150 da Silva ML, Kostakos V, Matsumoto M, et al. Improving Emergency Response to Mass Casualty Incidents. 2008.
151 Epstein RH, Ekbatani A, Kaplan J, et al. Development of a staff recall system for mass casualty incidents using cell phone text messaging. Anesth Analg. Mar. 1. 2010;110(3):871-8. [pmid: 20185663].
152 Korner M, Geyer LL, Wirth S, et al. Analysis of responses of radiology personnel to a simulated mass casualty incident after the implementation of an automated alarm system in hospital emergency planning. Emerg Radiol. 2010. Dec. 1. [pmid: 21120569].
153 Albanese J, Martens K, Arnold JL, et al. Building Connecticut’s clinical biodosimetry laboratory surge capacity to mitigate the health consequences of radiological and nuclear disasters: A collaborative approach between the state biodosimetry laboratory and Connecticut’s medical infrastructure. Radiation Measurements. Jul–Aug. 2007;42(6–7):1138-42.
154 Hammer RR, Rooser B, Lidman D, et al. Simplified external fixation for primary management of severe musculoskeletal injuries under war and peace time conditions. J Orthop Trauma. 1996;10(8):545-54. [pmid: 8915917].
155 Rosenbaum RA, Benyo JS, O’Connor RE, et al. Use of a portable forced air system to convert existing hospital space into a mass casualty isolation area. Ann Emerg Med. Dec. 2004;44(6):628-34. [pmid: 15573039].
156 Mead K, Johnson DL. An evaluation of portable high-efficiency particulate air filtration for expedient patient isolation in epidemic and emergency response. Ann Emerg Med. Dec. 2004;44(6):635-45. [pmid: 15573040].
157 Ytzhak A, Sagi R, Bader T, et al. Pediatric ventilation in a disaster - clinical and ethical decision making. Crit Care Med. 2011. Oct. 20. [pmid: 22020234].
158 SALT mass casualty triage: concept endorsed by the American College of Emergency Physicians, American College of Surgeons Committee on Trauma, American Trauma Society, National Association of EMS Physicians, National Disaster Life Support Education Consortium, and State and Territorial Injury Prevention Directors Association. Disaster Med Public Health Prep. Dec. 2008;2(4):245-6. [pmid: 19050431].
159 Lerner EB, Schwartz RB, Coule PL, et al. Mass casualty triage: an evaluation of the data and development of a proposed national guideline. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S25-34. [pmid: 18769263].
160 Lerner EB, Cone DC, Weinstein ES, et al. Mass Casualty Triage: An Evaluation of the Science and Refinement of a National Guideline. Disaster Medicine and Public Health Preparedness. Jun. 2011;5(2):129-37. [pmid: 21685309].
161 Rubinson L, Hick JL, Curtis JR, et al. Definitive care for the critically ill during a disaster: Medical resources for surge capacity. From a Task Force for Mass Critical Care summit meeting. January 26–27, 2007. Chicago, IL. Chest. May. 2008;133(5):32S-50S.
162 Rubinson L, Hick JL, Hanfling DG, et al. Definitive care for the critically ill during a disaster: a framework for optimizing critical care surge capacity: from a Task Force for Mass Critical Care summit meeting. January 26–27, 2007. Chicago, IL. Chest. May. 1. 2008;133(5 Suppl):8S-31S. [pmid: 18460504].
163 Devereaux AV, Dichter JR, Christian MD, et al. Definitive care for the critically ill during a disaster: a framework for allocation of scarce resources in mass critical care: from a Task Force for Mass Critical Care summit meeting. January 26–27, 2007. Chicago, IL. Chest. May. 2008;133(5 Suppl):51S-66S. [pmid: 18460506].
164 Christian MD, Hawryluck L, Wax RS, et al. Development of a triage protocol for critical care during an influenza pandemic. Canadian Medical Association Journal. Nov. 2006;175(11):1377-81. [pmid: 17116904].
165 Christian MD, Toltzis P, Kanter RK, et al. Treatment and triage recommendations for pediatric emergency mass critical care. Pediatr Crit Care Med. Nov. 2011;12(6 Suppl):S109-19. [pmid: 22067919].
166 Rubinson L, Nuzzo JB, Talmor DS, et al. Augmentation of hospital critical care capacity after bioterrorist attacks or epidemics: recommendations of the Working Group on Emergency Mass Critical Care. Crit Care Med. Oct. 2005;33(10):2393-403. [pmid: 16215397].
167 Consensus statement on the triage of critically ill patients. Society of Critical Care Medicine Ethics Committee. JAMA. Apr. 20. 1994;271(15):1200-3. [pmid: 7818629].
168 Fair allocation of intensive care unit resources. American Thoracic Society. Am J Respir Crit Care Med. Oct. 1997;156(4 Pt 1):1282-301. [pmid: 9351636].
169 Christian MD, Joynt GM, Hick JL, et al. Critical care triage. Intensive Care Medicine. Apr. 2010;36:S55-64. [pmid: 20213422].
170 Bradt DA, Aitken P, FitzGerald G, et al. Emergency department surge capacity: recommendations of the Australasian Surge Strategy Working Group. Academic Emergency Medicine. 2009;16(12):1350-8. [pmid: 19912133].
171 National Center for Injury Prevention and Control. Updated In A Moment’s Notice: Surge Capacity for Terrorist Bombings. Centers for Disease Control and Prevention. Atlanta, GA. 2010.
172 Chapman LE, Sullivent EE, Grohskopf LA, et al. Postexposure interventions to prevent infection with HBV, HCV, or HIV, and tetanus in people wounded during bombings and other mass casualty events--United States, 2008: recommendations of the Centers for Disease Control and Prevention and Disaster Medicine and Public Health Preparedness. Disaster Med Public Health Prep. Oct. 2008;2(3):150-65. [pmid: 18677271].
173 Taylor BL, Montgomery HE, Rhodes A, et al. Protection of patients and staff during a pandemic. Intensive Care Medicine. 2010;36(Suppl 1):45-54.
174 Lyznicki J. American Medical Association, American Public Health Association. Improving health system preparedness for terrorism and mass casualty events: recommendations for action. Chicago, IL. American Public Health Association. 2007.
175 Docter SP, Street J, Braunack-Mayer AJ, et al. Public perceptions of pandemic influenza resource allocation: A deliberative forum using Grid/Group analysis. J Public Health Policy. 2011. Jan. 13. [pmid: 21228887].
176 Braunack-Mayer AJ, Street JM, Rogers WA, et al. Including the public in pandemic planning: a deliberative approach. BMC Public Health. 2010;10:501. [pmid: 20718996].
177 Poll: children’s needs should be prioritized in disaster planning, response, and recovery efforts American Academy of Pediatrics
178 PEPPPI. Citizen Voices on Pandemic Flu Choices: A Report of the Public Engagement Pilot Project on Pandemic Influenza. December. 2005.
179 Vawter DE, Garrett EJ, Gervais KG, et al. For The Good of Us All Ethically Rationing Health Resources in Minnesota in a Severe Influenza Pandemic Minnesota Center for Health Care Ethics and the Univesity of Minnesota Center for Bioethics. 2010.
180 Public Health - Seattle & King County. Public Engagement Project on Medical Service Prioritization During an Influenza Pandemic. September. 29. 2009.
181 Bailey TM, Haines C, Rosychuk RJ, et al. Public engagement on ethical principles in allocating scarce resources during an influenza pandemic. Vaccine. 2011. Mar. 2. [pmid: 21376119].
182 Vawter DE, Garrett JE, Gervais KG, et al. Attending to Social Vulnerability When Rationing Pandemic Resources. Journal of Clinical Ethics. Spr. 2011;22(1):42-53. [pmid: 21595354].
183 Fortes PA. To choose who should live: a bioethical study of social criteria to microallocation of health care resources in medical emergencies. Rev Assoc Med Bras. Apr–Jun. 2002;48(2):129-34. [pmid: 12205529].
184 State of Louisiana Department of Health and Hospitals. Crisis Standards of Care Public Engagement Project. 2011.
185 Levin D, Cadigan RO, Biddinger PD, et al. Altered standards of care during an influenza pandemic: identifying ethical, legal, and practical principles to guide decision making. Disaster Med Public Health Prep. Dec. 2009;3(Suppl 2):S132-40. [pmid: 19755912].
186 Grier R. Health Research and Educational Trust. Hospital response to public health emergencies: collaborative strategies. Chicago, IL. Health Research & Educational Trust. 2006.
187 Buehler JW, Whitney EA, Berkelman RL. Business and public health collaboration for emergency preparedness in Georgia: a case study. BMC Public Health. 2006;6(285). 20. November. 2006.
188 Ginter PM, Rucks AC, Duncan WJ, et al. Southeastern Regional Pediatric Disaster Surge Network: a public health partnership. Public Health Rep. Nov–Dec. 2010;125(Suppl 5):117-26. [pmid: 21133068].
189 Kanter RK, Andrake JS, Boeing NM, et al. Developing consensus on appropriate standards of disaster care for children. Disaster Med Public Health Prep. Mar. 2009;3(1):27-32. [pmid: 19293741].
190 Koh HK, Shei AC, Bataringaya J, et al. Building community-based surge capacity through a public health and academic collaboration: the role of community health centers. Public Health Rep. Mar–Apr. 2006;121(2):211-6. [pmid: 16528956].
191 Kelen GD, Kraus CK, McCarthy ML, et al. Inpatient disposition classification for the creation of hospital surge capacity: a multiphase study. Lancet. Dec. 2. 2006;368(9551):1984-90. [pmid: 17141705].
192 Terriff CM, Tee AM. Citywide pharmaceutical preparation for bioterrorism. Am J Health Syst Pharm. Feb. 1. 2001;58(3):233-7. [pmid: 11217178].
193 Dayton C, Ibrahim J, Augenbraun M, et al. Integrated plan to augment surge capacity. Prehosp Disaster Med. Mar–Apr. 2008;23(2):113-9. [pmid: 18557290].
194 Lurie N, Dausey DJ, Knighton T, et al. Community planning for pandemic influenza: lessons from the VA health care system. Disaster Medicine and Public Health Preparedness. 2008;2(4):251-7. [pmid: 18824920].
195 Dausey DJ, Aledort JE, Lurie N, et al. Tabletop exercises for pandemic influenza preparedness in local public health agencies. Santa Monica, CA. RAND. 2006.
196 Moser R Jr, Connelly C, Baker L, et al. Development of a state medical surge plan, part I: the procedures, process, and lessons learned or confirmed. Disaster Manag Response. Oct–Dec. 2005;3(4):112-7. [pmid: 16216795].
197 California Dept of Public Health. Standards and Guidelines for Healthcare Surge During Emergencies. 2007.
198 Colorado Dept of Public Health and Environment. Guidance for Allocations in the Healthcare System During a Moderate to Severe Influenza Pandemic. Sept. 2009;7.
199 California Dept of Health Services. California Influenza Preparedness and Response Plan, An Annex to the CDHS Public Health Emergency Response Plan and Procedures. Sept. 8. 2006.
200 California Disaster Medical Response Plan: California Emergency Medical Services Authority EMSA #218A. Sept. 2007.
201 Pandemic Influenza Community Mitigation Plan. Annex to CEMP. Annex to Mass Illness Plan. Appendix to Pandemic and Influenza Preparedness and Response Plan. Draft Nov 30, 2007.
202 Overview of the Public Health Response Assessment Team (PHRAT).
203 Utah Hospitals and Health Systems Association for the Utah Dept of Health. Utah Pandemic Influenza Hospital and ICU Triage Guidelines. Version 2. Aug. 11. 2009.
204 Anderson E, Sandrock C. University of California Davis Health Systems. Enhancing Surge Capacity and Partnership Effort (ESCAPE). Available at: www.ucdmc.ucdavis.edu/escape/images/escape-fact-sheet.pdf. 2009.
205 Guam Memorial Hospital Authority. Pandemic Flu Plan Draft, Revision #5. Feb. 2007.
206 Minnesota Deptartment of Health. Minnesota Healthcare System Preparedness Program. Standards of Care for Scarce Resources. Aug. 2008.
207 Schenk Terry L. A Brief Assessment of Florida’s Pre-Hospital Triage Strategy Florida. Department of Health. Sept. 1. 2008.
208 Wisconsin Deptartment of Health Services. Oxygen Conservation Strategies in Resource Limited Situations. Dec. 2008.
209 Nevada SCEMP, Nevada Dept of Health and Human Services. Antiviral Drug Distribution Plan, Appendix to Nevada Pandemic Influenza Response Plan Annex to Mass Illness Plan. July. 2. 2008.
210 North Dakota Department of Health. State Plan for Mass Patient Care: North Dakota. November. 2006.
211 Puget Sound Regional Catastrophic preparedness Program: Pre-Hospital Emergency Triage and Treatment Annex.
212 California Emergency Medical Services Authority. California Medical Mutual Aid Plan: Annex A to the California Disaster Medical response Plan, EMSA #218B. Sept. 2007.
213 New York State Workgroup on Ventilator Allocation in an Influenza Pandemic, Allocation of Ventilators in an Influenza Pandemic Draft. March. 15. 2007.
214 Shekelle PG, Pronovost PJ, Wachter RM, et al. Advancing the science of patient safety. Ann Intern Med. May. 17. 2011;154(10):693-6. [pmid: 21576538].
215 Institute of Medicine. The Future of Public Health. National Academy Press. Washington, DC. 1988.
216 Institute of Medicine. The Future of the Public’s Health in the 21st Century. National Academy Press. Washington, DC. 2002.
217 Ringel JS, Wasserman J. The Public Health System in the Wake of 9/11: Progress Made and Challenges Remaining. Jenkins Brian, Godges J, editors. The Long Shadow of 9/11: America’s Response to Terrorism. Santa Monica, California. RAND Corporation. 2011.
218 Kellermann AL, Shelton SR, Connor KL, et al. Federal Investment in National Health Security Research RAND Corporation. PM-3599-1-DHHS. Submitted to the Department of Health and Human Services. Santa Monica, CA. March. 2011.
219 Olsen LA, Aisner D, McGinnis JM, et al. The Learning Healthcare System: Workshop Summary. National Academies Press. 2007.
220 Peleg K, Kellermann AL. Enhancing Hospital Surge Capacity for Mass Casualty Events Jama-. Journal of the American Medical Association. Aug. 2009;302(5):565-7.
221 Peleg K, Kellermann AL. Medical Relief After Earthquakes: It’s Time for a New Paradigm. Ann Emerg Med. 2011. Aug. 18. [pmid: 21855171].
222 Fineberg HV, Wilson ME. Epidemic science in real time. Science. May. 22. 2009;324(5930):987. [pmid: 19460968].
223 Waeckerle JF. Personal commnuication. Ringel JS, editor. 2012.