# Opportunities for Future Research

This comparative effectiveness review (CER) spans more than two decades of preparedness research, including the decade following the September 11, 2001, attacks. Despite generous inclusion criteria, the addition of studies that lacked a control group, and even a supplemental section examining promising ideas, we determined that few strategies for allocating resources in a mass casualty event (MCE) have been sufficiently evaluated to confirm their effectiveness.

## Key Challenges

Given the challenging nature of the topic and its importance to the health security of the United States, decisive action is required to quickly build the evidence base required to properly inform policies and practice. Three hurdles must be cleared to achieve such rapid progress.

### Insufficient Funding

Business and health care leaders frequently complain that the “tyranny of the urgent” distracts them from issues that are more important. This is certainly true in the case of planning and preparedness for MCEs. Those who are responsible for assuring our nation’s health security at the national, State, community, and tribal level must be careful to distinguish between what is urgent and what is important. Because MCEs are rare and largely unforeseeable, efforts to improve emergency preparedness, mitigation, and response often take a back seat to the day-to-day demands of managing complex public health and health care systems. But when an MCE occurs, its urgency and importance eclipse everything else. At that point, it is too late to prepare.

Prior to September 11, 2001, public health in the United States suffered through a long period of decline. In 1988 and again in 2002, the Institute of Medicine determined that our nation’s public health system was in “disarray”.215, 216 In the first few years following 9/11 and the anthrax attacks, large sums of Federal money were directed toward strengthening public health and hospital emergency preparedness. However, the bulk of these resources were devoted to biodefense through such Federal programs as BioWatch, BioSense, BioShield, and the Biodefense Advanced Research and Development Authority (BARDA) and biodefense research at the National Institutes of Health (NIH) and the Centers for Disease Control and Prevention (CDC).217 Less money was invested in restoring the core infrastructure and capabilities of public health and health care systems to respond to the full array of health security threats.

Most of the Federal money that made its way to the States and hospitals during this time was for capacity building, rather than research to determine the most effective ways to use these resources. Moreover, most of these resources were restricted to efforts directly related to biodefense. Little thought was given to creating systems and infrastructures that are capable of responding to both daily emergencies and MCEs of all types. As the decade progressed, the global economic crisis and the recession it triggered led to a sharp decline in government revenues and large cuts in Federal spending for preparedness research, core public health programs, and staff.

In light of the austere economic environment, future preparedness research activities should be tightly focused, efficient, and effective. The overarching goal of these studies should be to provide needed guidance to policymakers and providers. The approach should seek to build a solid foundation for a health care system that will be robust and responsive in day-to-day activities, as well as in any health care crisis. With proper guidance and oversight, even a limited funding stream can produce better research and more valid findings. Health crises are, by their very nature, variable in onset, cause, location, scope, duration, and other characteristics. For this reason, categorical programs are rarely adequate, because it is impossible to predict the next MCE or terror attack. Public health and health care systems and providers must be capable of flexibly responding to a wide range of threats drawing from a toolkit of capabilities and skills.

### Inadequate Coordination

Recently, the RAND Corporation, with support provided by the U.S. Department of Health and Human Services Assistant Secretary for Preparedness and Response, conducted a first-ever portfolio analysis of nonclassified federally funded extramural research on public health and health systems preparedness across eight Federal research agencies: the NIH, the CDC, the Agency for Healthcare Research and Quality, the Department of Homeland Security Office of Science and Technology, Department of Defense Northern Command, the Department of Energy, the National Science Foundation, and the Veterans Health Administration.

This analysis determined that 62 percent of identified projects are focused on one or more aspects of infectious disease, foodborne illness, or pandemic influenza. Only 10 percent of funded projects addressed natural disasters. Nuclear, radiological, and explosive threats were each the focus of no more than 4 percent of research projects. More than half of all extramurally funded projects were laboratory studies; most were funded by the NIH. Only 6 percent of projects were focused on improving the performance of the health care system in disasters.218

The results of this CER suggest that such an ad hoc, agency-specific approach to preparedness research may not produce the findings we need to rapidly strengthen the national health security of the United States. Rather than fragmenting activity and dissipating efforts across a wide range of objectives, future research activity should be focused on the most urgent and promising issues. This will only happen if the various Federal agencies and stakeholders craft a plan to coordinate their activities. Unity of purpose, combined with a sustained stream of funding, will produce a more rapid and actionable set of advances than a much larger but poorly coordinated program of research.

### Logistical Barriers

We have highlighted the inherent challenges of conducting research during an MCE. Because these events cannot be readily foreseen, research teams must be assembled and deployed on short notice. Few institutional review boards are able, much less willing, to provide the requisite approvals to allow human subjects research in a workable time frame. There are also formidable ethical and logistical obstacles to collecting data at a time when resources are scarce and large numbers of people are pleading for help. It is not only difficult to envision conducting randomized controlled trials in such circumstances; it is nearly unthinkable.

However, it can be argued that the type of research needed to rapidly advance the field does not employ the sort of study designs typically required for inclusion in a comparative effectiveness review. Many high-impact business innovations have come from “focused empiricism”—identifying what works and what does not and subsequently refining promising strategies. A similar approach undergirds the well-accepted process of continuous quality improvement. Some experts in health care innovation have argued that beyond basic determinations of therapeutic efficacy and safety, relying on serially constructed, randomized controlled trials (RCTs) to establish the comparative effectiveness of various approaches to health care operations is neither feasible nor desirable.219

Hospital leaders should not need the results of RCTs to convince them of the value of rapidly clearing the emergency department in the short time window between notification that a terrorist bombing has occurred and the arrival of the first wave of complex casualties.220 Likewise, Federal and State policymakers should not need RCTs, cohort studies, or quasi-experimental trials to convince them of the value of stockpiling vital drugs and critical supplies that are likely to run short in the first few days or weeks following a major MCE. Adoption and consistent performance of simple performance improvement processes, such as routinely conducting rigorous but nonjudgmental “after-action reviews” (AARs) following each MCE could produce rapid advances in technique. This will not happen unless the findings of these AARs are systematically captured and the resulting observations are widely shared. Such an effort would go a long way toward promoting systems learning and improved performance.

AARs of large-scale events—the type that trigger a Federal response—could be dramatically strengthened by predesignating an evaluation team, with contingent approval from a national institutional review board to rapidly deploy with the lead elements of a Federal disaster response. A similar concept could be adopted by the United Nations and its member States to prospectively collect important lessons from global disasters of the scale of the Indonesian tsunami and the Haiti earthquake.221

At the other end of the spectrum, local planners and hospital officials should view small-scale events, near misses, as opportunities to assess and refine various elements of their community’s response plan. Federal and State governments should leverage annually recurring events, such as flu vaccination campaigns, as opportunities to test various elements of their response plans for bioterrorism and other emerging disease threats.

## Planning a Prioritized Research Agenda

With adequate funding, greater levels of collaboration and coordination, and flexible approaches to various modes of evaluation and research, rapid progress could be made toward addressing the most urgent and formidable challenges to the health care system in disaster preparedness and response. Specifically, we recommend the development of a prioritized research agenda modeled along the following lines:

1. Enhance coordination across Federal research agencies. A Federal interagency working group on health security research would go a long way toward ensuring that future research portfolios minimize overlaps and address key gaps. This will only happen if agencies agree to share information and jointly allocate a portion of their resources.
2. Require federally funded researchers to prospectively categorize the projects and key findings using a standardized format. If agencies adopt a common taxonomy for categorizing disaster research, it will be much easier in the future to prospectively identify projects and index their results. This would allow agency heads, policymakers, and researchers to avoid needless duplication of effort and better target their activities toward filling critical gaps.
3. Create a centralized information center that banks all available strategic plans and pertinent discussions of current and past science and ongoing projects.
4. Encourage State officials to engage community members, health care providers, and local policymakers to ascertain their views about contingent strategies and ethical frameworks for allocating scarce resources in MCEs. Because public engagement is important, special efforts should be made to include participants from different regions, ethnic backgrounds, cultures, ages, and faith traditions.
5. At the same time, efforts should be made to fully engage provider groups, including primary care and specialty clinicians and health system administrators, along with experts in health care law, policy, and ethics, to reach a national consensus on how scarce resources should be allocated under crisis standards of care. This process should include a systematic effort to identify the most important legal or regulatory barriers that could impede or undermine optimal allocation of scarce resources under crisis conditions.
6. Because community forums and face-to-face meetings are costly to conduct, they will never reach more than a small sample of the public. For this reason, researchers should explore methods to harness the power and reach of traditional news media (e.g., print, radio, and television), new media (Internet, short message service [SMS]), and social networks, such as Facebook and Twitter. The goal of these efforts should be to determine the most effective ways to engage and inform different segments of the public so that they can take appropriate action in an unfolding MCE and the recovery phase that follows.
7. Because it will always be extremely difficult to test various strategies under actual conditions, efforts should be made to develop and refine affordable simulations, computer models, and drills, including “no-notice” exercises, to more realistically assess and improve key elements of public health and health system operations and decision making.
8. We urgently need to build on the existing evidence to identify a simple but reliable approach to field triage in the setting of MCEs. This question could be quickly answered with a focused program of research. This work might be guided by the Model Uniform Core Criteria and other consensus-based MCE triage principles and protocols.
9. Additional research devoted to understanding facilitators and barriers to the effective implementation of incident command systems might provide greater insight into the poor response to several MCEs that we observed in several studies included in our review, and might suggest opportunities to strengthen this framework moving forward.
10. Because the consequences of a bioterror attack, a highly lethal flu pandemic, or an emerging infectious disease are so great, we urgently need to build on the existing evidence to determine the most effective method or methods to rapidly deploy needed biological and/or nonbiological countermeasures to the public.
11. Considerable benefit could be achieved by quickly developing and deploying efficient and affordable IT solutions for a variety of challenges, including (1) systems capable of tracking victims through various steps in the continuum of care from the scene of an MCE to definitive care, recovery, and repatriation; (2) software to guide hospital emergency operations centers through the various phases of responding to an MCE; and (3) passive public health surveillance systems that track area hospital emergency department, inpatient bed, and intensive care unit occupancy rates and each institution’s diversion status so local EMS providers can swiftly determine the best destination for casualties of daily emergencies as well as MCEs.
12. Similarly quick gains could be achieved by rapidly evaluating a variety of bidirectional communication technologies, including call centers with automated IVR and nurse advice lines, Web sites, SMS, and various forms of interactive social media to reach, inform, and engage the public in bidirectional communication. Automated algorithms, modeled on existing prototypes, could allow patients to self-triage themselves and get specific advice that is appropriate to their condition and circumstance. Bidirectional tools of this sort could be used to better match patients to available resources, reduce needless visits to hospital emergency rooms, and collect epidemic intelligence in real time.222 Similar approaches could be used to enable local nongovernmental organizations and community groups to match available resources and needs.
13. In addition to interactive communications, other methods and tools are needed to enhance the capacity of public health agencies, primary care providers, retail clinics, and local/regional health care systems to safely provide substantial levels of minor illness and injury care. This will allow resource-constrained hospitals to focus their staff on meeting the needs of more seriously ill and injured victims.
14. Additional work is needed to improve the methodologies used in disaster research. This might best be accomplished by an expert panel convened by the Institute of Medicine or a similar body. This group should pay particular attention to improving existing “measures of effectiveness,” including appropriate measures of outcome. Measurement problems are a common source of error that weakens the value of many MCE studies. Reviewers and journal editors generally look at three main areas when considering the merits of a study: internal validity, external validity, and merit. A study has to answer a question that is meaningful to have merit. In one former editor’s words, “a difference to be a difference must make a difference.”223
15. As noted in the discussion above, widespread institutionalization of a rigorous and objective approach to after-action reviews could produce rapid gains in knowledge through focused empiricism. To maximize the yield of this activity, the standard components of an AAR should be identified and refined so that they are uniform and helpful. A national clearinghouse should be created to distill the lessons learned from this process and widely share them with policymakers, providers, and, when appropriate, the public.
16. The U.S. government should either designate or contract with a small team of evaluators with prior security clearance and institutional review board approval to be on 24/7 call to immediately deploy, in the case of a major disaster or terrorist attack, with elements of the National Disaster Medical System. The only responsibility of this team should be to prospectively monitor, document, and report back observations of what went well and what did not over the course of the event. Although these individuals should be empowered to alert incident commanders to problems they identify, they should not have patient care responsibilities. This will enable them to focus their attention on rigorous data collection and analysis. To enable them to perform this important task, the team should granted access to every aspect of the response, including field hospitals, distribution centers, and the inner workings of the incident command center. A similar approach should be taken to large-scale global disasters by the United Nations, the World Health Organization, or another global relief group. Otherwise, we are doomed to repeat the mistakes of the past.221

## Conclusions

Emergency preparedness and response is essential to protect our nation’s health security. Our nation faces a wide array of man-made and natural threats. The existence of these threats and others that will undoubtedly emerge in the years to come cannot be ignored or wished away. Prevention and mitigation can and should remain key elements of our approach. But, from time to time, terror groups will launch a successful strike, or natural forces will overwhelm the best-built and most thoughtfully designed structures. When that happens, our nation must be prepared and capable of responding to minimize subsequent harm and loss of life.

In light of these facts, readers of this CER should be concerned by the limited amount of high-quality, highly applicable evidence to help policymakers, health care providers, and the public determine the best course of action in planning, preparing for, and responding to MCEs. In the same way that health care providers in a disaster strive to do the most good for the most people with the resources at hand, so should officials charged with advancing the applied science of disaster response strive to generate the most useful information in the shortest possible time within existing and, hopefully, augmented resources.