# Introduction

## Background

### Context

This evidence report is intended to advance our Nation’s efforts to better prepare for and respond to large-scale health emergencies—one of 13 “urgent issues” flagged for immediate attention by the Government Accountability Office in 2008.^1,2^ The Government Accountability Office’s concern was based on observations by the Institute of Medicine (IOM) and other groups that our nation’s emergency care system—encompassing emergency medical services, hospital-based emergency departments, inpatient wards, and intensive care units—is so overburdened that it could not readily cope with a large-scale public health emergency.3–5

In 2009, in compliance with provisions of Public Law No. 109-417 (also known as the Pandemic and All-Hazards Preparedness Act of 2006), the U.S. Department of Health and Human Services (HHS) released its first-ever National Health Security Strategy for the United States (hereafter referred to as the NHSS or the Strategy). In its introduction to the NHSS, HHS noted that considerable progress had been made in the previous decade, but many challenges remained:

“…Emergency response efforts are sometimes disparate; and effective coordination is often lacking across governmental jurisdictions, communities, and the health and emergency response systems.3 Additional steps must be taken to ensure that adequate medical surge capacity and a sufficiently sized and competent workforce are available to respond to health incidents, a sustainable medical countermeasure enterprise sufficient to counter health incidents is fostered, and increased attention is paid to building more resilient communities and integrating the public, including at-risk individuals,4 into national health security efforts. Moreover, considerable variation remains in the degree to which individual States, territories, tribes, and local jurisdictions are prepared to address large-scale health threats. At the same time, few evidence-based performance measures and standards exist to gauge the effectiveness of national health security efforts and progress toward goals5—that is, to assess the extent to which the Nation is prepared for the types of health incidents that we have experienced in the past and may have to confront in the future.”6

To achieve national health security, which HHS describes as “…a state when the Nation and its people are prepared for, protected from, respond effectively to, and able to recover from incidents with potentially negative health consequences,” the NHSS establishes two overarching goals: (1) Build community resilience, and (2) strengthen and sustain health and emergency response systems. To pursue these goals, the NHSS calls for a “systems approach” to health security. This approach recognizes that many interrelated systems are needed to support and protect individual and community health. As depicted in Figure 1, the two overarching goals of the NHSS are supported by 10 strategic objectives. Two of these objectives, integrated, scalable health care systems and science, evaluation, quality improvement, are the primary focus of this comparative effectiveness review (CER). However, the issues and strategies addressed in this review are relevant to many of the other objectives (e.g., national health security workforce, effective countermeasures enterprise).

Figure 1 Achieving national health security

Source: HHS Web site6

Figure 1 depicts the framework for achieving national health security. A bar at the bottom is labeled “operational capabilities.” An arrow points from that bar to a box with 10 strategic objectives: 1) Informed and empowered individuals and communities, 2) National health security workforce, 3) Integrated, scalable health care delivery systems, 4) Situational awareness, 5) Timely and effective communications, 6) Effective counter­measures enterprise, 7) Prevention/mitigation of environmental, other health threats, 8) Post-incident health recovery in planning and response, 9) Cross-border and global partnerships, and 10) Science, evaluation, quality improvement. An arrow points from that box to the box at the top At the top are the two overarching goals: to build community resilience and to strengthen and sustain health and emergency response systems.

The NHSS highlights the importance of improving coordination between Federal, State, local, and tribal planning, preparedness, and response activities. It further notes that planning should be guided by the principles articulated in the National Response Framework7 and other key sources of national homeland security doctrine, such as the National Incident Management System.8 These principles are particularly relevant for allocating scarce medical resources.

### Definition of Terms

For the purposes of this report, we used the following definitions:

#### “Policymakers”

We defined policymakers as government officials and agencies at the Federal, State, regional, or local level who have authority to develop and enforce policies and protocols that drive decisionmaking. For example, policymakers include:

- Federal departments and agencies (e.g., HHS, Department of Homeland Security)
- State and local public health officials
- State governing officials (e.g., governor, State legislature)
- Local governing officials (e.g., mayor, city council, county supervisors)
- State and local emergency management officials
- Tribal officials
- International health officials (e.g., World Health Organization, Pan American Health Organization).

#### “Providers”

We defined providers as individuals who are licensed to provide health care services under State or tribal law, international standards, or the laws of their country and health care organizations or institutions that provide patient care. Providers include, for example:

- Licensed individuals, such as physicians, nurses, social workers, pharmacists, and emergency medical technicians, including paramedics
- Health care organizations, such as health maintenance organizations, private practices, home care agencies, community health centers, emergency medical services organizations, and nongovernmental organizations
- Health care facilities or institutions, such as acute care hospitals, skilled nursing facilities, long-term care institutions, and psychiatric care facilities
- Health responder teams to catastrophic events (e.g. international, nongovernmental organizations, military).

#### “Public”

We defined the public as all community members and individuals not addressed as policymakers or health care providers, regardless of gender, race, ethnicity, sexual orientation, age, disability, setting, health status, or other defining characteristics.

#### “Mass Casualty Events”

We defined a mass casualty event (MCE) as a natural (e.g., earthquake, pandemic) or manmade (e.g., detonation of a nuclear device, conventional explosive, bioterror attack, building collapse) incident that suddenly or progressively generates large numbers of injured and/or ill people who require medical and/or mental health care. The magnitude of this increase in demand for medical care resources has the potential to outstrip the ability of a facility or a local, regional, or national public health and health care delivery system to deliver medical care services consistent with established standards of care.

A mass casualty event can occur suddenly, as is typically the case with an earthquake, tornado, or terrorist bombing,9 or it may evolve over hours to days, as frequently happens in a hurricane, flood, disease outbreak,10 or bioterror attack.11 Regardless of its rate of onset, the scope and complexity of an MCE can severely challenge even highly experienced and well-equipped health care providers and systems.12 Typically in an MCE, demand for medical care resources quickly outstrips the day-to-day capacity of local and regional health care providers, rendering them unable to meet patients’ needs at the level normally expected in a modern health care delivery system. When immediately available resources are clearly insufficient to meet patients’ needs, health care providers and hospitals must be prepared to swiftly implement contingency plans to accelerate the delivery of services. If this response is inadequate to address the situation, they may need to shift from the individual approach to health care, which is intended to deliver optimum care to each and every patient, to one that that seeks to do the most good for the most people with the resources at hand. This concept has come to be known as “crisis standards of care.”

#### “Scarce Resources”

For purposes of this review, our technical expert panel defined “scarce resources” as medical care resources that are likely to be scarce in a crisis care environment. Medical care resources include physical items (e.g., medical supplies, drugs, beds, equipment), services (e.g., medical treatments, nursing care, palliative care), and health care personnel (e.g., physicians, nurses, psychologists, laboratory technicians, other essential workers).

#### “Crisis Standards of Care”

The foundation for this Evidence-based Practice Center report was laid by the IOM Committee on Guidance for Establishing Standards of Care for Use in Disaster Situations, which published a landmark Letter Report in 2009.^13^ In this report, the committee offered the following definition of “crisis standards of care”:

“Crisis standards of care” is defined as a substantial change in usual health care operations and the level of care it is possible to deliver, which is made necessary by pervasive (e.g., pandemic influenza) or catastrophic (e.g., earthquake, hurricane) disaster. This change in the level of care delivered is justified by specific circumstances and is formally declared by a State government, in recognition that crisis operations will be in effect for a sustained period. The formal declaration that crisis standards of care are in operation enables specific legal/regulatory powers and protections for health care providers in the necessary tasks of allocating and using scarce resources and implementing alternative care facility operations.”

To ensure that patients receive the best possible care during a catastrophic event, the IOM Letter Report recommended that health care providers, organizations, government officials, and the public approach this challenge in a thoughtful and proactive way.13 The Letter Report proposed a national approach, anchored in four values:

1. Fairness. The approach should employ standards that are widely recognized as fair by all concerned, that are evidence-based, and that compassionately respond to the needs of individuals and the affected population. Proper stewardship of resources is essential to maintain the trust of patients and the community.
2. Equitable processes. The approach should be transparent in design and decision making and be consistent across populations and individuals without regard for race, ethnicity, ability to pay, socioeconomic status, preexisting health conditions, and other characteristics. When measures are taken, they should reflect the scale of the emergency and the degree of resource scarcity. Individuals who decide when and how to implement such standards should be accountable for their decisions. Governments must also be accountable for assuring appropriate protections and just allocation of resources.
3. Community and provider engagement, education, and communication. Stakeholder input (from institutions, organizations, providers, and the public) should be sought through a formalized process of engagement and collaboration.
4. The rule of law. Legal authority is required to properly empower necessary and appropriate actions during a crisis. Also, an appropriate legal environment is needed to facilitate implementation of crisis standards in a public health emergency. Otherwise, health care providers may be reluctant to make the difficult decisions that are needed.

Experts generally agree that optimizing resource allocation in an MCE will require a multifaceted approach that includes strategies to minimize less-urgent demand for health care services, effective techniques to boost the supply of medical resources for those who need them, and evidence-based guidance on how to make difficult resource allocation decisions in crisis care situations. The development and implementation of these strategies will require, in turn, a multidisciplinary approach that balances multiple considerations, including ethical and legal issues and the special needs of at-risk populations. To be successful, stakeholders from the provider community and the public must be actively engaged in the process of developing and implementing crisis standards of care.

One of the first and most critical steps in this process is to systematically review the literature to identify, grade, and summarize relevant evidence regarding how best to approach and manage this process. That is the task we undertook in preparing this report.

Our work builds on previous comprehensive governmental and nongovernmental reviews and reports.9, 13–18 Collectively, these reports provided our team with a conceptual framework for approaching and evaluating the extant literature on this topic. In addressing the Key Questions, this report builds on the existing literature by identifying allocation strategies that are supported by evidence, describing strategies for engaging providers, and identifying key concerns of the public regarding the allocation of scarce medical resources.

## Scope of the Review

This CER is intended to address four important dimensions regarding allocation of scarce resources in MCEs. By compiling a thorough, current, and comprehensive evidence review, we hope to help the Agency for Healthcare Research and Quality and the Office of the Assistant Secretary for Preparedness and Response provide State governments, as well as planning and provider communities, with the information they need to clarify processes and/or make difficult but necessary decisions in the setting of MCEs and other large-scale public health emergencies, as well as to identify future research and policy needs. While ideally we would have restricted this CER to incidents that triggered a formal disaster declaration, such as through a Stafford Act declaration, through the authority of the governor of a State, or within a single community or institution, such as a hospital, we learned that few studies reported this information consistently. Requiring such a declaration as an inclusion criterion would ensure comparability but might exclude important studies.

The scope of this review was intentionally designed to be broad for additional reasons. Because MCEs are, fortunately, rare, the number of opportunities to conduct rigorous empirical research is limited. Moreover, the assessment of strategies in the midst of an MCE and potential “diverting” of resources in the midst of more fundamental needs after the MCE raise important ethical considerations. Thus, our review comprised a broad range of study designs—several of which might not be considered sufficiently rigorous for inclusion in a typical systematic review.

An additional challenge is that the consideration of strategies to allocate scarce health care resources does not happen in an ethical, moral, or legal vacuum. In fact, it is critical to take not only patient preferences into account, but also the views of health care providers, family members, entire communities, and at-risk populations. In this issue, as in few others, the social context in which these decisions are played out is highly relevant to the conduct and relevance of a particular strategy. Our review specifically sought to assess a broad range of outcomes for the resource allocation strategies, including both health outcomes and ethical outcomes.

With these considerations in mind, this CER should be relevant to several important groups, including (1) policymakers charged with responsibility to devise and promulgate strategies to guide the actions of public health agencies and health care institutions during an MCE; (2) health care providers who may be faced with the need to allocate scarce resources during an MCE; (3) patients, family members, and loved ones who may be personally affected by these decisions; and (4) members of the wider community, who also have a stake in how these decisions are made.

## Key Questions

Before conducting the review, the study investigators and our technical expert panel refined each of the Key Questions. The populations, interventions, comparators, outcomes, timings, and settings (PICOTS) considered for each Key Question are described in the Methods chapter.

Key Question 1. What current or proposed strategies are available to policymakers to optimize the allocation and management of scarce resources during MCEs? What outcomes are associated with these strategies? What factors act as facilitators or barriers to their implementation or effectiveness?

Key Question 2. What current or proposed strategies are available to providers to optimize the allocation of scarce resources during MCEs? What outcomes are associated with these strategies? What factors are identified as facilitators or barriers to their implementation or effectiveness?

Key Question 3. What are the public’s key perceptions and concerns (e.g., values, equity, transparency, communication, and public input) regarding the development and implementation of strategies to allocate and manage scarce resources during both actual and potential MCEs?

Key Question 4. What current and proposed methods are available to engage providers in discussions regarding the development and implementation of strategies to allocate and manage scarce resources both in planning for and during an MCE? What outcomes are associated with these strategies? What factors are identified as facilitators or barriers to engaging providers in these discussions?

## Organization of This Report

In the sections that follow, we describe the methods used to identify, analyze, and classify published studies that address each of the four Key Questions. We then summarize the key findings for each of these Key Questions, with supporting tables and appendixes. As noted above, because we encountered a substantial number of studies that examined a promising resource allocation technique, technology, or practice but used study designs that lacked comparison groups, we grouped these “proof of concept” studies differently and summarized them in a separate section. We then include a summary of strategies that have been proposed by professional organizations or by the Federal government. Finally, recognizing the IOM Letter Report’s call for thoughtful State plans, we reviewed a set of State plans for common themes, features, and gaps. Our objective is to provide readers with a comprehensive view of the current evidence regarding allocation of scarce resources during MCEs and propose options for strengthening the evidence base going forward. Moreover, by highlighting strengths and gaps in the existing evidence base, we hope to inform the development of a research agenda that will quickly improve our nation’s capacity to prepare, mitigate, respond, and quickly recover from large-scale health emergencies.