# Peer Reviewers

Susan Allan, M.D., J.D., M.P.H.

University of Washington

Seattle, WA

Georges Benjamin, M.D., FACP, FNAPA, FACEP (E), Hon FRSPH

American Public Health Association

Washington, DC

Colonel Connie Boatright, M.S.N., R.N.

Managed Emergency Surge for Healthcare (MESH)

Consultant Indiana Primary Health Care Association

Indianapolis, IN

Eric Frykberg, M.D.

University of Florida

Jacksonville, FL

Cheri Hummel

California Hospital Association

Sacramento, CA

Roberta Kanter, M.D.

Upstate Medical University

Syracuse, NY

Leslee Stein-Spencer, R.N., M.S.

Chicago Fire Department

Chicago, IL

Joseph Waeckerle, M.D., FACEP

University of Missouri–Kansas City School of Medicine

Leawood, KS

Matthew Wynia, M.D., M.P.H.

University of Chicago

Chicago, IL