# Technical Expert Panel

Tim Davis, M.D., M.P.H.

National Disaster Medical System

Washington, DC

Daniel Fagbuyi, M.D.

Children’s National Medical Center

Washington, DC

DeAnn Friedholm, M.P.A.

Consumers Union

Washington, DC

Cynthia Hansen, Ph.D.

Department of Health and Human Services

Office of the Assistant Secretary for Preparedness and Response

Office of Preparedness and Emergency Operations

Washington, DC

James Hodge, J.D., L.L.M.

Arizona State University

Tempe, AZ

Mary Jagim, R.N., B.S.N., CEN, FAEN

Intelligent InSites

Moorhead, MN

Kathy Kinlaw, M.Div.

Emory University

Atlanta, GA

Deborah Levy, Ph.D., M.P.H.

Centers for Disease Control and Prevention

National Center for Preparedness, Detection, and Control of Infectious Diseases

Atlanta, GA

Meredith Li-Vollmer, Ph.D., M.A.

Seattle & King County

Seattle, WA

Jeffrey Lowell, M.D.

Washington University School of Medicine

St. Louis, MO

Major General Lester Martinez-Lopez, M.D., M.P.H., FAAFP

Brandon Regional Hospital

Valrico, FL

Mark Williams, M.D., FACP, FHM

Northwestern University Feinberg School of Medicine

Chicago, IL

Charlotte Yeh, M.D.

AARP Services, Inc.

Tewksbury, MA