# Discussion

The United States faces a wide range of threats to its health security. The tragic events of September 11, 2001, and the subsequent anthrax attacks highlight the ongoing danger of terrorism. In the decade following the September 11, 2001, attacks, the major mass-casualty events on U.S. soil involved natural disasters, such as hurricanes Katrina and Rita, and naturally emerging biological threats, such as SARS and 2009 H1N1 influenza. The recent earthquakes that claimed so many lives around the world remind us that temblors of sufficient magnitude can cause widespread loss of life, even in highly developed nations, such as Chile, New Zealand, and Japan.

The predominant belief among authorities is that it is only a matter of time before a major natural or man-made disaster outstrips the capacity of our health care system to respond. Whether the incident is local, regional, or national in scope, the common denominator is a stark imbalance between immediate needs and existing resources, such as personnel, supplies, medications, and/or equipment at the incident site. When an MCE occurs, first responders, physicians, nurses, and other health care providers will be forced to make extremely difficult decisions about the delivery of care in the most demanding of circumstances with significant clinical, legal, and ethical ramifications. Therefore, strategies to allocate and manage scarce resources in mass casualty events (MCEs) must be founded in rigorous scientific scrutiny, grounded in empirical evidence, and thoughtfully considered before they are implemented. This is the context that led the Office of the Assistant Secretary for Preparedness and Response (ASPR) to request the Agency for Healthcare Quality and Research (AHRQ) to commission this comparative effectiveness review.

## Key Findings

At the current time, there is limited evidence to help policymakers select the most effective strategies to allocate scarce resources during MCEs. However, although the evidence is largely not definitive, there are some specific strategies that appear promising. It is generally accepted that rapid deployment of biological countermeasures, such as mass vaccinations, mass dispensing of antivirals, or the rapid distribution of prophylactic antibiotics, could reduce demand for health care resources in the immediate aftermath of a bioterror attack or pandemic. There is low- to medium-strength evidence that a “push” method to deliver medications, such as via U.S. Postal Service letter carriers, is more effective than conventional approaches that seek to “pull” patients to a fixed point of dispensing (POD) or a neighborhood pharmacy. However, most of these assessments used speed of distribution rather than accuracy or appropriateness as their measure of outcome.

There is low to medium strength evidence that better management of POD operations can speed throughput and therefore accelerate distribution of biological countermeasures. There is also low strength evidence that public distribution of non-biological countermeasures, such as N-95 respirators or surgical masks, can reduce demand for hospital beds, intensive care unit beds, and ventilators.

There is little evidence to support particular approaches to optimizing resource allocation and use in conditions of scarcity. There is some evidence that resource use can be optimized by better load sharing between facilities. There is also limited evidence that pressure on overburdened health care resources may be reduced by transferring patients to more distant hospitals and by opening temporary facilities, such as a mobile field hospital.

Other than these observations, there is no evidence to guide policymakers in their deliberations and recommendations regarding how to allocate scarce resources under crisis standards of care. A focused and prioritized agenda for developing policy guidelines is urgently needed.

The evidence base to guide providers on the best strategies to optimize the allocation of scarce resources during MCEs is equally limited. Numerous strategies have been proposed to help providers and health care systems respond to MCEs. Unfortunately, evidence is insufficient to favor one of them over the others. Rigorous studies are rare, and much of the evidence that exists comes from simulations, drills, and exercises, rather than empirical evidence drawn from actual events. Many of the studies we reviewed did not report outcomes that are relevant to patients or providers. In most cases, the applicability of the study’s findings beyond the immediate exercise setting or particular MCE was questionable.

The only provider-oriented strategy subjected to comparative assessment to date is field triage during MCEs. Even then, the strength of evidence to support use of one approach over others is low. A systematic review of field triage systems, comprising 11 papers that evaluated eight different triage tools, found limited evidence for the validity of any existing tool.62 Published derivation and validation studies were of relatively poor quality, in part because most were based on small sample sizes. Few existing triage tools are specifically designed for use with pediatric disaster victims.

The accuracy with which providers can apply various triage tools is also unclear. More than half of the studies of triage accuracy were based on exercises or drills, rather than on actual events. Exercise-based assessments may not accurately reflect how a triage tool will perform in an actual MCE. For example, four studies of START, a widely used prehospital triage tool, reported accuracy rates of 62 percent to 82 percent. But when one group used the tool in an actual MCE, they found that it poorly allocated patients because providers were confused about the meaning of the different triage categories. Research is urgently needed to develop a simple, reliable, and accurate method to triage casualties in an MCE.

For every other category of provider-based strategies, the evidence base was insufficient to support a conclusion at more than a low level of evidence. With the exception of the previously mentioned studies of pre-hospital triage, few strategies were evaluated in more than three studies. As a result, there is very limited evidence to guide providers on the best strategies to use to reduce demand, optimize use of resources, augment existing resources, or apply crisis standards of care in the setting of an MCE.

The addition of promising but untested strategies increased the pool of interesting and potentially promising ideas, but none of the studies in this group is backed by sufficient evidence to favor one promising idea over another. A few studies, such as those describing the emerging technique of “damage control surgery,” reported highly encouraging findings. However, most of the studies we reviewed were prone to at least a medium level of bias. Therefore, we judged the strength of evidence for most of the provider-based interventions described to date as low or insufficient.

First responders, physicians, and other health care providers need evidence-based guidance on how to best manage resource use and, when all else fails, employ crisis standards of care. Unfortunately, few strategies have been examined with sufficient scientific rigor to guide practice or policy. There is a compelling need to implement a prioritized research agenda and secure sufficient support to conduct these studies.

Although the evidence base is minimal regarding public perceptions of how scarce resources should be maximized and crisis standards applied during MCEs, the few published findings are generally consistent. Firm evidence regarding public perceptions is limited. The majority of the studies we reviewed reported data collected from a single community, four of which were outside the United States. Nevertheless, because these studies were well designed and their findings are generally consistent with each other, we judged the strength of evidence as medium. Collectively, these studies indicate that citizens are interested and motivated to participate in community forums. Participants in these forums expressed the belief that a successful allocation system should balance the goals of ensuring the functioning of society, saving the greatest number of people, protecting the most vulnerable, reducing deaths and hospitalizations, and treating people fairly. Although the public wanted appropriate guidelines to be established in advance with the input of health care professionals, they believed that the guiding parameters should allow providers a degree of flexibility to make allocation decisions based on their specific demand and supply situation.

The viewpoints elicited to date should be interpreted with caution. They are drawn from a relatively small number of participants, including four groups outside the United States. More substantive public input through community engagement forums will give credence to the process and ensure the level of public confidence needed to secure citizen cooperation during future MCEs. Consequently, we recommend that more public engagement studies of the sort reported to date be conducted in a variety of communities and settings. Determining the most effective ways to engage the public and to disseminate information to policymakers and providers is a matter of urgent concern.

Promising strategies exist to engage providers in developing resource allocation strategies, including crisis standards of care, but none has been sufficiently evaluated. The 14 studies we examined indicate that it is possible to engage health care providers in productive discussions, but there was insufficient evidence to recommend one engagement strategy as superior to the others. Nonetheless, several important themes emerged from our synthesis of this work. First, inclusive processes that engage all major stakeholders work better than those that do not. Ideally, such efforts should involve representatives of the relevant provider institutions, professional associations, State and/or local government, academia, and the public. Second, systematic and iterative processes produce more robust and satisfying products—such as a critical planning framework or a consensus plan—than those that do not. Third, involving credible subject matter experts enhances participation, satisfaction, and the quality of the final product. Finally, engaging nontraditional providers or groups adds innovation and breadth. Additional research will be needed to confirm these observations.

In addition to assessing the published research literature, we also analyzed the consensus guidelines of various specialty societies and task forces and strategies outlined in existing State plans. These efforts produced two additional summary findings:

Currently, the consensus guidelines and recommendations of specialty societies and government advisory groups rest on an insufficient body of evidence. Few offer actionable guidance to policymakers, health care providers, or the public. Most of the consensus panel recommendations we reviewed are either badly dated or pitched at a level unlikely to be useful to policymakers or health care providers. This was particularly true of guidelines produced by specialty societies.

In many cases, the intent of the consensus task force was to develop principles that providers at the local level could use to derive their own protocols. This approach contradicts the recommendations of the committee that produced the IOM Letter Report, which expressed the hope that their guidance would produce “a single, national framework for responding to crises in a fair, equitable and transparent matter.”13

It is interesting to note that committees sponsored by the Society for Critical Care Medicine and the American Thoracic Society’s Bioethics Task Force recommended that intensive care unit resources be allocated on the basis of “first come, first served.” This position contradicts the view of the public, based on the limited number of surveys and public engagement studies published to date. The public, like the authors of the IOM letter report, want to see resource allocation decisions made in a proactive and thoughtful way that protects the core interests of society, as defined by the populace.

Some States have made progress toward adopting plans to manage and, if necessary, allocate resources under crisis standards of care. We reviewed plans from 11 States and one U.S. territory and abstracted information regarding how policymakers and providers should respond in the context of an MCE. Some plans seek to reduce less-urgent use of health care resources through such measures as mass dispensing of vaccine, prophylactic medications, and self-quarantine. Others seek to optimize use of existing resources through triage, load balancing, repurposing of facilities, more efficient use of providers, and substitution of more plentiful alternatives. Most seek to augment existing resources by tapping stockpiling and other reserves and by activating mutual aid agreements. Finally, some plans recommend that, when all else fails, crisis standards of care should be implemented based on predefined priorities, with the understanding that this means certain patients will receive comfort care rather than aggressive intervention. However, few of the plans defined detailed approaches for making these determinations that could be readily put into practice. Moreover, few plans proposed legal and operational frameworks for shifting to crisis standards of care. Although these strategies are appealing in principle, and most have a high degree of face validity, they are supported by a limited base of evidence.

## Limitations of the Review Methods

As with all attempts to systematically review a vast body of literature about a complex topic, it was necessary to make a number of decisions to clearly define the scope of the review, identify and assess the key studies, and synthesize the findings. We considered each decision carefully and believe we have a strong rationale for the choices we made. In making these choices, however, some trade-offs were made that could be seen as limitations of the study.

First, we chose to keep the scope of the review quite broad. While this was useful in identifying resource allocation strategies from across the full spectrum of preparedness and response, it made it difficult to conduct targeted searches of the literature. It is possible that our more general search did not identify specialized studies that would have been found if the CER had focused on a small set of specific strategies. The use of reference mining and forward searches mitigates this possibility to some extent.

Second, because of the challenges in conducting research on MCEs, we included study designs in this CER that are normally considered to produce lower levels of evidence, including cohort, before-after, and quasi-experimental studies. In the end, we retained even studies that referenced historical performance as the comparison standard, but graded the level of evidence accordingly. To further broaden our coverage of the topic, we included studies that had some measure of feasibility or performance but lacked a comparison group. Finally, we identified consensus recommendations by specialty societies and national panels. None of these provided new evidence, but they did speak to important dimensions of Key Questions 1 and 2.

Because we included a broader range of study types in the CER, the validated instruments for assessing quality typically used in CERs were not applicable. We therefore searched for other relevant rubrics. Finding no single scale that seemed appropriate for our topic, we combined elements of several and developed our own composite scale. While the scale seemed to work well, it has not been validated. In addition, as in most rating schemes, there is some degree of subjectivity in assigning scores to each item in our quality assessment scales. To minimize the potential bias, two reviewers rated each study independently and any discrepant scores were reconciled.

We were unable to perform meta-analyses that often accompany CERs due to the wide range of topics covered, the different measures of effectiveness employed across studies, and the small number of studies focused on any one particular strategy. As such, the synthesis of the results and the grading of strength of evidence for each Key Question are primarily qualitative in nature. While the process was systematic, there is some subjectivity involved.

Although the scope of our review was broad, it did not address every aspect of the management of MCEs. For example, our review did not address clinical or logistical aspects of EMS care and transport of patients, other than the technique of field triage in the setting of MCEs. Finally, although our literature search procedures were extensive, the possibility of publication bias still exists.

## Limitations of the Evidence Base

By their very nature, MCEs are uncommon and largely unanticipated. MCEs also vary widely from one another with respect to geography, cause, onset, setting, duration, scale, and many other characteristics. This high degree of unpredictability, coupled with the variability and rapid evolving nature of MCEs, make it difficult to draw generalizable inferences from any single event. The technical and ethical dimensions of disaster research are challenging as well. Unlike directors of clinical trials, researchers interested in improving response to MCEs cannot prospectively enroll and allocate their subjects into treatment groups with precisely controlled study protocols. By their nature, MCEs invite and sometimes require improvisation. This makes such basic processes as systematic data collection difficult at best.

Some research teams have attempted to model alternative interventions using computer simulation or have tested them in simulated exercises and drills. Although these approaches provide useful data, they raise significant internal and external validity concerns. It is far from clear how generalizable the findings of these studies are to actual MCEs. It is difficult for the most realistic models and drills to reproduce the demanding environment of an actual disaster or MCE. It is equally difficult to predict human behavior in such incidents, especially if the rescuers and health care providers lack prior experience.

The current evidence base is characterized by marked variability in methodologies and a relative paucity of studies that addressed any single strategy. The multiplicity of options assessed to date means that few strategies have been sufficiently evaluated to confirm their effectiveness. With the exception of prehospital (field) triage, most of the strategies we identified were assessed by no more than three studies. This limited the strength of evidence available to compare one strategy to another. As a result, it was almost impossible to reach firm conclusions regarding their comparative effectiveness.

The different measures of effectiveness employed by authors posed another limitation. Most of the articles that met our generous screening criteria for inclusion assessed the impact of a current or proposed strategy on a clinical process or some aspect of a process. Relatively few examined outcomes. When outcomes were measured, they were often secondary outcomes that served as proxies for the true outcome of interest (e.g., survival). Second, as addressed by Shekelle and colleagues (in an evidence review on assessing the quality of patient safety interventions), the outcomes of process interventions are often, if not always, inextricably linked with the specific context in which they are implemented.214 Thus, no guarantee exists that an intervention that was successfully implemented in one setting will produce the same results if it is implemented in a different setting. This challenge is dramatically amplified in the context of MCEs because the conditions on the ground can vary dramatically from one incident to another.