# Excluded Studies

## Short Form Rejects

### No Key Questions Addressed (N=692)

1 A 2002 national assessment of state trauma system development, emergency medical services resources, and disaster readiness for mass casualty events. [Washington, DC]. US Dept of Health and Human Services, Health Resources and Services Administration. 2003.
2 Supplement A, Command and Control, Incident Command and Management System Public Health Guidance for Community-Level Preparedness and Response to Severe Acute Respiratory Syndrome (SARS) Version 2. Department of Health and Human Services, Centers for Disease Control and Prevention. Contract No.: Document Number|.
3 Special report. The Oklahoma City bombing: mass casualties and the local hospital response. Hosp Secur Saf Manage. Sep. 1995;16(5):5-10.
4 Establishing a mass casualty management system. Washington, DC. Pan American Health Organization, Pan American Sanitary Bureau, Regional Office of the World Health Organization. 1995.
5 Few problems for hospitals treating speedway walkway collapse victims. Hosp Secur Saf Manage. Sep. 2000;21(5):13-4.
6 Expect 2 waves of patients after terrorist attack. ED Manag. Jan. 2000;12(1):8-9. [pmid: 11067320].
7 VETERANS HEALTH ADMINISTRATION EMERGENCY MANAGEMENT PROGRAM PROCEDURES. Department of Veterans Affairs Veterans Health Administration. 2000.
8 What’s the ASC’s role for mass casualties?. OR Manager. Nov. 2002;18(11):23-5.
9 New aspects in mass casualties. Anasthesiol Intensivmed Notfallmed Schmerzther. Sep. 2002;37(9):537-8. [pmid: 12215939].
10 Collaboration and coordination in mass casualty disaster plans. Healthc Hazard Manage Monit. Jan. 2002;15(5):1-7.
11 Guidelines for the use of foreign field hospitals in the aftermath of sudden-impact disaster. Prehosp Disaster Med. Oct–Dec. 2003;18(4):278-90. [pmid: 15310039].
12 Checklists for mass casualty disaster plans. Disaster Management and Response. 2003;1(1):31.
13 Is it OK to have someone very quickly screen incoming patients?. ED Manag. Jan. 2004;16(1):8-9. [pmid: 14719285].
14 Staffing up helps EDs handle Katrina surge. ED Manag. Oct. 2005;17(10):112-3. [pmid: 16235503].
15 Disaster relief. Hurricane victims with HIV/AIDS overwhelm resources. AIDS Policy Law. Sep. 23. 2005;20(18):1. 4.
16 Health care system surge capacity recognition, preparedness, and response. Ann Emerg Med. Feb. 2005;45(2):239. [pmid: 15671992].
17 Riding out the surge. JEMS: Journal of Emergency Medical Services. 2005;30(11):42.
18 Altered standards of care in mass casualty events. Rockville, MD. Agency for Healthcare Research and Quality. 2005.
19 Proceedings of the Consensus Conference “The Science of Surge”. May 17, 2006. San Francisco, California, USA. Acad Emerg Med. Nov. 2006;13(11):1087-253.
20 Office of the Assistant Secretary for Preparedness and Response; HHS Public Health Emergency Medical Countermeasures Enterprise implementation plan for chemical, biological, radiological and nuclear threats. Notice Fed Regist. Apr. 23. 2007;72(77):20117-28.
21 AORN guidance statement: mass casualty, triage, and evacuation. AORN J. Apr. 4. 2007;85(4):792-5. 7. 800. [pmid: 17458024].
22 National disaster management guidelines. New Delhi. National Disaster Management Authority. 2007.
23 Improving health system preparedness for terrorism and mass casualty events : recommendations for action : a consensus report from the AMA/APHA Linkages Leadership Summit. Chicago. July 7–8, 2005. New Orleans. June 7–8, 2006. Chicago, IL. American Medical Association : American Public Health Association. 2007.
24 DEPARTMENT OF VETERANS AFFAIRS AND DEPARTMENT OF DEFENSE. CONTINGENCY PLAN: Department of Veteran s Affairs Veterans Health Administration. 2007. Contract No.: Document Number|.
25 HIV PEP rarely warranted after mass casualties. CDC guidelines for HIV, hepatitis and tetanus. AIDS Alert. Sep. 2008;23(9):107-8. [pmid: 18939309].
26 ED handles 30 burn patients after plant fire and explosion in Georgia. ED management : the monthly update on emergency department management. 2008;20(4):37-9. [pmid: 18689220].
27 Wireless Sensor Networks - 5th European Conference, EWSN 2008, Proceedings. Lecture Notes in Computer Science (including subseries Lecture Notes in Artificial Intelligence and Lecture Notes in Bioinformatics). Bologna. 2008.
28 Flight 1404. The response and lessons learned from the crash at Denver International Airport. JEMS. Sep. 2009;34(9):36-43. 5.
29 ‘Reverse triage’ adds to surge capacity. ED Manag. Jun. 2009;21(6):64-5. [pmid: 19548605].
30 Abstracts of note: the bioethics literature. Cambridge Quarterly of Healthcare Ethics. 2010;19(1):154-6.
31 Preparedness and Response to a Rural Mass Casualty Incident: Workshop Summary. Washington DC. National Academy of Sciences. 2011.
32 EDs credit drills, community engagement with helping them manage casualties from tornado crises. ED Manag. Jul. 2011;23(7):73-6. [pmid: 21749003].
33 Minnesota Department of Health. All-Hazards Response and Recovery Base plan. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention and Assistant Secretary for Preparedness and Response. June. 2009. Contract No.: Document Number|.
34 Project ER One. Dirksen Building. May. 8. 2003. Contract No.: Document Number|.
35 Alabama Preparedness Guide 001 (APG 001): A Guide for State, Tribal, and Local Governments Alabama Emergency Management Agency. November. 2009. Contract No.: Document Number|.
36 Aaby K, Cook D, Herrmann J, Jordan C, Wood K. Simulating a mass vaccination clinic: Health Care Management Science. 2008. [updated 2008; cited 2008 December 30]; Available from: http://www.isr.umd.edu/Labs/CIM/projects/clinic/hcms.pdf.
37 Aacharya RP, Gastmans C, Denier Y. Emergency department triage: an ethical analysis. BMC Emerg Med. 2011;11:16. [pmid: 21982119].
38 Ablah E, Konda K, Kelley CL. Factors Predicting Individual Emergency Preparedness: A Multi-State Analysis of 2006 Brfss Data. Biosecurity and Bioterrorism-Biodefense Strategy Practice and Science. Sep. 2009;7(3):317-30.
39 Ablah E, Konda KS, Konda K, Melbourne M, Ingoglia JN, Gebbie KM. Emergency preparedness training and response among community health centers and local health departments: results from a multi-state survey. J Community Health. Jun. 2010;35(3):285-93. [pmid: 20379843].
40 Ablah E, Nickels D, Hodle A, Wolfe DJ. Public health investigation: focus group study of a regional infectious disease exercise. Public Health Nurs. Nov–Dec. 2008;25(6):546-53. [pmid: 18950419].
41 Acosta J, Stern S, Uscher-Pines L, Williams MV, Yeung D, Garnett J, et al. Building community resilience to disasters. 2011. Contract No.: Document Number|.
42 Adams HA. Patient care in mass casualty disaster: Statement of the interdisciplinary working group on shock of the DIVI. Patientenversorgung im katastrophenfall: Stellungnahme der interdisziplinären arbeitsgruppe (IAG) schock der deutschen interdisziplinären vereinigung für intensivmedizin und notfallmedizin (DIVI). 2006;109(7):583-6.
43 Adams K. The South Carolina Nurses Association unveils preliminary findings of the nursing school survey on competencies for entry-level registered nurses related to mass casualty incidents. S C Nurse. Oct-Dec. 2005;12(4):1. [pmid: 16252783].
44 Adini B, Cohen R, Bar-Dayan Y. Risk and protective factors that impact survival in emergencies--the time has come for an upgrade in preventive emergency population behavior. Prehosp Disaster Med. Nov–Dec. 2008;23(6):507-9. [pmid: 19557965].
45 Adini B, Goldberg A, Cohen R, Bar-Dayan Y. Relationship Between Standards of Procedures for Pandemic Flu and Level of Hospital Performance in Simulated Drills. Annals of Emergency Medicine. 2008;52(3):223-9. [pmid: 18468729].
46 Adini B, Goldberg A, Laor D, Cohen R, Bar-Dayan Y. Factors that may influence the preparation of standards of procedures for dealing with mass-casualty incidents. Prehosp Disaster Med. May–Jun. 2007;22(3):175-80. [pmid: 17894209].
47 Adler J. Mass casualty management in earthquakes and air crashes. Isr Med Assoc J. May. 2002;4(5):373-4. [pmid: 12040829].
48 Adoff S, Leaming JM, Terndrup TE. Ability of Hospitals to Meet influenza Pandemic Surge Capacity Requirements: Regionalization in Disaster Response. Annals of Emergency Medicine. Sep. 2010;56(3):S137-S.
49 Albores P, Shaw D. Responding to terrorist attacks and natural disasters: A case study using simulation. Kuhl ME, Steiger NM, Armstrong FB, Joines JA, editors. 2005.
50 Alexander DA, Klein S. Biochemical terrorism: too awful to contemplate, too serious to ignore: subjective literature review. Br J Psychiatry. Dec. 2003;183:491-7. [pmid: 14645019].
51 Alfici R, Ashkenazi I, Kessel B. Management of victims in a mass casualty incident caused by a terrorist bombing: treatment algorithms for stable, unstable, and in extremis victims. Mil Med. Dec. 2006;171(12):1155-62. [pmid: 17256673].
52 Allen D. Crisis care. Nurs Stand. Dec. 4–10. 2002;17(12):14-5. [pmid: 12518575].
53 Altevogt BM. Institute of Medicine (U.S.) Forum on Medical and Public Health Preparedness for Catastrophic Events. Medical surge capacity workshop summary / [electronic resource]. Washington, DC. National Academies Press. 2010. [cited RAND Library-NYAM.
54 Altintepe L, Guney I, Tonbul Z, Turk S, Mazi M, Agca E, et al. Early and intensive fluid replacement prevents acute renal failure in the crush cases associated with spontaneous collapse of an apartment in Konya. Ren Fail. 2007;29(6):737-41. [pmid: 17763170].
55 Álvarez Fernández JA. Sanitary response in disasters. Learnings from the terrorist attack against the twin towers of New York City. Medicina Clinica. 2001;117(20):790-2. [pmid: 11784511].
56 American College of Radiology. Disaster Preparedness for Radiology Professionals: A Primer for Radiologists, Radiation Oncologists and Medical Physicists. 2006. Contract No.: Document Number|.
57 Anderson ED, Hodge JG Jr, Yeskey K. Emergency legal preparedness among select US local governments. Disaster Medicine and Public Health Preparedness. 2009;3(Suppl 2):S176-84. [pmid: 19797962].
58 Andradottir S, Chiu WC, Goldsman D, Lee ML, Tsui KL, Fisman DN, et al. Simulation of Strategies for Containing Pandemic Influenza. Proceedings of the 2010 Winter Simulation Conference. 2010:2221-9.
59 Andradottir S, Chiu WC, Goldsman D, Lee ML, Tsui KL, Sander B, et al. Reactive strategies for containing developing outbreaks of pandemic influenza. Bmc Public Health. Feb. 2011:11. [pmid: 21208451].
60 Argon NT, Ziya S, Righter R. Scheduling impatient jobs in a clearing system with insights on patient triage in mass casualty incidents. Probability in the Engineering and Informational Sciences. 2008;22(3):301-32.
61 Arino J, Bowman CS, Moghadas SM. Antiviral resistance during pandemic influenza: implications for stockpiling and drug use. BMC Infectious Diseases. 2009;9(8). 22. January. 2009.
62 Arino J, Brauer F, van den Driessche P, Watmough J, Wu J. Simple models for containment of a pandemic. J R Soc Interface. Jun. 22. 2006;3(8):453-7. [pmid: 16849273].
63 Arizona Department of Health Services. Emergency Response Plan: Division of Public Health Services Bureau of Emergency Preparedness and Response. August. 2007. Contract No.: Document Number|.
64 Armstrong JH, Frykberg ER, Burris DG. Toward a National Standard in Primary Mass Casualty Triage. Disaster Medicine and Public Health Preparedness. 2008;2(Suppl 1):S1-57. [pmid: 18769259].
65 Armstrong JH, Hammond J, Hirshberg A, Frykberg ER. Is overtriage associated with increased mortality? The evidence says “yes”. Disaster Medicine and Public Health Preparedness. 2008;2(1):4-5. [pmid: 18388647].
66 Arnold JL, Tsai MC, Halpern P, Smithline H, Stok E, Ersoy G. Mass-casualty, terrorist bombings: epidemiological outcomes, resource utilization, and time course of emergency needs (Part I). Prehosp Disaster Med. Jul–Sep. 2003;18(3):220-34. [pmid: 15141862].
67 Arora H, Raghu TS, Vinze A, editors. Optimizing regional aid during public health emergencies: An autonomic resource allocation approach. Proceedings of the Annual Hawaii International Conference on System Sciences. 2007. Big Island, HI. SCOPUS.
68 Asaeda G. The day that the START triage system came to a STOP: observations from the World Trade Center disaster. Acad Emerg Med. Mar. 2002;9(3):255-6. [pmid: 11874794].
69 Ashkan K, Edwards RJ, Bell BA. Crisis in resources: a neurosurgical prospective. Br J Neurosurg. Aug. 2001;15(4):342-6. [pmid: 11599451].
70 Ashkenazi I, Olsha O, Schecter WP, Kessel B, Khashan T, Alfici R. Inadequate mass-casualty knowledge base adversely affects treatment decisions by trauma care providers: Survey on hospital response following a terrorist bombing. Prehosp Disaster Med. Jul–Aug. 2009;24(4):342-7. [pmid: 19806559].
71 Association of American Medical Colleges, Expert Panel on Bioterrorism Education for Medical Students (U.S.). Training future physicians about weapons of mass destruction: report of the Expert Panel on Bioterrorism Education for Medical Students. Washington, D.C. Association of American Medical Colleges. 2003. [cited RAND Library-NYAM.
72 Association of State and Territorial Health Officials. At-risk populations project : federal and national-level document review. Arlington, VA. Association of State and Territorial Health Officials. 2008. [cited RAND Library-NYAM.
73 Aucoin RG. Hurricane Katrina--one hospital’s experience. Crit Care. Feb. 2006;10(1):109. [pmid: 16420646].
74 Augustine JJ. ‘How many can you take?’ A medical mass-casualty incident requires consultation and coordination in its response. EMS Mag. Aug. 5. 2007;36(8):23-7. [pmid: 17784707].
75 Ayliffe L, Lagace C, Muldoon P. The use of a mental health triage assessment tool in a busy Canadian tertiary care children’s hospital. Journal of Emergency Nursing. 2005;31(2):161-5. [pmid: 15834382].
76 Baccam P, Boechler M. Public health response to an anthrax attack: An evaluation of vaccination policy options. Biosecurity and Bioterrorism-Biodefense Strategy Practice and Science. Mar. 2007;5(1):26-34.
77 Baccam P, Willauer D, Krometis J, Ma YC, Sen A, Boechler M. Mass Prophylaxis Dispensing Concerns: Traffic and Public Access to Pods. Biosecurity and Bioterrorism-Biodefense Strategy Practice and Science. Jun. 2011;9(2):139-51.
78 Baez JE, Fuente Adl, Santos I. Forschungsinstitut zur Zukunft der Arbeit. Do natural disasters affect human capital? an assessment based on existing empirical evidence. [electronic resource]. Bonn, Germany. Forschungsinstitut zur Zukunft der Arbeit. 2010. [cited RAND Library-NYAM.
79 Bail HJ, Kleber C, Haas NP, Fischer P, Mahlke L, Matthes G, et al. Distribution planning of injured persons in mass disasters or catastrophes. Structuring of hospital capacities exemplified by the catastrophe network of the German Society for Trauma Surgery (DGU). Unfallchirurg. Oct. 2009;112(10):870-7. [pmid: 19756454].
80 Bail HJ, Weidringer JW, Mahlke L, Matthes G, Sturm J, Ruchholtz S. Network disaster medicine: Proposal of the AG Notfallmedizin of the DGU on structuring of hospital capacities in case of a disaster. Netzwerk katastrophenmedizin: Ein vorschlag der AG notfallmedizin der DGU zur strukturierung der krankenhauskapazitäten im katastrophenfall. 2006;9(3):309-11.
81 Baker UK. Mass thermal injuries: care from American military physicians for the victims in the railroad catastrophe in Bashkiria. Voen Med Zh. Sep. 1990;(9):21-3. [pmid: 2264293].
82 Balbis L, Gaetani F, Miniciardi R, Portella G, Sacile R, Trasforini E. A decisional model for dynamic allocation of resources in natural disasters management. Brebbia CA, editor. Risk Analysis Iii. 2002:243-52.
83 Balkstra CR. Altered standards of care: an update on pandemic flu planning. Georgia Nursing. 2010;70(1):5.
84 Barbera J, Macintyre A, Gostin L, Inglesby T, O’Toole T, DeAtley C, et al. Large-scale quarantine following biological terrorism in the United States: scientific examination, logistic and legal limits, and possible consequences. JAMA. Dec. 5. 2001;286(21):2711-7. [pmid: 11730447].
85 Barbisch DF, Koenig KL. Understanding surge capacity: essential elements. Acad Emerg Med. Nov. 2006;13(11):1098-102. [pmid: 17085738].
86 Bar-Dayan Y. Editorial comments: -PLUS prehospital mass-casualty triage: a strategy for addressing unusual injury mechanisms. Prehosp Disaster Med. May–Jun. 2010;25(3):237-8. [pmid: 20586017].
87 Bar-Dayan Y. Editorial comments-Psychological effects of patient surge in large-scale emergencies: a quality improvement tool for hospital and clinic capacity planning and response. Prehosp Disaster Med. Mar–Apr. 2010;25(2):115-6. [pmid: 20467988].
88 Barillo DJ. Burn centers and disaster response. Journal of Burn Care & Research. Sep–Oct. 2006;27(5):558-9. [pmid: 16998384].
89 Barillo DJ. Planning for burn mass casualty incidents. Journal of Trauma - Injury, Infection and Critical Care. 2007;62(6 SUPPL).
90 Barishansky RM, Langan J. Surge capacity. Is your system prepared for the victims of a large-scale incident?. EMS Mag. Apr. 2009;38(4):36-40. [pmid: 19522336].
91 Bascetta CA. United States Government Accountability Office, United States Congress House Committee on Homeland Security Subcommittee on Management, Investigations, and Oversight. Emergency preparedness state efforts to plan for medical surge could benefit from shared guidance for allocating scarce medical resources : testimony before the Subcommittee on Management, Investigations, and Oversight, Committee on Homeland Security, House of Representatives. [electronic resource]. Washington, D.C. United States Government Accountability Office. 2010. [cited RAND Library-NYAM.
92 Bashir Z, Ransom J. Full-use preparedness: addressing the 2004–2005 influenza vaccine shortage. J Public Health Manag Pract. Jul–Aug. 2005;11(4):375-7. [pmid: 15958941].
93 Baskett PJ. Ethics in disaster medicine. Prehosp Disaster Med. Jan–Mar. 1994;9(1):4-5. [pmid: 10155487].
94 Bayram JD, Zuabi S, Subbarao I. Disaster Metrics: Quantitative Benchmarking of Hospital Surge Capacity in Trauma-Related Multiple Casualty Events. Disaster Medicine and Public Health Preparedness. Jun. 2011;5(2):117-24. [pmid: 21685307].
95 Beekley AC. Mass casualties in combat: Lessons learned. Journal of Trauma - Injury, Infection and Critical Care. 2007;62(6 SUPPL):S39-40.
96 Bengtsson L, Lu X, Thorson A, Garfield R, von Schreeb J. Improved response to disasters and outbreaks by tracking population movements with mobile phone network data: a post-earthquake geospatial study in Haiti. PLoS Medicine. 2011;8(8).
97 Benjaminov O, Sklair-Levy M, Rivkind A, Cohen M, Bar-Tal G, Stein M. Role of radiology in evaluation of terror attack victims. American Journal of Roentgenology. 2006;187(3):609-16. [pmid: 16928920].
98 Bergeron MA. Virginia Tech’s larger lessons. Behav Healthc. Aug. 2007;27(8):41-2. [pmid: 18030843].
99 Berlow S. Association of State and Territorial Health Officials (U.S.). Addressing mental health and suicide after disasters : working with state health agencies. Washington D.C. Association of State and Territorial Health Officials. 2006. [cited RAND Library-NYAM.
100 Berr TF, Meron G, Hodl W, Laggner AN. Alarm plan BLUE--a concept for managing mass emergencies in emergency ambulatory care of the new Vienna general hospital. Wien Klin Wochenschr Suppl. 1992;194:10-1. [pmid: 1288020].
101 Bethea S. Pharmacy mass casualty disaster plan implemented after the train wreck. Hosp Pharm. Mar. 1994;29(3):224-5. [pmid: 10132697].
102 Biddinger PD, Savoia E, Massin-Short SB, Preston J, Stoto MA. Public health emergency preparedness exercises: lessons learned. Public Health Rep. Nov-Dec. 2010;125(Suppl 5):100-6. [pmid: 21133066].
103 Biddinger PD, Zane RD. Abt Associates; United States Agency for Healthcare Research and Quality; United States Health Resources and Services Administration. Hospital assessment and recovery guide. [electronic resource]. Rockville, MD. United States Dept. of Health and Human Services, Agency for Healthcare Research and Quality. 2010. [cited RAND Library-NYAM.
104 Biddinger PD, Zane RD. Abt Associates; United States Agency for Healthcare Research and Quality; United States Health Resources and Services Administration. Hospital evacuation decision guide. [electronic resource]. Rockville, MD. U.S. Dept. of Health and Human Services, Agency for Healthcare Research and Quality. 2010. [cited RAND Library-NYAM.
105 Birnbaum ML. Editorial comments-Evaluation of medical command and control using performance indicators during a full-scale major aircraft crash exercise. Prehosp Disaster Med. Mar–Apr. 2010;25(2):124-5. [pmid: 20467990].
106 Blaivas M, Kuhn W, Reynolds B, Brannam L. Change in differential diagnosis and patient management with the use of portable ultrasound in a remote setting. Wilderness & Environmental Medicine. Spr. 2005;16(1):38-41. [pmid: 15813146].
107 Bland SA. Management of the irradiated casualty. J R Army Med Corps. Sep. 2004;150(3 Suppl 1):5-9. [pmid: 15615103].
108 Blecken A, Danne C, Dangelmaier W, Rottkemper B, Hellingrath B. Ieee. Optimal Stock Relocation under Uncertainty in Post-disaster Humanitarian Operations. 43rd Hawaii International Conference on Systems Sciences. 2010;1–5:1125-34.
109 Bloch YH, Leiba A, Veaacnin N, Paizer Y, Schwartz D, Kraskas A, et al. Managing mild casualties in mass-casualty incidents: lessons learned from an aborted terrorist attack. Prehosp Disaster Med. May–Jun. 2007;22(3):181-5. [pmid: 17894210].
110 Bloch YH, Schwartz D, Pinkert M, Blumenfeld A, Avinoam S, Hevion G, et al. Distribution of casualties in a mass-casualty incident with three local hospitals in the periphery of a densely populated area: lessons learned from the medical management of a terrorist attack. Prehosp Disaster Med. May–Jun. 2007;22(3):186-92. [pmid: 17894211].
111 Boatright JR. Emergency medical service--mass gathering action plans. J Emerg Nurs. Jun. 2004;30(3):253-6. [pmid: 15192681].
112 Boev BV, Iastrebov VS. Prediction of mass panic in anthropogenic accidents and disasters. Zh Nevrol Psikhiatr Im S S Korsakova. 2009;109(11):81-8. [pmid: 20120067].
113 Bonnett CJ, Peery BN, Cantrill SV, Pons PT, Haukoos JS, McVaney KE, et al. Surge capacity: a proposed conceptual framework. Am J Emerg Med. Mar. 2007;25(3):297-306. [pmid: 17349904].
114 Borzotta A. Civilian and military trauma: Does civilian training prepare surgeons for the battlefield?. American Surgeon. 2011;77(1):25-6. [pmid: 21396300].
115 Boscarino JA, Figley CR, Adams RE. Fear of terrorism in New York after the September 11 terrorist attacks: implications for emergency mental health and preparedness. Int J Emerg Ment Health. Fall. 2003;5(4):199-209. [pmid: 14730761].
116 Bouzianas DG. Medical countermeasures to protect humans from anthrax bioterrorism. Trends in Microbiology. Nov. 2009;17(11):522-8. [pmid: 19781945].
117 Bouzianas DG. Current and Future Medical Approaches To Combat the Anthrax Threat. Journal of Medicinal Chemistry. Jun. 2010;53(11):4305-31. [pmid: 20102155].
118 Boyle R, Childress J, Gravely SD, Kalpowitz L, Melnick A, Rothstein M, et al. Health departments, hospitals, and pandemic flu: overlapping ethical and legal questions. Journal of Law, Medicine & Ethics. 2007;35(4):53-4.
119 Boyte WR. A sense of duty. Health Aff (Millwood). Mar–Apr. 2006;25(2):481-2. [pmid: 16522592].
120 Braithwaite RS, Fridsma D, Roberts MS. The cost-effectiveness of strategies to reduce mortality from an intentional release of aerosolized anthrax spores. Medical Decision Making. Mar–Apr. 2006;26(2):182-93. [pmid: 16525172].
121 Brandeau ML, McCoy JH, Hupert N, Holty JE, Bravata DM. Recommendations for modeling disaster responses in public health and medicine: a position paper of the society for medical decision making. Med Decis Making. Jul–Aug. 2009;29(4):438-60. [pmid: 19605887].
122 Branson RD. Patient needs should drive ventilator selection for stockpiling: “handy” Devices may not “Lend a Hand”. Respiratory Care. 2011;56(6):879-81. [pmid: 21679496].
123 Branson RD, Rubinson L. A single ventilator for multiple simulated patients to meet disaster surge. Acad Emerg Med. Dec. 2006;13(12):1352-3. author reply 3–4. [pmid: 17158729].
124 Branson RD, Rubinson L. Mechanical ventilation in mass casualty scenarios. Respir Care. Jan. 2008;53(1):38-9. [pmid: 18173858].
125 Braun BI, Wineman NV, Finn NL, Barbera JA, Schmaltz SP, Loeb JM. Integrating hospitals into community emergency preparedness planning. Ann Intern Med. Jun. 6. 2006;144(11):799-811. [pmid: 16754922].
126 Brazle EM. MCI (mass casualty incident) success story. How an EMS system improved its MCI-response strategy through planning & practice. A Journal of emergency medical services : JEMS. 2001;26(6):58-60. 6.
127 Briggs S. Triage in mass casualty incidents: challenges and controversies. Am J Disaster Med. Mar-Apr. 2007;2(2):57. [pmid: 18271152].
128 Briggs SM. Earthquakes. Surg Clin North Am. Jun. 2006;86(3):537-44. [pmid: 16781268].
129 Brinker A, Prior K, Schumacher J. Personal protection during resuscitation of casualties contaminated with chemical or biological warfare agents--a survey of medical first responders. Prehosp Disaster Med. Nov–Dec. 2009;24(6):525-8. [pmid: 20301071].
130 Brookmeyer R, Johnson E, Bollinger R. Modeling the optimum duration of antibiotic prophylaxis in an anthrax outbreak. Proceedings of the National Academy of Sciences of the United States of America. Aug. 2003;100(17):10129-32. [pmid: 12890865].
131 Brookmeyer R, Johnson E, Bollinger R. Public health vaccination policies for containing an anthrax outbreak. Nature. Dec. 2004;432(7019):901-4. [pmid: 15602561].
132 Brown M, Beatty J, O’Keefe S, Bierenbaum A, Scott M, Hodgson M, et al. Planning for hospital emergency mass-casualty decontamination by the US Department of Veterans Affairs. Disaster Manag Response. Jul–Sep. 2004;2(3):75-80. [pmid: 15286597].
133 Burnweit C, Stylianos S. Disaster response in a pediatric field hospital: lessons learned in Haiti. Journal of Pediatric Surgery. Jun. 2011;46(6):1131-9. [pmid: 21683211].
134 Butler AS, Panzer AM, Goldfrank LR. Institute of Medicine (US) Committee on Responding to the Psychological Consequences of Terrorism Board on Neuroscience and Behavioral Health. Preparing for the psychological consequences of terrorism : a public health strategy. Washington, DC. National Academies Press. 2003. [cited RAND Library-NYAM.
135 Camacho-McAdoo G. Triage following a natural disaster: a Haitian experience. J Emerg Nurs. Jul. 2010;36(4):385-7. [pmid: 20624582].
136 Campbell AM, Jones PC. Prepositioning supplies in preparation for disasters. European Journal of Operational Research. Mar. 2011;209(2):156-65.
137 Canini L, Andreoletti L, Ferrari P, D’Angelo R, Blanchon T, Lemaitre M, et al. Surgical Mask to Prevent Influenza Transmission in Households: A Cluster Randomized Trial. Plos One. Nov. 2010;5(11).
138 Carlisle D. Nurses and the media. Careful what you say. Nurs Times. Aug. 21–27. 1991;87(34):29-30. [pmid: 1881779].
139 Carmona RH. The science of surge: an all-hazard approach is critical to improving public health preparedness. Acad Emerg Med. Nov. 2006;13(11):1097. [pmid: 16968686].
140 Caro JJ, DeRenzo EG, Coleman CN, Weinstock DM, Knebel AR. Resource Allocation After a Nuclear Detonation Incident: Unaltered Standards of Ethical Decision Making. Disaster Medicine and Public Health Preparedness. Mar. 2011;5:S46-S53. [pmid: 21402811].
141 Carr BG, Addyson DK, Kahn JM. Variation in critical care beds per capita in the United States: Implications for pandemic and disaster planning. JAMA - Journal of the American Medical Association. 2010;14;303(14):1371-2.
142 Carr S, Roberts S. Planning for Infectious Disease Outbreaks: A Geographic Disease Spread, Clinic Location, and Resource Allocation Simulation. Proceedings of the 2010 Winter Simulation Conference. 2010:2171-84.
143 Carrasco LR, Lee VJ, Chen MI, Matchar DB, Thompson JP, Cook AR. Strategies for antiviral stockpiling for future influenza pandemics: a global epidemic-economic perspective. Journal of the Royal Society Interface. Sep. 2011;8(62):1307-13.
144 Ceglowski R, Churilov L, Wasserheil J. Don’t panic--prepare: towards crisis-aware models of emergency department operations. Clin Invest Med. Dec. 2005;28(6):320-2. [pmid: 16450623].
145 Center for Health Policy, Columbia School of Nursing. Adapting Standards of Care under Extreme Conditions: Guidance for Professionals During Disasters, Pandemics, and Other Extreme Emergencies. American Nurses Association. March. 2008. Contract No.: Document Number|.
146 Center for Mental Health Services (US), United States Office of Justice Programs, Office for Victims of Crimes. Mental health response to mass violence and terrorism: a training manual. Rockville, MD. US Dept of Health and Human Services, Substance Abuse and Mental Health Services Administration, Center for Mental Health Services. 2004. [cited RAND Library-NYAM.
147 Centers for Disease Control and Prevention (U.S) Coordinating Office for Terrorism Preparedness and Emergency Response. Public health preparedness : strengthening CDC’s emergency response : a CDC report on Terrorism Preparedness and Emergency Response (TPER) - funded activities for fiscal year 2007. Atlanta, GA. Centers for Disease Control and Prevention. 2009. [cited RAND Library-NYAM.
148 Centers for Disease Control and Prevention (U.S) Office of Public Health Preparedness and Response. Public health preparedness strengthening the nation’s emergency response state by state : a report on CDC-funded preparedness and response activities in 50 states, 4 cities, and 8 U.S. insular areas. [electronic resource]. Atlanta, GA. Centers for Disease Control and Prevention, Office of Public Health Preparedness and Response. 2010. [cited RAND Library-NYAM.
149 Chan EW-M, Jackson BA, Nelson C, Parker AM, Shelton SR, Wasserman J, et al. Initial evaluation of the Cities Readiness Initiative. [electronic resource]. 2009. [cited RAND Library-NYAM.
150 Chang E, Backer H, Bey T, Koenig K. Maximizing medical and health outcomes after a catastrophic disaster: Defining a new “crisis standard of care”. Western Journal of Emergency Medicine. 2008;9(3).
151 Chang P, Hsu YS, Tzeng YM, Sang YY, Hou IC, Kao WF. The development of intelligent, triage-based, mass-gathering emergency medical service PDA support systems. J Nurs Res. Sep. 2004;12(3):227-36. [pmid: 15362014].
152 Chang Y, Wilkinson S, Brunsdon D, Seville E, Potangaroa R. An integrated approach: managing resources for post-disaster reconstruction. Disasters. Oct. 2011;35(4):739-65. [pmid: 21913934].
153 Chapman K, Arbon P. Are nurses ready? Disaster preparedness in the acute setting. Australasian Emergency Nursing Journal. 2008;11(3):135-44.
154 Checchi F, Gayer M, Grais RF, Mills EJ. Public health in crisis-affected populations: a practical guide for decision-makers. HPN Network Paper - Humanitarian Practice Network, Overseas Development Institute. [Bulletin]. 2007;(61):57.
155 Chen G, Lai W, Liu F, Mao Q, Tu F, Wen J, et al. The dragon strikes: lessons from the Wenchuan earthquake. Anesth Analg. Mar. 1. 2010;110(3):908-15. [pmid: 20185667].
156 Chess C, Calia J, O’Neill KM. Communication triage: an anthrax case study. Biosecur Bioterror. 2004;2(2):106-11. [pmid: 15225404].
157 Childers AK, Visagamurthy G, Taaffe K. Prioritizing patients for evacuation from a health-care facility. Transportation Research Record. 2009:38-45.
158 Christen HT, Maniscalco PM. EMS incident management: the treatment sector in mass casualty events. A multi-part series. Emerg Med Serv. Jun. 46. 1998;27(6):28-8. [pmid: 10180395].
159 Christian MD, Devereaux AV, Dichter JR, Geiling JA, Rubinson L. Definitive care for the critically ill during a disaster: current capabilities and limitations: from a Task Force for Mass Critical Care summit meeting, January 26–27, 2007, Chicago, IL. Chest. May. 2008;133(5 Suppl):8S-17S. [pmid: 18460503].
160 Christian MD, Farmer JC, Young BP. Disaster triage and allocation of scarce resources. Medicine SoCC. Fundamentals of Disaster Management. Third Edition. Mount Prospect, IL. 2009.
161 Claassen C, Kashner TM, Kashner TK, Xuan L, Larkin GL. Psychiatric emergency “surge capacity” following acts of terrorism and mass violence with high media impact: what is required?. Gen Hosp Psychiatry. May–Jun. 2011;33(3):287-93. [pmid: 21601726].
162 Clancy CM. Emergency departments in crisis: implications for accessibility, quality, and safety. Am J Med Qual. Jan–Feb. 2007;22(1):59-62. [pmid: 17227879].
163 Clarke CE, Chess C. False alarms, real challenges--one university’s communication response to the 2001 anthrax crisis. Biosecur Bioterror. 2006;4(1):74-83. [pmid: 16545026].
164 Claudius I, Behar S, Ballow S, Wood R, Stevenson K, Blake N, et al. Disaster drill exercise documentation and management: are we drilling to standard?. J Emerg Nurs. Dec. 2008;34(6):504-8. [pmid: 19022071].
165 Coffey N. And the good news is.... a provider that makes the effort to meet local reporters during good times has a better chance of a balanced story if a crisis occurs. Provider. Jun. 1998;24(6):55-7. [pmid: 10180044].
166 Coker R. UK preparedness for pandemic influenza. British Medical Journal. 2007;12;334(7601):965-6.
167 Coleman CN, Knebel AR, Hick JL, Weinstock DM, Casagrande R, Caro JJ, et al. Scarce resources for nuclear detonation: project overview and challenges. Disaster Med Public Health Prep. Mar. 2011;5(Suppl 1):S13-9. [pmid: 21402805].
168 Collander B, Green B, Millo Y, Shamloo C, Donnellan J, DeAtley C. Development of an “all-hazards” hospital disaster preparedness training course utilizing multi-modality teaching. Prehosp Disaster Med. Jan–Feb. 2008;23(1):63-7. discussion 8–9. [pmid: 18491664].
169 Cone DC, MacMillan DS. Mass-casualty triage systems: a hint of science. Acad Emerg Med. Aug. 2005;12(8):739-41. [pmid: 16079427].
170 Cone DC, Weir SD, Bogucki S. Convergent volunteerism. Ann Emerg Med. Apr. 2003;41(4):457-62. [pmid: 12658243].
171 Connor KM, Foa EB, Davidson JR. Practical assessment and evaluation of mental health problems following a mass disaster. J Clin Psychiatry. 2006;67(Suppl 2):26-33. [pmid: 16602812].
172 Cooney WP 3rd. Disasters and mass casualties: II. J Am Acad Orthop Surg. Aug. 2007;15(8):449. [pmid: 17664364].
173 Copeland C. Library of Congress Congressional Research Service. Hurricane-damaged drinking water and wastewater facilities : impacts, needs, and response. Washington, D.C. Library of Congress, Congressional Research Service. 2006. [cited RAND Library-NYAM.
174 Cotta C. Effective patient prioritization in mass casualty incidents using hyperheuristics and the pilot method. OR Spectrum. 2011:1-22.
175 Cotter S. Mass-casualty response: the vital first few minutes. EMS Mag. Apr. 2009;38(4):29-34. [pmid: 19522335].
176 Courtney B, Morhard R, Bouri N, Cicero A. Expanding practitioner scopes of practice during public health emergencies: experiences from the 2009 H1N1 pandemic vaccination efforts. Biosecur Bioterror. Sep. 2010;8(3):223-31. [pmid: 20825333].
177 Courtney B, Toner E, Waldhorn R, Franco C, Rambhia K, Norwood A, et al. Healthcare coalitions: the new foundation for national healthcare preparedness and response for catastrophic health emergencies. Biosecur Bioterror. Jun. 2009;7(2):153-63. [pmid: 19635000].
178 Cox E, Briggs S. Disaster nursing. New frontiers for critical care. Crit Care Nurse. Jun. 2004;24(3):16-22. quiz 3–4. [pmid: 15206292].
179 Crabtree J. Terrorist homicide bombings: a primer for preparation. J Burn Care Res. Sep–Oct. 2006;27(5):576-88. [pmid: 16998388].
180 Craft DL, Wein LM, Wilkins AH. Analyzing bioterror response logistics: The case of anthrax. Management Science. 2005;51(5):679-94.
181 Cragin CL. The role of the Department of Defense in domestic weapons of mass destruction consequence management. Mil Med. Dec. 2001;166(12 Suppl):1-3. [pmid: 11778417].
182 Cretikos M, Eastwood K, Dalton C, Merritt T, Tuyl F, Winn L, et al. Household disaster preparedness and information sources: rapid cluster survey after a storm in New South Wales. Australia. BMC Public Health. [Journal article]. 2008;8(195). 4. June. 2008.
183 Crowe S, Utley M, Walker G, Grove P, Pagel C. A model to evaluate mass vaccination against pneumococcus as a countermeasure against pandemic influenza. Vaccine. 2011;29(31):5065-77. [pmid: 21539879].
184 Culley JM. Use of a Computer-Mediated Delphi Process to Validate a Mass Casualty Conceptual Model. Comput Inform Nurs. 2010. Oct. 25.
185 Culley JM, Effken JA. Conceptual model for a mass casualty continuum of care. AMIA Annu Symp Proc. 2007;920.
186 Cummings G, Della Corte F. Disaster medicine education for physicians: A systematic review. International Journal of Disaster Medicine. 2006;4(3):125-36.
187 Curren S, Kodolikar S. Interstate planning for the Strategic National Stockpile: experiences in five regions. Washington D.C. Association of State and Territorial Health Officials. 2005. [cited RAND Library-NYAM.
188 Custer JW, Watson CM, Dwyer J, Kaczka DW, Simon BA, Easley RB. Critical evaluation of emergency stockpile ventilators in an in vitro model of pediatric lung injury. Pediatric Critical Care Medicine. 2011.
189 Dai J, Zhao Y, Li G. Wenchuan earthquake: response of Chinese dental professionals. Br Dent J. Mar. 14. 2009;206(5):273-6. [pmid: 19287428].
190 Daily E, Padjen P, Birnbaum M. A review of competencies developed for disaster healthcare providers: limitations of current processes and applicability. Prehosp Disaster Med. Sep–Oct. 2010;25(5):387-95. [pmid: 21053183].
191 Danon Y, Bar Y. The planning and activities of toxicology centers in mass casualties. Voen Med Zh. Aug. 1990;(8):72-3. [pmid: 2267771].
192 Dara SI, Farmer JC. Preparedness Lessons from Modern Disasters and Wars. Critical Care Clinics. Jan. 2009;25(1). 47-+.
193 Das TK, Savachkin AA, Zhu YL. A large-scale simulation model of pandemic influenza outbreaks for development of dynamic mitigation strategies. Iie Transactions. 2008;40(9):893-905.
194 Dausey DJ, Buehler JW, Lurie N. Designing and conducting tabletop exercises to assess public health preparedness for manmade and naturally occurring biological threats. BMC Public Health. 2007;7:92. [pmid: 17535426].
195 Davids MS, Case C, Hornung R, Chao NJ, Chute JP, Coleman CN, et al. Assessing Surge Capacity for Radiation Victims with Marrow Toxicity. Biology of Blood and Marrow Transplantation. Oct. 2010;16(10):1436-41. [pmid: 20399880].
196 Davis LM, Blanchard JC. Are local health responders ready for biological and chemical terrorism?. Santa Monica, CA. RAND Corporation. 2002. [cited RAND Library-NYAM.
197 Davis LM, Ringel JS. Public health preparedness for chemical, biological, radiological, and nuclear weapons. [electronic resource]. Santa Monica, Calif. RAND Corporation. 2010. [cited RAND Library-NYAM.
198 Davis MV. University of North Carolina School of Public Health, North Carolina Institute for Public Health. Evaluation of improvements in North Carolina public health capacity to plan, prepare, and respond to public health emergencies. Chapel Hill, N.C. UNC School of Public Health. 2004. [cited RANDLibrary-NYAM.
199 De Boer J. Order in chaos: modelling medical management in disasters. Eur J Emerg Med. Jun. 1999;6(2):141-8. [pmid: 10461559].
200 Deshmukh N. Mass casualty aboard USS Kitty Hawk (CV 63) January 2005--lessons learned. Military medicine. 2006;171(1).
201 DiBenedetto DV. Managing employee health and productivity after mass disasters: Preparing, recognizing, and responding to posttraumatic stress and other health issues--Part II. Lippincotts Case Manag. Jan–Feb. 2006;11(1):47-51. [pmid: 16444122].
202 DiCarlo AL, Maher C, Hick JL, Hanfling D, Dainiak N, Chao N, et al. Radiation injury after a nuclear detonation: medical consequences and the need for scarce resources allocation. Disaster Med Public Health Prep. Mar. 2011;5(Suppl 1):S32-44. [pmid: 21402810].
203 DiGiovanni C Jr. The spectrum of human reactions to terrorist attacks with weapons of mass destruction: early management considerations. Prehosp Disaster Med. Jul–Sep. 2003;18(3):253-7. [pmid: 15141866].
204 Dolev E. Ethical issues in military medicine. Isr J Med Sci. Sep. 1996;32(9):785-8. [pmid: 8865840].
205 Dolev E, Priel I. Ethical commitment during mass casualties. Harefuah. Mar. 15. 1996;130(6):424-6. [pmid: 8707205].
206 Dominguez OJ Jr. MCI on the high seas. EMS Mag. Feb. 42. 2008;37(2):4.
207 Domres BD, Rashid A, Grundgeiger J, Gromer S, Kees T, Hecker N, et al. European survey on decontamination in mass casualty incidents. Am J Disaster Med. May–Jun. 2009;4(3):147-52. [pmid: 19739457].
208 Doron VO, Danon I. A new approach to resolving the problem of rendering medical care in mass casualties. Voen Med Zh. Sep. 1990;(9):18-9. [pmid: 2264291].
209 Dress JM, Horton EH, Florida R. Music, mud & medicine. Woodstock ‘94: a maniacal, musical mass-casualty incident. Emergency Medical Services. 30. 1995;24(1):21-2. [pmid: 10139459].
210 Drogovoz VA, Orlov OI, BerkovichIu A. A model of mass medical service system for emergency recovery based on mobile telemedical complexes. Med Tekh. 2009;(1):1-5. [pmid: 19248606].
211 Drury J, Cocking C, Reicher S. Everyone for themselves? A comparative study of crowd solidarity among emergency survivors. Br J Soc Psychol. Sep. 2009;48(Pt 3):487-506. [pmid: 18789185].
212 Ducharme J. Mass casualties and triage at a sporting event: Commentary [1]. British Journal of Sports Medicine. 2002;36(2):88.
213 Eastridge BJ, Blackbourne L, Wade CE, Holcomb JB. Radiologic diagnosis of explosion casualties. Am J Disaster Med. Sep–Oct. 2008;3(5):301-5. [pmid: 19069034].
214 Edwards NA, Caldicott DG, Eliseo T, Pearce A. Truth hurts--hard lessons from Australia’s largest mass casualty exercise with contaminated patients. Emerg Med Australas. Apr. 2006;18(2):185-95. [pmid: 16669945].
215 Einav S, Aharonson-Daniel L, Weissman C, Freund HR, Peleg K. In-hospital resource utilization during multiple casualty incidents. Ann Surg. Apr. 2006;243(4):533-40. [pmid: 16552206].
216 Eiseman B, Chandler JG. Military medical surge capacity in times of war and natural disaster. J Trauma. Jan. 2006;60(1):237-9. [pmid: 16456463].
217 Elizabeth K, Gopakumar H, Koshy G. Red Tide Phenomenon Leading to Panic Attack and Mass Casualty among Children in Coastal Kerala. Indian J Community Med. Apr. 2010;35(2):342-3. [pmid: 20922120].
218 Ende N, Azzam EI. Consideration for the treatment of mass casualties based on pathology of the fatalities of Hiroshima and Nagasaki. Int J Radiat Biol. 2011. Jan. 4.
219 Engel A, Soudack M, Ofer A, Nitecki SS, Ghersin E, Fischer D, et al. Coping with war mass casualties in a hospital under fire: The radiology experience. American Journal of Roentgenology. 2009;193(5):1212-21. [pmid: 19843733].
220 Ensman RG Jr. Crisis communication. What to do when the press comes knocking on your door. Balance. Jun. 1998;2(4):19-21.
221 Esbitt D. The Strategic National Stockpile: roles and responsibilities of health care professionals for receiving the stockpile assets. Disaster Manag Response. Jul–Sep. 2003;1(3):68-70. [pmid: 12888743].
222 Eyre A, Fertel N, Fisher JM, Gunn SW, Hampton D, Lederman B, et al. Disaster coordination and management: summary and action plans. Prehosp Disaster Med. Jan–Mar. 2001;16(1):22-5. [pmid: 11367933].
223 Fairbrother G, Galea S. Project CFHS. Terrorism, mental health, and September 11: lessons learned about providing mental health services to a traumatized population. New York, NY. Century Foundation. 2005. [cited RAND Library-NYAM.
224 Falagas ME, Kiriaze IJ. Reaction to the threat of influenza pandemic: the mass media and the public. Crit Care. 2006;10(2):408. [pmid: 16677417].
225 Farrar JA. Pandemic influenza: allocating scarce critical care resources. J Nurs Adm. Jan. 2010;40(1):1-3. [pmid: 20010369].
226 Feng ZL, Towers S, Yang YD. Modeling the Effects of Vaccination and Treatment on Pandemic Influenza. Aaps Journal. Sep. 2011;13(3):427-37. [pmid: 21656080].
227 Fetter JC. Psychosocial Response to Mass Casualty Terrorism: Guidelines for Physicians. Prim Care Companion J Clin Psychiatry. 2005;7(2):49-52. [pmid: 15841195].
228 Fiedrich F, Gehbauer F, Rickers U. Optimized resource allocation for emergency response after earthquake disasters. Safety Science. Jun-Aug. 2000;35(1–3):41-57.
229 Fink A. Models of management in mass disasters and critical situations. Lijec Vjesn. 2007;129(Suppl 5):28-37. [pmid: 18283873].
230 Fink SL. Worst case: rethinking tertiary triage protocols in pandemics and other health emergencies. Crit Care. Jan. 21. 2010;14(1):103. [pmid: 20122291].
231 Fischer P, Wafaisade A, Bail H, Domres B, Kabir K, Braun T. Civil protection and disaster medicine in Germany today. Langenbeck’s Archives of Surgery. 2011:1-6.
232 FitzGerald DJ, Sztajnkrycer MD, Crocco TJ. Chemical weapon functional exercise--Cincinnati: observations and lessons learned from a “typical medium-sized” city’s response to simulated terrorism utilizing Weapons of Mass Destruction. Public Health Rep. May–Jun. 2003;118(3):205-14. [pmid: 12766215].
233 Fitzgerald DJ, Sztajnkrycer MD, Crocco TJ. Chemical weapon functional exercise - Cincinnati: Observations and lessons learned from a “typical medium-sized” city’s response to simulated terrorism utilizing Weapons of Mass Destruction. Public Health Reports. 2003;118(3):205-14. [pmid: 12766215].
234 Flood AB, Nicolalde RJ, Demidenko E, Williams BB, Shapiro A, Wiley AL Jr, et al. A framework for comparative evaluation of dosimetric methods to triage a large population following a radiological event. Radiation Measurements. 2011;46(9):916-22. [pmid: 21949481].
235 Fowler RA, Sanders GD, Bravata DM, Nouri B, Gastwirth JM, Peterson D, et al. Cost-effectiveness of defending against bioterrorism: A comparison of vaccination and antibiotic prophylaxis against anthrax. Annals of Internal Medicine. Apr. 2005;142(8):601-10. [pmid: 15838066].
236 Franc-Law JM, Bullard MJ, Della Corte F. Accuracy of computer simulation to predict patient flow during mass-casualty incidents. Prehosp Disaster Med. Jul–Aug. 2008;23(4):354-60. [pmid: 18935951].
237 Freimuth VS, Hilyard KM, Barge JK, Sokler LA. Action, not talk: a simulation of risk communication during the first hours of a pandemic. Health Promotion Practice. 3. 2008;9(4 suppl):5s-44s. [pmid: 18936254].
238 Fricker RD, Jacobson JO, Davis LM. Measuring and evaluating local preparedness for a chemical or biological terrorist attack. Santa Monica, CA. RAND Corporation. 2002. [cited RAND Library-NYAM.
239 Friedl HP, Trentz O, Hoffmann R, Kossmann T. Clinical management problems in mass accidents. Chirurg. Apr. 1991;62(4):239-42. [pmid: 1860349].
240 Frykberg ER. Principles of Mass Casualty Management Following Terrorist Disasters. Annals of Surgery. 2004;239(3):319-21. [pmid: 15075647].
241 Galloro V. Screen test. HCA tries to move nonemergency patients out of ER. Mod Healthc. Apr. 26. 2004;34(17):12.
242 Gamelli RL, Purdue GF, Greenhalgh DG, Yurt RW, Kagan RJ, Kealey P, et al. Disaster management and the ABA plan. Journal of Burn Care & Rehabilitation. Mar–Apr. 2005;26(2):102-6. [pmid: 15756109].
243 Ganz A, Yu X, Schafer J, D’Hauwe S, Nathanson LA, Burstein J, et al., editors. DIORAMA: Dynamic information collection and resource tracking architecture. 2010. Annual International Conference of the IEEE Engineering in Medicine and Biology Society, EMBC’10. 2010. Buenos Aires. SCOPUS.
244 Gao HG Qin Q Li DJ Zhang WD Zeng Z Tang SY Triage algorithm analysis of 2621 patients 3 weeks after Wenchuan earthquakeChinese Journal of Evidence-Based Medicine2008 2008 8 9 718 21
245 Gao LL, Miller A, Daniels WJ. Chemical and biological terrorism preparedness - Web-based resources. Applied Occupational and Environmental Hygiene. 2000;15(8):592-5. [pmid: 10957813].
246 Garner A. Documentation and tagging of casualties in multiple casualty incidents. Emerg Med (Fremantle). Oct-Dec. 2003;15(5–6):475-9. [pmid: 14992064].
247 Garrison MW, Miller G, Rohan E. Cincinnati’s collaborative response for mass casualty incidents. J Emerg Nurs. Jul–Aug. 1990;16(4):274-8. [pmid: 2385062].
248 Gazetov BM, Teryaev VG, Goryainova MG. EMERGENCY MEDICAL-CARE IN DISASTERS. Sovetskaya Meditsina. 1990;(9):18-22.
249 Gebbie KM, Peterson CA, Subbarao I, White KM. Adapting standards of care under extreme conditions. Disaster Med Public Health Prep. Jun. 2009;3(2):111-6. [pmid: 19190493].
250 Gebbie KM, Valas J, Merrill J, Morse S. Role of exercises and drills in the evaluation of public health in an emergency response. Prehospital and Disaster Medicine. 2006;21(3):173-82. [pmid: 16892882].
251 Gensheimer KF, Meltzer MI, Postema AS, Strikas RA. Influenza Pandemic Preparedness. Emerging Infectious Diseases. 2003;9(12):1645-8. [pmid: 14725306].
252 Georgetown University Center for Law and the Public’s Health, Centers for Disease Control and Prevention (U.S.), National Governors’ Associationm, National Conference of State Legislatures, Association of State and Territorial Health Officials (U.S.), National Association of County & City Health Officials (U.S.), et al. The model state emergency health powers act. Washington D.C. Center for Law and the Public’s Health, Georgetown University Law Center. 2001. [cited RAND Library-NYAM.
253 Georgopoulos PG, Fedele P, Shade P, Lioy PJ, Hodgson M, Longmire A, et al. Hospital response to chemical terrorism: Personal protective equipment, training, and operations planning. American Journal of Industrial Medicine. 2004;46(5):432-45. [pmid: 15490471].
254 Gibson MJ, Hayunga M. AARP (Organization) We can do better : lessons learned for protecting older persons in disasters. Washington, DC. AARP Public Policy Institute. 2006. [cited RAND Library-NYAM.
255 Ginter PM, Duncan WJ, McCormick LC, Rucks AC, Wingate MS, Abdolrasulnia M. Effective response to large-scale disasters: the need for high-reliability preparedness networks. Int J Mass Emergencies and Disasters. 2006;24:331-49.
256 Giovachino M, Carey N. Modeling the consequences of bioterrorism response. Military Medicine. 2001;166(11):925-30. [pmid: 11725318].
257 Glass TA, Schoch-Spana M. Bioterrorism and the people: how to vaccinate a city against panic. Clinical Infectious Diseases. 2002;34(2):217-23. [pmid: 11740711].
258 Glick DE. Focus your leadership. Preparing for a major incident response. EMS Mag. Oct. 2007;36(10):144. [pmid: 17983108].
259 Goddard NL, Delpech VC, Watson JM, Regan M, Nicoll A. Lessons learned from SARS: the experience of the Health Protection Agency, England. Public Health. Jan. 2006;120(1):27-32. [pmid: 16297417].
260 Gojovic MZ, Sander B, Fisman D, Krahn MD, Bauch CT. Modelling mitigation strategies for pandemic (H1N1) 2009. Canadian Medical Association Journal. Nov. 2009;181(10):673-80. [pmid: 19825923].
261 Goldfrank LR, Liverman CT. Institute of Medicine (US) Committee on Personal Protective Equipment for Healthcare Workers During an Influenza Pandemic, Institute of Medicine (US) Board on Health Sciences Policy, National Academies Press (U.S.). Preparing for an influenza pandemic : personal protective equipment for healthcare workers. Washington, D.C. National Academies Press. 2008. [cited RAND Library-NYAM.
262 Goldstein ML. United States Government Accountability Office, United States Congress. House.Committee on Homeland Security. Subcommittee on Emergency Communications PaR. Emergency preparedness : improved planning and coordination necessary for modernization and integration of public alert and warning system : testimony before Subcommittee on Economic Development, Public Buildings, and Emergency Management, Committee on Transportation and Infrastructure, House of Representatives. Washington D.C. United States Government Accountability Office. 2009. [cited RAND Library-NYAM.
263 Gomez D, Haas B, Ahmed N, Tien H, Nathens A. Disaster preparedness of Canadian trauma centres: the perspective of medical directors of trauma. Can J Surg. Feb. 2011;54(1):9-16. [pmid: 21251427].
264 Gosden C, Gardener D. Weapons of mass destruction--threats and responses. BMJ. Aug. 13. 2005;331(7513):397-400. [pmid: 16096310].
265 Gostin LO, Bayer R, Fairchild AL. Ethical and legal challenges posed by severe acute respiratory syndrome: implications for the control of severe infectious disease threats. JAMA. Dec. 24. 2003;290(24):3229-37. [pmid: 14693876].
266 Gostin LO, Hanfling D. National preparedness for a catastrophic emergency: crisis standards of care. JAMA. Dec. 2. 2009;302(21):2365-6. [pmid: 19952324].
267 Gostin LO, Sapsin JW, Teret SP, Burris S, Mair JS, Hodge JG Jr, et al. The Model State Emergency Health Powers Act: planning for and response to bioterrorism and naturally occurring infectious diseases. JAMA. Aug. 7. 2002;288(5):622-8. [pmid: 12150674].
268 Gough AR, Gulliver LS. Anchors, bites, and choppers: media relations and legal issues in disasters. J Emerg Nurs. Jul–Aug. 1990;16(4):259-62. [pmid: 2385059].
269 Graham J, Liggin R, Shirm S, Nation B, Dick R. Planning for a mass casualty incident in Arkansas schools. J Sch Health. Oct. 2005;75(8):327-8. [pmid: 16179084].
270 Graham RF, Hoskins JD, Cortijo MP, Barbee GA, Folio LR, Lutz CC. A casualty tracking system modeled after air traffic control methodology employed in a combat support hospital in Iraq. Military Medicine. 2011;176(3):244-5. [pmid: 21456347].
271 Great Britain Dept of Health, Emergency Preparedness Division. Mass casualties incidents: a framework for planning. London. Great Britain Department of Health. 2006.
272 Greenwood JE, Mackie IP. Factors for consideration in developing a plan to cope with mass burn casualties. ANZ J Surg. Sep. 2009;79(9):581-3. [pmid: 19895508].
273 Groenewold MR. Enhancing local health department disaster response capacity with rapid community needs assessments: validation of a computerized program for binary attribute cluster sampling. Prehosp Disaster Med. Jan–Feb. 2006;21(1):32-9. [pmid: 16602263].
274 Gryth D, Radestad M, Nilsson H, Nerf O, Svensson L, Castren M, et al. Evaluation of medical command and control using performance indicators in a full-scale, major aircraft accident exercise. Prehosp Disaster Med. Mar–Apr. 2010;25(2):118-23. [pmid: 20467989].
275 Gupta RK, Toby M, Gagori B, Cooke M, Gelb D, Nguyen-Van-Tam JS. Public understanding of pandemic influenza, United Kingdom. Emerging Infectious Diseases. 2006;12(10):1620-1. [pmid: 17176595].
276 Gupta U, Ranganathan N. Ieee. Social Fairness in Multi-Emergency Resource Management. 2006 Ieee International Symposium on Technology and Society. 2006:53-61.
277 Guscott WM, Guscott AJ, Malingambi G, Parker R. The Bali bombings and the evolving mental health response to disaster in Australia: lessons from Darwin. J Psychiatr Ment Health Nurs. May. 2007;14(3):239-42. [pmid: 17430446].
278 Gutierrez RS, Ochoa C, Guerrero GC, editors. Using ARENA simulation software to predict hospital capabilities during CBRNE events. IIE Annual Conference and Expo 2008. 2008. Vancouver, BC. SCOPUS.
279 Guy PJ, Ineson N, Bailie R, Grimwood A. Operation Nightingale: the role of BMH Dharan following the 1988. Nepal earthquake, and some observations on Third World earthquake disaster relief missions. J R Army Med Corps. Feb. 1990;136(1):7-18. [pmid: 2319510].
280 Haas NP, Lindner T, Bail HJ. Developments in polytrauma management. Priority-based strategy. Chirurg. Oct. 2007;78(10):894-901. [pmid: 17876558].
281 Handy JM. Critical care bed capacity during the flu pandemic: implications for anaesthetic and critical care departments. Anaesthesia. Sep. 2009;64(9):933-4. [pmid: 19645760].
282 Harapin M, Cafuk B. Crisis communication in emergency situations. Lijec Vjesn. 2007;129(Suppl 5):102-4. [pmid: 18283885].
283 Hardaway RM 3rd. “This is no drill”: Pearl Harbor as a mass-casualty event. Bull Am Coll Surg”. Sep. 2004;89(9):21-6. [pmid: 18435169].
284 Hartel W, Steinmann R. First aid for severely injured patients in mass accidents. Chirurg. Apr. 1991;62(4):233-8. [pmid: 1860348].
285 Hays JC. Surge capacity of public health nurses. Public Health Nurs. Jul–Aug. 2008;25(4):293-4. [pmid: 18666933].
286 Heath SE, Dorn R, Linnabary RD, Hooks J, Casper J, Marshall K. An overview of disaster preparedness for veterinarians. J Am Vet Med Assoc. Feb. 1. 1997;210(3):345-8. [pmid: 9057915].
287 Heinrichs WL, Youngblood P, Harter P, Kusumoto L, Dev P. Training healthcare personnel for mass-casualty incidents in a virtual emergency department: VED II. Prehosp Disaster Med. Sep–Oct. 2010;25(5):424-32. [pmid: 21053190].
288 Henrich N, Holmes B. What the public was saying about the H1N1 vaccine: perceptions and issues discussed in on-line comments during the 2009 H1N1 pandemic. PLoS ONE. 2011.
289 Hersch M, Sonnenblick M, Karlic A, Einav S, Sprung CL, Izbicki G. Mechanical ventilation of patients hospitalized in medical wards vs the intensive care unit--an observational, comparative study. J Crit Care. Mar. 2007;22(1):13-7. [pmid: 17371738].
290 Hick JL, Barbera JA, Kelen GD. Refining surge capacity: conventional, contingency, and crisis capacity. Disaster Med Public Health Prep. Jun. 2009;3(2 Suppl):S59-67. [pmid: 19349869].
291 Hick JL, Weinstock DM, Coleman N, Hanfling D, Cantrill S, Redlener I, et al. Health Care System Planning for and Response to a Nuclear Detonation. Disaster Medicine and Public Health Preparedness. Mar. 2011;5:S73-S88. [pmid: 21402815].
292 Hilton S, Smith E. Public views of the UK media and government reaction to the 2009 swine flu pandemic. BMC Public Health. 2010;10(697):1471-2458.
293 Hirshberg A, Holcomb JB, Mattox KL. Hospital trauma care in multiple-casualty incidents: a critical view. Ann Emerg Med. Jun. 2001;37(6):647-52. [pmid: 11385336].
294 Hirshberg A, Scott BG, Granchi T, Wall MJ Jr, Mattox KL, Stein M. How does casualty load affect trauma care in urban bombing incidents? A quantitative analysis. J Trauma. Apr. 2005;58(4):686-93. discussion 94–5. [pmid: 15824643].
295 Hobfoll SE, Watson P, Bell CC, Bryant RA, Brymer MJ, Friedman MJ, et al. Five essential elements of immediate and mid-term mass trauma intervention: empirical evidence. Psychiatry. Winter. 2007;70(4):283-315. discussion 6–69. [pmid: 18181708].
296 Hodge JG Jr. Legal triage during public health emergencies and disasters. Adm Law Rev. 2006;58:627-44.
297 Hodge JG Jr, Lant T, Arias J, Jehn M. Building evidence for legal decision making in real time: legal triage in public health emergencies. Disaster Med Public Health Prep. Sep. 2011;5(Suppl 2):S242-51. [pmid: 21908702].
298 Hodge JGJ. Assessing the legal environment concerning mass casualty event planning and response. Phillips SJ, Knebel A, editors. Mass medical care with scarce resources: a community planning guide. Also available from Also available from: URL: http://www.ahrq.gov/research/mce/mceguide.pdf. Rockville, MD. Agency for Healthcare Research and Quality (AHRQ). 2007. Contract No.: Document Number|.
299 Hodgetts TJ. Lessons from the Musgrave Park Hospital bombing. Injury. Apr. 1993;24(4):219-21. [pmid: 8325675].
300 Hodgson MJ, Bierenbaum A, Mather S, Brown MA, Beatty J, Scott M, et al. Emergency management program operational responses to weapons of mass destruction: Veterans Health Administration, 2001–2004. Am J Ind Med. Nov. 2004;46(5):446-52. [pmid: 15490478].
301 Hollingsworth TD, Klinkenberg D, Heesterbeek H, Anderson RM. Mitigation Strategies for Pandemic Influenza A: Balancing Conflicting Policy Objectives. Plos Computational Biology. Feb. 2011;7(2).
302 Holmes BJ, Henrich N, Hancock S, Lestou V. Communicating with the public during health crises: experts’ experiences and opinions. Journal of Risk Research. 2009;12(5/6):793-807.
303 Homeland Security. National Response Framework: FEMA. 2008. Contract No.: Document Number|.
304 Hreckovski B, Dobson B, Grgic Z, Matic I, Jurisic D, Jurjevic M. Mass disasters: experience and organization of work. Lijec Vjesn. 2007;129(Suppl 5):100-1. [pmid: 18283884].
305 Hsu EB, Casani JA, Romanosky A, Millin MG, Singleton CM, Donohue J, et al. Are regional hospital pharmacies prepared for public health emergencies?. Biosecur Bioterror. 2006;4(3):237-43. [pmid: 16999585].
306 Hsu EB, Casani JA, Romanosky A, Millin MG, Singleton CM, Donohue J, et al. Critical assessment of statewide hospital pharmaceutical surge capabilities for chemical, biological, radiological, nuclear, and explosive incidents. Prehosp Disaster Med. May–Jun. 2007;22(3):214-8. [pmid: 17894215].
307 Hsu EB, Jenckes MW, Catlett CL, Robinson KA, Feuerstein C, Cosgrove SE, et al. Effectiveness of hospital staff mass-casualty incident training methods: a systematic literature review. Prehosp Disaster Med. Jul–Sep. 2004;19(3):191-9. [pmid: 15571194].
308 Hsu EB, Millin MG. A hospital-based strategy for setting priorities for antiviral prophylaxis during an influenza pandemic. Biosecurity and Bioterrorism: Biodefense Strategy, Practice and Science. 2008;6(2):171-8.
309 Hu XJ, Kreutzer R. Evidence-based Review on the Effectiveness of Interventions for the Control and Prevention of SARS and other Respiratory Pathogens in Health Care Workers. Proceedings of the 5th International Academic Conference on Environmental and Occupational Medicine. 2010:27-32.
310 Huang CC, Yen DH, Huang HH, Kao WF, Wang LM, Huang CI, et al. Impact of severe acute respiratory syndrome (SARS) outbreaks on the use of emergency department medical resources. J Chin Med Assoc. Jun. 2005;68(6):254-9. [pmid: 15984818].
311 Huang CF, Wang JJ, Lin TJ. Resource sufficiency, organizational cohesion, and organizational effectiveness of emergency response. Natural Hazards. Jul. 2011;58(1):221-34.
312 Hupert N, Hollingsworth E, Wei XO, James JJ. Is overtriage associated with increased mortality? Insights from a simulation model of mass casualty trauma care. Disaster Medicine and Public Health Preparedness. 2007;1(Suppl 1):S14-24. [pmid: 18388607].
313 Hupert N, Hollingsworth E, Xiong W. Is Overtriage Associated With Increased Mortality? Insights From a Simulation Model of Mass Casualty Trauma Care. Disaster Medicine and Public Health Preparedness. Sep. 2007;1:S14-S24. [pmid: 18388607].
314 Hupert N, Mushlin AI, Callahan MA. Modeling the public health response to bioterrorism: using discrete event simulation to design antibiotic distribution centers. Med Decis Making. Sep-Oct. 2002;22(5 Suppl):S17-25. [pmid: 12369227].
315 Hupert N, Wattson D, Cuomo J, Hollingsworth E, Neukermans K, Xiong W. Predicting hospital surge after a large-scale anthrax attack: a model-based analysis of CDC’s cities readiness initiative prophylaxis recommendations. Med Decis Making. Jul–Aug. 2009;29(4):424-37. [pmid: 19617582].
316 Inglis TJ, Merritt AJ, Levy A, Vietheer P, Bradbury R, Scholler A, et al. Deployable laboratory response to influenza pandemic; PCR assay field trials and comparison with reference methods. PLoS One. 2011;6(10):e25526. [pmid: 22022407].
317 Institute of Medicine (US) Committee on Research Priorities in Emergency Preparedness and Response for Public Health Systems, Centers for Disease Control and Prevention (U.S) Coordinating Office for Terrorism Preparedness and Emergency Response. Research priorities in emergency preparedness and response for public health systems : a letter report. Washington, D.C. National Academies Press. 2008. [cited RAND Library-NYAM.
318 International Strategy for Disaster Reduction ; Platform for the Promotion of Early Warning UNISDR, 2010 early warning practices can save lives : selected examples; good practices and lessons learned. [electronic resource]. Bonn, Germany. International Strategy for Disaster Reduction. 2010. [cited RAND Library-NYAM.
319 IOM (Institute of Medicine). Barriers to integrating crisis standards of care principles into international disaster and response plans. Workshop summary. In press. 2012.
320 Irvin CB, Messman A, Parikh S, Nigl J. In a Major Disaster, How Do You Allocate Hospital Resources?. Annals of Emergency Medicine. Sep. 2009;54(3):S123-S.
321 Isaacs D. Lessons from the swine flu: Pandemic, panic and/or pandemonium?. Journal of Paediatrics and Child Health. 2010;46(11):623-6. [pmid: 21121084].
322 IsakovIu F, Roshal LM, Malakhov OA, Rozinov VM. Medical care for children in mass casualties. Voen Med Zh. Aug. 1990;(8):33-4.
323 Jabeen K. When a disaster strikes. Managing multi and mass casualties. Nurs J India. Oct. 1998;89(10):225. [pmid: 10531963].
324 Jackson BA. Science and Technology Policy Institute (Rand Corporation), National Institute for Occupational Safety and Health. Protecting emergency responders lessons learned from terrorist attacks. [electronic resource]. Santa Monica, CA. 2002. [cited RAND Library-NYAM.
325 James JJ. Special issue to present complexities inherent in a response to a devastating mass casualty incident. Disaster Med Public Health Prep. Sep. 2007;1(1 Suppl):S2. [pmid: 18388608].
326 James JJ. Triage:implications for mass casualty response. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S2-3. [pmid: 18769262].
327 James JJ. Re: Allocation of ventilators in a public health disaster. Disaster Med Public Health Prep. Jun. 2008;2(2):72. [pmid: 18525368].
328 James JJ, Subbarao I, Lanier WL. Improving the art and science of disaster medicine and public health preparedness. Mayo Clinic Proceedings. 2008;83(5):559-62. [pmid: 18452686].
329 Jasper E, Miller M, Sweeney B, Berg D, Feuer E, Reganato D. Preparedness of hospitals to respond to a radiological terrorism event as assessed by a full-scale exercise. J Public Health Manag Pract. Nov. Suppl. 2005:S11-6. [pmid: 16205528].
330 Javornik N. Effect of the Red Cross in mass disasters and catastrophes. Lijec Vjesn. 2007;129(Suppl 5):64-8. [pmid: 18283878].
331 Jen HC, Shew SB, Atkinson JB, Rosenthal JT, Hiatt JR. Creation of inpatient capacity during a major hospital relocation: lessons for disaster planning. Arch Surg. Sep. 2009;144(9):859-64. [pmid: 19797112].
332 Jesus JE, Michael GE. Ethical considerations of research in disaster-stricken populations. Prehosp Disaster Med. Mar–Apr. 2009;24(2):109-14. [pmid: 19591303].
333 Johnston SC, Sorel ME, Sidney S. Effects of the September 11th attacks on urgent and emergent medical evaluations in a Northern California managed care plan. American Journal of Medicine. Nov. 2002;113(7):556-62. [pmid: 12459401].
334 Jordan MH, Hollowed KA, Turner DG, Wang DS, Jeng JC. The Pentagon attack of September 11, 2001: A Burn Center’s experience. Journal of Burn Care and Rehabilitation. 2005;26(2):109-16. [pmid: 15756111].
335 Joshi AJ, Rys MJ. STUDY ON THE EFFECT OF DIFFERENT ARRIVAL PATTERNS ON AN EMERGENCY DEPARTMENT’S CAPACITY USING DISCRETE EVENT SIMULATION. International Journal of Industrial Engineering-Theory Applications and Practice. 2011;18(1):40-50.
336 Juffermans J, Bierens JJ. Recurrent medical response problems during five recent disasters in the Netherlands. Prehosp Disaster Med. Mar–Apr. 2010;25(2):127-36. [pmid: 20467991].
337 Kahan E, Fogelman Y, Kitai E, Vinker S. Patient and family physician preferences for care and communication in the eventuality of anthrax terrorism. Fam Pract. Aug. 2003;20(4):441-2. [pmid: 12876118].
338 Kahn LH, Barondess JA. Preparing for disaster: response matrices in the USA and UK. J Urban Health. Nov. 2008;85(6):910-22. [pmid: 18756376].
339 Kaji A, Koenig KL, Bey T. Surge capacity for healthcare systems: a conceptual framework. Acad Emerg Med. Nov. 2006;13(11):1157-9. [pmid: 16968688].
340 Kaji AH, Koenig KL, Lewis RJ. Current hospital disaster preparedness. Jama-Journal of the American Medical Association. Nov. 2007;298(18):2188-90.
341 Kaji AH, Langford V, Lewis RJ. Assessing hospital disaster preparedness: A comparison of an on-site survey, directly observed drill performance, and video analysis of teamwork. Annals of Emergency Medicine. Sep. 2008;52(3):195-201. [pmid: 18191285].
342 Kaji AH, Lewis RJ. Hospital disaster preparedness in Los Angeles County. Acad Emerg Med. Nov. 2006;13(11):1198-203. [pmid: 16885400].
343 Kales SN, Christiani DC. Acute chemical emergencies. N Engl J Med. Feb. 19. 2004;350(8):800-8. [pmid: 14973213].
344 Kaneko K. Disaster response of tertiary hospitals. Chudoku Kenkyu. Jan. 2005;18(1):53-5. [pmid: 15844366].
345 Kanter RK, Moran JR. Hospital emergency surge capacity: An empiric new York Statewide study. Annals of Emergency Medicine. Sep. 2007;50(3):314-9. [pmid: 17178173].
346 Kanz KG, Hornburger P, Kay MV, Mutschler W, Schäuble W. The mSTaRT algorithm for mass casualty incident management. MSTaRT-algorithmus für sichtung, behandlung und transport bei einem massenanfall von verletzten. 2006;9(3):264-70.
347 Karp E, Sebbag G, Peiser J, Dukhno O, Ovnat A, Levy I, et al. Mass casualty incident after the Taba terrorist attack: An organisational and medical challenge. Disasters. 2007;31(1):104-12. [pmid: 17367377].
348 Kass NE, Otto J, O’Brien D, Minson M. Ethics and severe pandemic influenza: maintaining essential functions through a fair and considered response. Biosecurity and Bioterrorism: Biodefense Strategy, Practice and Science. 2008;6(3):227-36.
349 Kastenbaum R. Death writ large. Death Stud. May. 2004;28(4):375-92. [pmid: 15129691].
350 Kazancioglu R, Pinarbasi B, Esen BA, Turkmen A, Sever MS. The need for blood products in patients with crush syndrome. Am J Disaster Med. Sep–Oct. 2010;5(5):295-301. [pmid: 21162411].
351 Keim ME, Pesik N, Twum-Danso NA. Lack of hospital preparedness for chemical terrorism in a major US city: 1996–2000. Prehosp Disaster Med. Jul–Sep. 2003;18(3):193-9. [pmid: 15141858].
352 Kelen GD, McCarthy ML. Special Issue: Developing the science of health care emergency and response. Disaster Medicine and Public Health Preparedness. 2009;3(Suppl 1):S1-89. [pmid: 19491581].
353 Kemmerer DA, Lund JL, Tanguay R, Tomassoni AJ, staff N. Creating poison center surge capacity in response to a mass casualty event. Clinical Toxicology. 2006;44(5):314.
354 Kemppainen A. Allocating resources during pandemic addressed in annual ethics lecture. Mich Med. Jul-Aug. 2009;108(4):13. [pmid: 19731490].
355 Kerth R. U.S. Public Interest Research Group. Unacceptable risk. 2011. Contract No.: Document Number|.
356 Ketchie K, Breuilly E. Our experience in earthquake-ravaged Haiti: two nurses deployed with a disaster medical assistance team. J Emerg Nurs. Sep. 2010;36(5):492-6. [pmid: 20837226].
357 Kieny MP, Costa A, Hombach J, Carrasco P, Pervikov Y, Salisbury D, et al. A global pandemic influenza vaccine action plan. Vaccine. Sep. 2006;24(40–41):6367-70. [pmid: 17240560].
358 King DR, Patel MB, Feinstein AJ, Earle SA, Topp RF, Proctor KG. Simulation training for a mass casualty incident: Two-year experience at the army trauma training center. Journal of Trauma-Injury Infection and Critical Care. Oct. 2006;61(4):943-8.
359 Kirk MA, Deaton ML. Bringing order out of chaos: effective strategies for medical response to mass chemical exposure. Emerg Med Clin North Am. May. 2007;25(2):527-48. abstract xi. [pmid: 17482031].
360 Kirsch TD, Mitrani-Reiser J, Bissell R, Sauer LM, Mahoney M, Holmes WT, et al. Impact on hospital functions following the 2010 Chilean earthquake. Disaster Med Public Health Prep. Jun. 2010;4(2):122-8. [pmid: 20526134].
361 Kirschenbaum L, Keene A, O’Neill P, Westfal R, Astiz ME. The experience at St. Vincent’s Hospital, Manhattan, on September 11, 2001: Preparedness, response, and lessons learned. Critical Care Medicine. 2005;33(1 SUPPL):S48-52. [pmid: 15640679].
362 Kittler AF, Hobbs J, Volk LA, Kreps GL, Bates DW. The Internet as a vehicle to communicate health information during a public health emergency: a survey analysis involving the anthrax scare of 2001. J Med Internet Res. Mar. 3. 2004;6(1):e8. [pmid: 15111274].
363 Klein KR, Nagel NE. Mass medical evacuation: Hurricane Katrina and nursing experiences at the New Orleans airport. Disaster Manag Response. Apr–Jun. 2007;5(2):56-61. [pmid: 17517364].
364 Klein L, Michaelson M. NATO international advanced course on best way of training for mass casualty situations. Vnitr Lek. Jul. 2010;56(7):676-80. [pmid: 20842911].
365 Klein MB, Nathens AB, Emerson D, Heimbach DM, Gibran NS. An analysis of the long-distance transport of burn patients to a regional burn center. Journal of Burn Care and Research. 2007;28(1):49-55. [pmid: 17211200].
366 Kleinpeter MA. Disaster preparedness of dialysis patients for Hurricanes Gustav and Ike 2008. Adv Perit Dial. 2009;25:62-7. [pmid: 19886319].
367 Knebel AR, Coleman CN, Cliffer KD, Murrain-Hill P, McNally R, Oancea V, et al. Allocation of scarce resources after a nuclear detonation: setting the context. Disaster Med Public Health Prep. Mar. 2011;5(Suppl 1):S20-31. [pmid: 21402809].
368 Knoppers BM, Saginur M, Cash H. Ethical issues in secondary uses of human biological materials from mass disasters. J Law Med Ethics. Summer. 2006;34(2):352-65. [pmid: 16789956].
369 Koenig KL. Editorial comments-training healthcare personnel for mass casualty incidents in a virtual emergency department: VED II. Prehosp Disaster Med. Sep–Oct. 2010;25(5):433-4. [pmid: 21053191].
370 Koenig KL, Cone DC, Burstein JL, Camargo CA Jr. Surging to the right standard of care. Acad Emerg Med. Feb. 2006;13(2):195-8. [pmid: 16436799].
371 Korniushko IG, Kotenko PK, Iakovlev SV. Genesis of the service of catastrophe medicine of the Armed Forces of Russian Federation. Voen Med Zh. Sep. 2008;329(9):10-8. [pmid: 19048847].
372 Kort R, Sturart AJ, Bonotovics E. Ensuring a broad and inclusive approach: A provincial perspective on pandemic preparedness. Canadian Journal of Public Health. 2005;96(6):409-11. [pmid: 16350862].
373 Kosashvili Y, Daniel LA, Peleg K, Horowitz A, Laor D, Blumenfeld A. Israeli hospital preparedness for terrorism-related multiple casualty incidents: Can the surge capacity and injury severity distribution be better predicted?. Injury. 2009;40(7):727-31. [pmid: 19394934].
374 Kostomarova LG, Stazhadze LL, Spiridonova EA, Krugovykh EA. Prehospital emergency medical care to victims in peace-time state of emergency. Anesteziol Reanimatol. Jul-Aug. 2007;(4):12-4. [pmid: 17933040].
375 Kotalik J. Preparing for an influenza pandemic: ethical issues. Bioethics. Aug. 2005;19(4):422-31. [pmid: 16222857].
376 Kreimeier U, Weidringer JW. TEAM and disaster medicine. Management during the Soccer World Championship 2006 in Germany: Introduction to the topic. TEAM und katastrophenmedizin: Management bei der fußball- weltmeisterschaft Deutschland 2006. 2006;9(3):244-5.
377 Kreiss Y, Merin O, Peleg K, Levy G, Vinker S, Sagi R, et al. Early disaster response in Haiti: The Israeli field hospital experience. Annals of Internal Medicine. 2010;153(1):45-8. [pmid: 20442270].
378 Kroon MB, Overdijk WI. Psychosocial care and shelter following the Bijlmermeer air disaster. Crisis. 1993;14(3):117-25. [pmid: 8281803].
379 Kyle RR, Via DK, Lowy RJ, Madsen JM, Marty AM, Mongan PD. A multidisciplinary approach to teach responses to weapons of mass destruction and terrorism using combined simulation modalities. J Clin Anesth. Mar. 2004;16(2):152-8. [pmid: 15110382].
380 Landman WA, Schuklenk U. Medecins sans Frontieres under the spotlight. Dev World Bioeth. May. 2006;6(2):iii-iv. [pmid: 16594967].
381 Laor N, Wiener Z, Spirman S, Wolmer L, Danieli Y, Brom D, et al. Community mental health in emergencies and mass disasters: the Tel-Aviv Model. The trauma of terrorism: sharing knowledge and shared care, an international handbook. Binghamton. Haworth Press Inc. 2005.
382 Latasch L, Inglis R, Jung G, Stark S. Appraisal of hospitals during the 2006 FIFA World Cup: Treatment in prehospital treatment areas. Bestandsaufnahme der Krankenhäuser zur Fußball-WM 2006 : Versorgung in vorgeschalteten Klinikbehandlungseinheiten. 2006;10(6):411-3.
383 Lavon O, Bentur Y. Does amyl nitrite have a role in the management of pre-hospital mass casualty cyanide poisoning?. Clin Toxicol (Phila). Jul. 2010;48(6):477-84. [pmid: 20653465].
384 Lavon O, Hershko D, Barenboim E. Large-scale air-medical transport from a peripheral hospital to level-1 trauma centers after remote mass-casualty incidents in Israel. Prehosp Disaster Med. Nov–Dec. 2009;24(6):549-55. [pmid: 20301076].
385 Lee EK, Chen CH, Pietz F, Benecke B. Modeling and Optimizing the Public-Health Infrastructure for Emergency Response. Interfaces. Sep–Oct. 2009;39(5):476-90.
386 Lee VJ, Lye DC, Wilder-Smith A. Combination strategies for pandemic influenza response - a systematic review of mathematical modeling studies. BMC Med. 2009;7:76. [pmid: 20003249].
387 Lee YM. Analyzing Dispensing Plan for Emergency Medical Supplies in the Event of Bioterrorism. 2008 Winter Simulation Conference. 2008;1–5:2600-8.
388 Leiba A, Ashkenasi I, Nakash G, Pelts R, Schwartz D, Goldberg A, et al. Response of Thai hospitals to the Tsunami disaster. Prehospital and Disaster Medicine. 2006;21(1):s32-s7. [pmid: 16602271].
389 Lemon SM. Institute of Medicine (US). Forum on Microbial Threats Ethical and legal considerations in mitigating pandemic disease : workshop summary. Washington, DC. National Academies Press. 2007. [cited RAND Library-NYAM.
390 Lemyre L, Johnson C, Corneil W. Psychosocial considerations for mass decontamination. Radiat Prot Dosimetry. Nov. 2010;142(1):17-23. [pmid: 20924122].
391 Lenert LA, Kirsh D, Griswold WG, Buono C, Lyon J, Rao R, et al. Design and evaluation of a wireless electronic health records system for field care in mass casualty settings. J Am Med Inform Assoc. Nov. 1. 2011;18(6):842-52. [pmid: 21709162].
392 Lerner EB. Studies evaluating current field triage: 1966 - 2005. Prehospital Emergency Care. 2006;10(3):303-6. [pmid: 16801265].
393 Lerner EB, Shah MN, Swor RA, Cushman JT, Guse CE, Brasel K, et al. Comparison of the 1999 and 2006 Trauma Triage Guidelines: Where Do Patients Go?. Prehospital Emergency Care. Jan. 2011;15(1):12-7. [pmid: 21054176].
394 Levi L, Bregman D. Simulation and management games for training command and control in emergencies. Stud Health Technol Inform. 2003;95:783-7. [pmid: 14664083].
395 Levi L, Bregman D, Geva H, Revah M. Does number of beds reflect the surgical capability of hospitals in wartime and disaster? The use of a simulation technique at a national level. Prehosp Disaster Med. Oct–Dec. 1997;12(4):300-4. [pmid: 10179211].
396 Levi L, Eran T. Role of the anaesthetist in developing and implementing readiness of hospital to mass casualty incidents. Curr Opin Anaesthesiol. Apr. 2003;16(2):201-4. [pmid: 17021460].
397 Levy K, Aghababian RV, Hirsch EF, Screnci D, Boshyan A, Ricks RC, et al. An Internet-based exercise as a component of an overall training program addressing medical aspects of radiation emergency management. Prehosp Disaster Med. Apr–Jun. 2000;15(2):18-25. [pmid: 11183457].
398 Lewicki G. Fiery plane crash finds Little Rock hospitals ready to handle influx of media and public attention. Profiles Healthc Mark. Sep–Oct. 1999;15(5):44-5. [pmid: 10621480].
399 L’Her E, Roy A. Bench Tests of Simple, Handy Ventilators for Pandemics: Performance, Autonomy, and Ergonomy. Respiratory Care. Jun. 2011;56(6):751-60. [pmid: 21333059].
400 Li T, Li Z, Qi S. Experiences of early management of mass burn casualties. Zhonghua zheng xing shao shang wai ke za zhi = Zhonghua zheng xing shao shang waikf [ie waike] zazhi = Chinese journal of plastic surgery and burns / [Chung-hua cheng hsing shao shang wai k”o tsa chih pien chi wei yuan hui pien ch. 1999;15(4):252-3.
401 Liebergall MH, Braverman N, Shapira SC, Rotem OP, Soudry I, Mor-Yosef S. Role of nurses in a university hospital during mass casualty events. Am J Crit Care. Sep. 2007;16(5):480-4. [pmid: 17724245].
402 Linden JV, Davey RJ, Burch JW. The September 11, 2001 disaster and the New York blood supply. Transfusion. Oct. 2002;42(10):1385-7. [pmid: 12423526].
403 Ling Z, Tie L, Huang H, editors. Relief equipment layout model for natural disaster with uncertain demands. Proceedings - International Conference on Management and Service Science, MASS 2009. 2009. Wuhan. SCOPUS.
404 Liu DW. Mass casualty critical care for surgical patients during a disaster. Zhonghua Wai Ke Za Zhi. Dec. 15. 2008;46(24):1843-4. [pmid: 19134363].
405 Liu DW. The role of critical care medicine in the rescue of sudden and mass disaster victims. Zhonghua Nei Ke Za Zhi. Oct. 2008;47(10):798-9. [pmid: 19080133].
406 Lockey DJ, MacKenzie R, Redhead J, Wise D, Harris T, Weaver A, et al. London bombings July 2005: The immediate pre-hospital medical response. Resuscitation. 2005;66(2):ix-xii. [pmid: 16053939].
407 Lodree EJ, Taskin S. Supply chain planning for hurricane response with wind speed information updates. Computers & Operations Research. Jan. 2009;36(1):2-15.
408 Longstaff PH, Yang SU. Communication management and trust: their role in building resilience to “surprises” such as natural disasters, pandemic flu, and terrorism. Ecology and Society. [Journal article]. 2008;13(1). Art. 3.
409 Loyd GE. The reach of patient simulation: Is there no boundary?. Journal of Clinical Anesthesia. 2004;16(2):142-3. [pmid: 15110380].
410 Lundalv J. Intensive media reporting following bus crash in Rasbo-Uppsala. Lakartidningen. Sep. 3–9. 2008;105(36):2418-20. [pmid: 18831453].
411 Luss H. On equitable resource allocation problems: A lexicographic minimax approach. Operations Research. May–Jun. 1999;47(3):361-78.
412 Luzhnikov EA, Ostapenko Iu N. The organization and rendering of specialized medical care in mass poisonings. Ter Arkh. 1990;62(10):29-34. [pmid: 2084886].
413 Lyznicki J, Subbarao I, Benjamin GC, James JJ. Developing a consensus framework for an effective and efficient disaster response health system: a national call to action. Disaster Medicine and Public Health Preparedness. 2007;1(Suppl 1):S51-4. [pmid: 18388617].
414 Mace SE, Sharieff G, Bern A, Benjamin L, Burbulys D, Johnson R, et al. Pediatric issues in disaster management, part 3: special healthcare needs patients and mental health issues. Am J Disaster Med. Sep–Oct. 2010;5(5):261-74. [pmid: 21162408].
415 Mack D. MCI (mass casualty incident) resource guide 2001. A Journal of emergency medical services : JEMS. 2001;26(6):72-83.
416 Mackie DP. Mass burn casualties: A rational approach to planning. Burns. 2002;28(5):403-4. [pmid: 12163276].
417 Mackie DP, Koning HM. Fate of mass burn casualties: Implications for disaster planning. Burns. 1990;16(3):203-6. [pmid: 2383361].
418 Mahoney EJ, Harrington DT, Biffl WL, Metzger J, Oka T, Cioffi WG. Lessons learned from a nightclub fire: Institutional disaster preparedness. Journal of Trauma - Injury, Infection and Critical Care. 2005;58(3):487-91.
419 Malcic M. Role of the public firemen’s force in mass disasters and catastrophes. Lijec Vjesn. 2007;129(Suppl 5):58-63. [pmid: 18283877].
420 Maltz J, T CN, Li D, Wang J, Wang K, Bergeron W, et al. The Trauma Patient Tracking System: implementing a wireless monitoring infrastructure for emergency response. Conf Proc IEEE Eng Med Biol Soc. 2005;3:2441-6. [pmid: 17282731].
421 Manning FJ, Goldfrank LR. Institute of Medicine (US). Committee on Evaluation of the Metropolitan Medical Response Program Preparing for terrorism tools for evaluating the Metropolitan Medical Response System Program. [electronic resource]. Washington, DC. National Academy Press. 2002. [cited RAND Library-NYAM.
422 Marcozzi D, Sanders M, Vanderwagen WC. A nation prepared: inspiration in the face of tragedy. Disaster Medicine and Public Health Preparedness. 2007;1(1 Suppl).
423 Marmor M, Goldstein L, Levi Y, Onn E, Blumenfeld A, Kosashvili Y, et al. Mass medical repatriation of injured civilians after terrorist attack in Mombassa, Kenya: medical needs, resources used, and lessons learned. Prehospital and disaster medicine : the official journal of the National Association of EMS Physicians and the World Association for Emergency and Disaster Medicine in association with the Acute Care Foundation. 2005;20(2):98-102.
424 Marsh JL. Disasters and mass casualties. J Am Acad Orthop Surg. Jul. 2007;15(7):378-9. [pmid: 17602026].
425 Marshall KM, Begier EM, Griffith KS, Adams ML, Hadler JL. A population survey of smallpox knowledge, perceptions, and healthcare-seeking behavior surrounding the Iraq invasion - Connecticut 2002–03. Biosecurity and Bioterrorism: Biodefense Strategy, Practice and Science. 2005;3(3):246-55.
426 Martin J. Pandemic risk--planning and prevention in the face of constant scarce resources and the political process. Rev Med Suisse. Jan. 18. 2006;2(49):246-7. [pmid: 16493968].
427 Marx RG. Mass casualties and triage at a sporting event: Commentary [2]. British Journal of Sports Medicine. 2002;36(2).
428 Masterson L, Steffen C, Brin M, Kordick MF, Christos S. Willingness to respond: of emergency department personnel and their predicted participation in mass casualty terrorist events. J Emerg Med. Jan. 2009;36(1):43-9. [pmid: 18514469].
429 Matsui Y, Ohbu S, Yamashina A. Hospital deployment in mass sarin poisoning incident of the Tokyo subway system--an experience at St. Luke’s International Hospital, Tokyo. Jpn Hosp. Jul. 1996;15:67-71. [pmid: 10161859].
430 McAlister V. Drills and exercises: The way to disaster preparedness. Canadian Journal of Surgery. 2011;54(1):7-8.
431 McAlister VC. Catastrophe surgery: response to multiple casualties or individual patients with devastating injuries. Can J Surg. Jun. 2009;52(3):175-6. [pmid: 19503659].
432 McCabe OL, Perry C, Azur M, Taylor HG, Bailey M, Links JM. Psychological First-Aid Training for Paraprofessionals: A Systems-Based Model for Enhancing Capacity of Rural Emergency Responses. Prehosp Disaster Med. Oct. 2011;7:1-8.
433 McCann DGC. Preparing for the worst: a disaster medicine primer for health care. Journal of Legal Medicine. 2009;30(3):329-48. [pmid: 19681011].
434 McCaw JM, Moss R, McVernon J. A decision support tool for evaluating the impact of a diagnostic-capacity and antiviral-delivery constrained intervention strategy on an influenza pandemic. Influenza and Other Respiratory Viruses. May. 2011;5:212-5.
435 McCormick LC, Yeager VA, Rucks AC, Ginter PM, Hansen S, Kazzi ZN, et al. Pandemic influenza preparedness: Bridging public health academia and practice. Public Health Reports. 2009;124(2):344-9. [pmid: 19320379].
436 McCurdy DB, Brown FB, Shackleton RA, Scofield G, Koch T, Lammers SE, et al. Disclosure vs. confidentiality when disaster strikes. Mak Rounds Health Faith Ethics. Apr. 22. 3. 1996;1(16):1-5. [pmid: 11660225].
437 McCurley MC, Miller CW, Tucker FE, Guinn A, Donnelly E, Ansari A, et al. Educating medical staff about responding to a radiological or nuclear emergency. Health Phys. May. 2009;96(5 Suppl 2):S50-4. [pmid: 19359842].
438 McDonnall D, Hiatt S, Yatsenko D, Guillory KS. Field deployable EEG monitor for nerve agent casualties. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:5291-3. [pmid: 19964118].
439 McFee RB, Caraccio TR, Gamble VN. Understocking antidotes for common toxicologic emergencies: A neglected public health problem. Advanced Studies in Medicine. 2005;5(5):262-3.
440 McGrath D, Hunt A, Bates M, editors. A simple distributed simulation architecture for emergency response exercises. Proceedings - IEEE International Symposium on Distributed Simulation and Real-Time Applications, DS-RT. 2005. Montreal, QC. SCOPUS.
441 McHugh MD. The legal context of nurses volunteering in mass casualty events. Pa Nurse. Jun. 2007;62(2):14-5. [pmid: 17668834].
442 McInerney JE, Richter A. Strengthening hospital preparedness for chemical, biological, radiological, nuclear, and explosive events: clinicians’ opinions regarding physician/physician assistant response and training. Am J Disaster Med. Mar–Apr. 2011;6(2):73-87. [pmid: 21678818].
443 McKenna M. The most good for the most people: emergency physicians lead push for creating “crisis standards of care” in tough political climate. Ann Emerg Med. Jul. 2010;56(1):22A-4A.
444 McLaughlin S. Ready for anything. A look at the Joint Commission’s new emergency management standards. Health Facil Manage. Nov. 2007;20(11):39-40. 2. [pmid: 18074949].
445 McMahon MM. Preventing pediatric mass casualty events. Disaster Manag Response. Apr–Jun. 2007;5(2):25-6. [pmid: 17517358].
446 McNaughton EG. International Federation of Red Cross and Red Crescent Societies. A practical guide to advocacy for disaster risk reduction. New Delhi International Federation of Red Cross and Red Crescent Societies. 2009. [cited RANDLibrary-NYAM.
447 Mechem CC. Surge capacity: we all need it. How do we get it? JEMS. Nov. 2007;32(11):48-50.
448 Meltzer MI, McNeill KM, Miller JD. Laboratory Surge Capacity and Pandemic Influenza. Emerging Infectious Diseases. Jan. 2010;16(1):147-8. [pmid: 20031064].
449 Menon DK, Taylor BL, Ridley SA. Modeling the impact of an influenza pandemic on critical care services in England. Anaesthesia. 2005;60:952-4. [pmid: 16179037].
450 Miller G, Randolph S, Patterson JE. Responding to simulated pandemic influenza in San Antonio, Texas. Infection Control and Hospital Epidemiology. Apr. 2008;29(4):320-6. [pmid: 18462144].
451 Miller GT, Scott JA, Issenberg SB, Petrusa ER, Brotons AA, Gordon DL, et al. Development, implementation and outcomes of a training program for responders to acts of terrorism. Prehospital Emergency Care. 2006;10(2):239-46. [pmid: 16531383].
452 Miller K, Groff L, Erdman M, King S. Lessons learned in preparing to receive large numbers of contaminated individuals. Health Physics. 2005;89(2 SUPPL):S42-7. [pmid: 16010120].
453 Mills CN, Mills GH. Mass casualty incident response and aeromedical evacuation in antarctica. West J Emerg Med. Feb. 2011;12(1):37-42. [pmid: 21691470].
454 Minin AA, Abushinov VV. The basic trends in creating a territorial system of emergency medical care in extreme situations. Voen Med Zh. Nov. 1993;(11):4-6. [pmid: 8109087].
455 Mississippi State Department of Health. Plan for Receiving, Distributing, and Dispensing Strategic National Stockpile Assets: Public Health Emergency Preparedness and Planning Program. January. 15. 2010. Contract No.: Document Number|.
456 Mitani S, Ozaki E, Fujita N, Hashimoto T, Mori I, Fukuyama T, et al. Ensuring adequate human medical resources during an avian influenza A/H5N1 pandemic. Prehospital & Disaster Medicine. 2011;26(1):15-9. [pmid: 21838061].
457 Mitka M. National plan for pandemic flu unveiled. Journal of the American Medical Association. 2006;21;295(23):2707-8.
458 Modi PJ, Jung H, Tambe M, Shen WM, Kulkarni S. Dynamic distributed resource allocation: A distributed constraint satisfaction approach. Meyer JJC, Tambe M, editors. Intelligent Agents Viii: Agent Theories, Architectures, and Languages. 2002:264-76.
459 Modlin JF. A mass smallpox vaccination campaign: reasonable or irresponsible?. Eff Clin Pract. Mar–Apr. 2002;5(2):98-9. [pmid: 11990219].
460 Morgan DL, Trail WR, Trompler VA. Liability immunity as a legal defense for recent emergency medical services system litigation. Prehosp Disaster Med. Apr–Jun. 1995;10(2):82-90. discussion -1. [pmid: 10155419].
461 Mortensen K, Dreyfuss Z. How many walked through the door?: the effect of hurricane Katrina evacuees on Houston emergency departments. Med Care. Sep. 2008;46(9):998-1001. [pmid: 18725856].
462 Moskop JC, Iserson KV. Triage in Medicine, Part II: Underlying Values and Principles. Annals of Emergency Medicine. 2007;49(3):282-7. [pmid: 17141137].
463 Mouro G. Emergency nursing in Lebanon amidst chaos. J Emerg Nurs. Apr. 2009;35(2):154-7. [pmid: 19285187].
464 Mrsic Z, Jakic I. Role of the police in care during mass disasters and catastrophes. Lijec Vjesn. 2007;129(Suppl 5):54-7. [pmid: 18283876].
465 Muller D. Ethics and trauma: lessons from media coverage of Black Saturday. Aust J Rural Health. Feb. 2010;18(1):5-10. [pmid: 20136808].
466 Mullin S. Public health and the media: the challenge now faced by bioterrorism. J Urban Health. Mar. 2002;79(1):12. [pmid: 11937610].
467 Munro H. Managing chaos amidst the unbelievable. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S1. [pmid: 18769259].
468 Murad H, Kaufman D, Greenlaw J, Harvey T, D’Angio C, Demme R. ASSESSMENT OF THE NEW YORK STATE DEPARTMENT OF HEALTH PROPOSED GUIDELINES FOR VENTILATOR ALLOCATION IN THE SCENARIO OF SEVERE INFLUENZA PANDEMIC. Critical Care Medicine. Dec. 2009;37(12):792.
469 Murnane M, Cooper DM. Is the Australian hospital system adequately prepared for terrosism? The Australian Government’s response. Medical Journal of Australia. 2005;183(11–12):572-3. [pmid: 16336132].
470 Murray MJ. Communicating during a disaster. Anesth Analg. Mar. 1. 2010;110(3):657-8. [pmid: 20185642].
471 Myers L, Grant L. The creation of regional partnerships for regional emergency planning. J Bus Contin Emer Plan. Nov. 2010;4(4):338-51. [pmid: 21177220].
472 Nagle C. Responding to the media in emergencies. J Nucl Med. Apr. 2003;44(4):11N-3N. 6N. [pmid: 12515870].
473 Nair R, Tambe M. Coordinating teams in uncertain environments: A hybrid BDI-POMDP approach. Bordini RH, Dastani M, Dix J, Seghrouchni AEF, editors. Programming Multi-Agent Systems. 2005:1-37.
474 National Association of Public Hospitals and Health Systems. Hospital staffing and surge capacity during a disaster event. Washington D.C. National Association of Public Hospitals and Health Systems. 2007. [cited RAND Library-NYAM.
475 National Center for Post-Traumatic Stress Disorder (US), National Child Traumatic Stress Network (US). Psychological first aid : field operations guide Los Angeles. Durham, NC. National Child Traumatic Stress Network. [White River Junction, Vt]. National Center for Post-Traumatic Stress Disorder. 2006. [cited RAND Library-NYAM.
476 Nechaev EA, Nazarenko GI, Zhizhin VN, Agapov VK. Diagnosis and prognosis in determining the priority of care for the victims in mass casualties. Diagnoz i prognoz v opredelenii prioriteta pomoshchi postradavshim pri massovykh porazheniiakh. 1993;(12):4-7.
477 Needle S. A disaster preparedness plan for pediatricians: American Academy of Pediatrics. Contract No.: Document Number|.
478 Ng AT. Cultural diversity in the integration of disaster mental health and public health: a case study in response to bioterrorism. Int J Emerg Ment Health. Winter. 2005;7(1):23-31. [pmid: 15869078].
479 Nguyen D. Mass casualties on the modern battlefield: problems and proposed solutions. Mil Med. Apr. 1990;155(4):186-7. [pmid: 2110343].
480 Nicogossian A, Zimmerman T, Addo-Ayensu G, Thomas K, Kreps GL, Ebadirad N, et al. The use of U.S. academic institutions in community medical disaster recovery. World Medical and Health Policy. 2011;3(1).
481 Niska RW, Burt CW. Emergency response planning in hospitals, United States: 2003–2004. Adv Data. Aug. 2007;20(391):1-13.
482 NORC (Organization), National Rural Health Association (US), Western New York Public Health Alliance I. Migrant and seasonal farm worker emergency preparedness planning guide. [electronic resource]. Chicago, IL. National Opinion Research Center. 2009. [cited RAND Library-NYAM.
483 Norcross ED, Elliott BM, Adams DB, Crawford FA. Impact of a major hurricane on surgical services in a university hospital. Am Surg. Jan. 1993;59(1):28-33. [pmid: 8480928].
484 Nordberg M. Rapid rescue: the Illinois tornado. Emerg Med Serv. Jan. 1991;20(1):25. 7. 9. [pmid: 10109444].
485 Okudera H, Morita H, Iwashita T, Shibata T, Otagiri T, Kobayashi S, et al. Unexpected nerve gas exposure in the city of Matsumoto: report of rescue activity in the first sarin gas terrorism. Am J Emerg Med. Sep. 1997;15(5):527-8. [pmid: 9270397].
486 Okumura T, Ninomiya N, Ohta M. The chemical disaster response system in Japan. Prehosp Disaster Med. Jul–Sep. 2003;18(3):189-92. [pmid: 15141857].
487 Ortenwall P. Precision of in-hospital triage in mass-casualty incidents after terror attacks. Prehospital and disaster medicine : the official journal of the National Association of EMS Physicians and the World Association for Emergency and Disaster Medicine in association with the Acute Care Foundation. 2006;21(3):220.
488 Otto JL, Lipnick RJ, Sanchez JL, DeFraites RF, Barnett DJ. Preparing military installations for pandemic influenza through tabletop exercises. Mil Med. Jan. 2010;175(1):7-13. [pmid: 20108836].
489 Owens DK, Buckeridge D, Wilkening D. Bioterrorism preparedness and response : use of information technologies and decision support systems. Rockville, MD. US Dept of Health and Human Services, Public Health Service, Agency for Healthcare Research and Quality. 2002. [cited RAND Library-NYAM.
490 Pandey K, Singh P. Dealing of mass casualty in ophthalmology - A challenge. Oman J Ophthalmol. May. 2010;3(2):101. [pmid: 21217910].
491 Parker CL, Everly GS Jr, Barnett DJ, Links JM. Establishing evidence-informed core intervention competencies in psychological first aid for public health personnel. Int J Emerg Ment Health. Spring. 2006;8(2):83-92. [pmid: 16703846].
492 Pasternak D, Boyce N, Samuel T. Tools of mass distraction. US News World Rep. Oct. 29. 2001;131(18):12-6. [pmid: 11699228].
493 Paul AO, Kay MV, Hornburger P, Kanz KG. Mass casualty incident management by mSTaRT. MMW Fortschr Med. May. 8. 2008;150(19):40-1. [pmid: 18589863].
494 Paul JA, Batta R. Improving hurricane disaster preparedness: Models for optimal reallocation of hospital capacity. International Journal of Operational Research. 2011;10(2):194-213.
495 Pelaccia T. Preparing health care students for mass casualty events. Med Educ. 2008. Oct. 1.
496 Peleg K, Kellermann AL. Enhancing Hospital Surge Capacity for Mass Casualty Events. Jama-Journal of the American Medical Association. Aug. 2009;302(5):565-7.
497 Peral Gutierrez De Ceballos J, Turégano Fuentes F, Perez Diaz D, Sanz Sanchez M, Martin Llorente C, Guerrero Sanz JE. Casualties treated at the closest hospital in the Madrid, March 11, terrorist bombings. Critical Care Medicine. 2005;33(1 SUPPL):S107-12. [pmid: 15640672].
498 Peral-Gutierrez de Ceballos J, Turégano-Fuentes F, Pérez-Díaz D, Sanz-Sánchez M, Martín-Llorente C, Guerrero-Sanz JE. 11 March 2004: The terrorist bomb explosions in Madrid, Spain - An analysis of the logistics, injuries sustained and clinical management of casualties treated at the closest hospital. Critical Care. 2005;9(1):104-11. [pmid: 15693992].
499 Petrovskii BV. Delivering medical care to the victims in mass peacetime catastrophes. Voen Med Zh. Jul. 1990;(7):13-4. [pmid: 2238486].
500 Pezzino G, Thompson MZ, Edgar M. National Network of Public Health Institutes, Illinois Public Health Leadership Institute, Kansas Health Institute, et al. A multi-state comparison of local public health preparedness assessment using a common, standardized tool. New Orleans, LA. National Network of Public Health Institutes. 2006. [cited RAND Library-NYAM.
501 Pheby D, Robinson P. Nuclear accidents: how people react. Health Visit. Apr. 1990;63(4):119-21. [pmid: 2332341].
502 Phelps S. Mission failure: emergency medical services response to chemical, biological, radiological, nuclear, and explosive events. Prehosp Disaster Med. Jul–Aug. 2007;22(4):293-6. [pmid: 18019095].
503 Phillips S. Current status of surge research. Acad Emerg Med. Nov. 2006;13(11):1103-8. [pmid: 17032944].
504 Phillips SJ, Knebel A. Mass medical care with scarce resources: a community planning guide. <Document Title>. Mass medical care with scarce resources: a community planning guide. 2007.
505 Phillips SJ, Knebel A, Roberts MJ. United States Agency for Healthcare Research and Quality, Health Systems Research I. Providing mass medical care with scarce resources : a community planning guide. Rockville, Md. Agency for Healthcare Research and Quality. 2006. [cited RAND Library-NYAM.
506 Phillips WJ, Reynolds PC, Lenczyk M, Walton S, Ciresi S. Anesthesia during a mass-casualty disaster: the Army’s experience at Fort Bragg, North Carolina, March 23, 1994. Mil Med. Jun. 1997;162(6):371-3. [pmid: 9183155].
507 Ploughman P. Disasters, the media and social structures: a typology of credibility hierarchy persistence based on a newspaper coverage of the Love Canal and six other disasters. Disasters. Jun. 1997;21(2):118-37. [pmid: 9235221].
508 Pollard WE. Public perceptions of information sources concerning bioterrorism before and after anthrax attacks: an analysis of national survey data. J Health Commun. 2003;8(Suppl 1):93-103. discussion 48–51. [pmid: 14692574].
509 Porter D, Hall M, Hartl B, Raevsky C, Peacock R, Kraker D, et al. Local health department 2009 H1N1 influenza vaccination clinics-CDC staffing model comparison and other best practices. J Public Health Manag Pract. Nov. 2011;17(6):530-3. [pmid: 21964365].
510 Povstianoi NE, Perekhrestenko PM, Polishchuk SA. The organization of medical aid in mass thermal injuries. Klin Khir. 1990;(3):54-7. [pmid: 2366431].
511 Powers MF. Evaluation of Hospital-based Disaster Education. Journal of Emergency Nursing. 2007;33(1):79-82. [pmid: 17258063].
512 Powers R. Organization of a Hospital-based Victim Decontamination Plan Using the Incident Command Structure. Disaster Management and Response. 2007;5(4):119-23. [pmid: 17996656].
513 Prati G, Pietrantoni L, Zani B. Compliance with recommendations for pandemic influenza H1N1 2009: the role of trust and personal beliefs. Health Education Research. 2011;26(5):761-9. [pmid: 21613380].
514 President’s Council of Advisors on Science and Technology (US). Report to the President on reengineering the influenza vaccine production enterprise to meet the challenges of pandemic influenza. [electronic resource]. Washington, DC. Executive Office of the President of the United States. 2010. [cited RAND Library-NYAM.
515 Priest C. Catastrophic conditions, tough decisions: the roles and responsibilities of nurse leaders in disaster settings. Nurse Leader. 2009;7(3):48-50.
516 Prizmic V. Role of the Croatian Mountain Rescue service in care during mass disasters and catastrophes. Lijec Vjesn. 2007;129(Suppl 5):69-74. [pmid: 18283879].
517 Ramos G, Flageat G, Queiroz G, Nacif G, Fiorentino R, Arata A, et al. Massive hospital admission of patients with respiratory failure resulting from smoke inhalation injury: The cromagnon republic tragedy. Journal of Burn Care and Research. 2006;27(6):842-7. [pmid: 17091080].
518 Rao RR, Eisenberg J, Schmitt T. National Research Council (US) Committee on Using Information Technology to Enhance Disaster Management, National Academies Press (U.S.). Improving disaster management the role of IT in mitigation, preparedness, response, and recovery. Washington, D.C. National Academies Press. 2007. [cited RAND Library-NYAM.
519 Raphael B. Crowds and other collectives: complexities of human behaviors in mass emergencies. Psychiatry. 2005;68(2):115-20. [pmid: 16247854].
520 Rawls CG, Turnquist MA. Ieee. Pre-positioning of Emergency Supplies for Disaster Response. 2006 Ieee International Symposium on Technology and Society. 2006:139-47.
521 Rebmann T, Citarella B, Alexander S, Russell B, Volkman JC. Personal protective equipment use and allocation in home health during disasters. Am J Infect Control. 2011. Jun. 23.
522 Rebmann T, Russell J, Alexander S, Cloughessy M, Coll B, Hilley S, et al. Infection Prevention for Alternate Care Sites: 2009 APIC Emergency Preparedness Committee. November. 2009. Contract No.: Document Number|.
523 Rebmann T, Volkman J. Infection Prevention Implications of Managing Haitian 2010 Earthquake Patient in U.S. Hospitals: 2010 APIC Emergency Preparedness Committee. February. 2010. Contract No.: Document Number|.
524 Reddy MC, Paul SA, Abraham J, McNeese M, DeFlitch C, Yen J. Challenges to effective crisis management: Using information and communication technologies to coordinate emergency medical services and emergency department teams. International Journal of Medical Informatics. 2009;78(4):259-69. [pmid: 18835211].
525 Reich DS. Modernizing local responses to public health emergencies: bioterrorism, epidemics, and the model state emergency health powers act. J Contemp Health Law Policy. Spring. 2003;19(2):379-414. [pmid: 14748251].
526 Reigner P, Carron PN, Ribordy V, Yersin B. Terrorism and turning to physicians: management of a mass casualty situation. Rev Med Suisse. Dec. 13. 2006;2(91):2876-9. [pmid: 17236329].
527 Reilly MJ, Markenson D. Hospital referral patterns: how emergency medical care is accessed in a disaster. Disaster Med Public Health Prep. Oct. 2010;4(3):226-31. [pmid: 21149219].
528 Reilly MJ, Markenson D, DiMaggio C. Comfort level of emergency medical service providers in responding to weapons of mass destruction events: impact of training and equipment. Prehosp Disaster Med. Jul–Aug. 2007;22(4):297-303. [pmid: 18019096].
529 Repine TB, Lisagor P, Cohen DJ. The dynamics and ethics of triage: rationing care in hard times. Mil Med. Jun. 2005;170(6):505-9. [pmid: 16001601].
530 Revere D, Nelson K, Thiede H, Duchin J, Stergachis A, Baseman J. Public Health Emergency Preparedness and Response Communications with Health Care Providers: A Literature Review. Bmc Public Health. May. 2011:11. [pmid: 21208451].
531 Rhodes R. Justice in medicine and public health. Camb Q Healthc Ethics. Winter. 2005;14(1):13-26. [pmid: 15747479].
532 Rich T, Biddinger PD, Hassol A, Zane RD. Abt Associates, United States Agency for Healthcare Research and Quality. Recommendations for a national mass patient and evacuee movement, regulating, and tracking system. Rockville, MD. United States Agency for Healthcare Research and Quality. 2009. [cited RAND Library-NYAM.
533 Rigg NJ. The LA Marathon. Fun-run turns mass-casualty. Emerg Med Serv. Jun. 2004;33(6):101-6. [pmid: 15216593].
534 Robertson AG, Cooper DM. Disaster surge planning in Australia: measuring the immeasurable. Med J Aust. Apr. 16. 2007;186(8):388-9. [pmid: 17437390].
535 Robison JL. Army nurses’ knowledge base for determining triage categories in a mass casualty. Mil Med. Oct. 2002;167(10):812-6. [pmid: 12392246].
536 Rodgers J, Foushee R, Terndrup TE, Gaddis GM. Research methods of inquiry. Acad Emerg Med. Nov. 2006;13(11):1183-92. [pmid: 16968685].
537 Rodgers P, Storey CP. Pandemic palliative care: Time to plan. Journal of Pain and Symptom Management. 2010;39(2):354.
538 Rodoplu U, Arnold JL, Tokyay R, Ersoy G, Cetiner S, Yücel T. Mass-casualty terrorist bombings in Istanbul, Turkey, November 2003: report of the events and the prehospital emergency response. Prehospital and disaster medicine : the official journal of the National Association of EMS Physicians and the World Association for Emergency and Disaster Medicine in association with the Acute Care Foundation. 2004;19(2):133-45.
539 Romano M. Emergency preparedness. Texas system scores first with inflatable surge hospital. Mod Healthc. Jan. 1. 2007;37(1):16.
540 Romig LE. Pediatric triage. A system to JumpSTART your triage of young patients at MCIs. JEMS. Jul. 2002;27(7):52-8. 60. 3. [pmid: 12141119].
541 Rosenbaum S, Kamoie B. Finding a way through the hospital door: the role of EMTALA in public health emergencies. J Law Med Ethics. Winter. 2003;31(4):590-601. [pmid: 14968661].
542 Rosenfeld LA, Etkind P, Grasso A, Adams AJ, Rothholz MC. Extending the reach: local health department collaboration with community pharmacies in Palm Beach County, Florida for H1N1 influenza pandemic response. J Public Health Manag Pract. Sep–Oct. 2011;17(5):439-48. [pmid: 21788782].
543 Rosoff PM, DeCamp M. Preparing for an influenza pandemic: are some people more equal than others?. J Health Care Poor Underserved. Aug. 2011;22(3 Suppl):19-35. [pmid: 21857134].
544 Rostrup M. After the wave: bringing emergency medical care to Aceh. Br J Gen Pract. Mar. 2005;55(512):236-7. [pmid: 15808050].
545 Rothman RE, Hsu EB, Kahn CA, Kelen GD. Research priorities for surge capacity. Acad Emerg Med. Nov. 2006;13(11):1160-8. [pmid: 17032947].
546 Roxland BE, Han SA, Birkhead G. Public engagement on New York State’s plan for allocating ventilators during a pandemic. Annals of Emergency Medicine. 2011;57(3):308-9. [pmid: 21353914].
547 Rudenko MI. The anesthesiological support for surgical interventions under emergency conditions with the arrival of mass casualties. Voen Med Zh. Aug. 1991;(8):42-7. [pmid: 1836691].
548 Rusakov AB. A systems approach to rendering medical care in mass trauma. Voen Med Zh. Dec. 1994;(12):27-9. [pmid: 7900314].
549 Rush RM Jr. Surgical Response to Disaster. Surgical Clinics of North America. 2006;86(3):xvii-xxi.
550 Safar P, Semenov VN, Teriaev VG, Abrams J, Crippen D, Klain M, et al. The potentials of the modern science of resuscitation for saving the lives of victims in mass catastrophes. Voen Med Zh. Aug. 1990;(8):47-50. [pmid: 2267760].
551 Salhanick SD, Sheahan W, Bazarian JJ. Use and analysis of field triage criteria for mass gatherings. Prehosp Disaster Med. Oct–Dec. 2003;18(4):347-52. [pmid: 15310047].
552 Salinas NL, Eller RL, Davis MR, Rasmussen TE. Mass casualty response of a modern deployed head and neck surgical team. J Craniofac Surg. Jul. 2010;21(4):987-90. [pmid: 20613569].
553 Salmeron J, Apte A. Stochastic Optimization for Natural Disaster Asset Prepositioning. Production and Operations Management. Sep–Oct. 2010;19(5):561-74.
554 Sandrock C. Manpower. Intensive Care Medicine. Apr. 2010;36:S32-S7. [pmid: 20213419].
555 Sanyasi A. Extreme emergencies. Humanitarian assistance to civilian populations following chemical, biological, radiological, nuclear and explosive incidents: a sourcebook. <Document Title>. Extreme emergencies. Humanitarian assistance to civilian populations following chemical, biological, radiological, nuclear and explosive incidents: a sourcebook. [Book]. +. 2004;xvii:222.
556 Schenk JR, Huang D, Zheng N, Allen TT. Multiple fidelity simulation optimization of hospital performance under high consequence event scenarios. Kuhl ME, Steiger NM, Armstrong FB, Joines JA, editors. 2005.
557 Scheulen JJ, Thanner MH, Hsu EB, Latimer CK, Brown J, Kelen GD. Electronic Mass Casualty Assessment and Planning Scenarios (EMCAPS): development and application of computer modeling to selected National Planning Scenarios for high-consequence events. Ann Emerg Med. Feb. 2009;53(2):226-32. [pmid: 18986730].
558 Schleipman AR, Gerbaudo VH, Castronovo FP Jr. Radiation disaster response: preparation and simulation experience at an academic medical center. J Nucl Med Technol. Mar. 2004;32(1):22-7. [pmid: 14990671].
559 Schmiedle M, Sefrin P. Limitation of medical supply in hospitals under disaster conditions. Notarzt. 2003;9(6):220-8.
560 Schoch-Spana M. Implications of pandemic influenza for bioterrorism response. Clinical Infectious Diseases. Dec. 2000;31(6):1409-13. [pmid: 11096011].
561 Schultz CH, Koenig KL, Lewis RJ. Implications of hospital evacuation after the Northridge, California, earthquake. New England Journal of Medicine. 2003;348(14):1349-55. [pmid: 12672863].
562 Schultz M, Carius-Düssel C. Telemedizin - Einsatzmöglichkeiten in der Notfallversorgung. Public Health Forum. 2009;17(4):6.e1-6.e3.
563 Schwerin MJ, Kennedy K, Wardlaw M. Counseling support within the Navy Mass Casualty Assistance Team post-September 11. Mil Med. Sep. 2002;167(9 Suppl):76-8. [pmid: 12363149].
564 Scott LA, Carson DS, Greenwell IB. Disaster 101: a novel approach to disaster medicine training for health professionals. J Emerg Med. Aug. 2010;39(2):220-6. [pmid: 20079997].
565 Sergeev GV, Nechaev EA. The interaction of civilian public health and military medicine in mass catastrophes. Voen Med Zh. Aug. 1990;(8):20-3. [pmid: 2267749].
566 Serrano Moraza A, Pacheco Rodríguez A, Pérez Belleboni A, Briñas Freire MJ. Urban disasters. Treatment to the victims. Methods, myths and tools: In conflicts with the evidence? Desastres en el medio urbano: Atención in situ a las víctimas Métodos, mitos y herramientas: ¿En conflicto con la evidencia?. 2007;7(2):63-5.
567 Shapira SC, Shemer J, Oren M. Hospital management of a bioterror event. Israel Medical Association Journal. 2002;4(7):493-4. [pmid: 12120457].
568 Shapiro DS. Surge capacity for response to bioterrorism in hospital clinical microbiology laboratories. J Clin Microbiol. Dec. 2003;41(12):5372-6. [pmid: 14662913].
569 Shaw KN, Krug SE, Ackerman AD, Bojko T, Fein JA, Fitzmaurice LS, et al. Policy Statement-Emergency Information Forms and Emergency Preparedness for Children With Special Health Care Needs. Pediatrics. Apr. 2010;125(4):829-37. [pmid: 20351008].
570 Sheu JB, Chen YH, Lan LW. A novel model for quick response to disaster relief distribution. Satoh K, editor. Proceedings of the Eastern Asia Society for Transportation Studies. 2005;5:2454-62.
571 Shim EH, Meyers LA, Galvani AP, Tchuenche JM, Smith R. Optimal H1N1 vaccination strategies based on self-interest versus group interest. BMC Public Health. 2011;11(Suppl 1):S4. [pmid: 21356133].
572 Shinar E, Yahalom V, Silverman BG. Meeting blood requirements following terrorist attacks: The Israeli experience. Current Opinion in Hematology. 2006;13(6):452-6. [pmid: 17053458].
573 Shirm S, Liggin R, Dick R, Graham J. Prehospital preparedness for pediatric mass-casualty events. Pediatrics. Oct. 2007;120(4):e756-61. [pmid: 17908733].
574 Shoenfeld Y. Mass casualty events during night shifts in the internal medicine departments. Harefuah. Mar. 2001;140(3):230-1. [pmid: 11303350].
575 Shubert J, Ritchie EC, Everly GS Jr, Fiedler N, Williams MB, Mitchell CS, et al. A missing element in disaster mental health: behavioral health surveillance for first responders. Int J Emerg Ment Health. Summer. 2007;9(3):201-13. [pmid: 18372662].
576 Shugarman LR, Eiseman E, Jain A, Nicosia N, Stern S, Wasserman J, et al. Enhancing public health preparedness: exercises, exemplary practices, and lessons learned: assessing the adequacy of extant exercises for addressing local and state readiness for public health emergencies. Santa Monica, CA. RAND Corporation. 2005. [cited RAND Library-NYAM.
577 Siassakos D, Bristowe K, Draycott TJ, Angouri J, Hambly H, Winter C, et al. Clinical efficiency in a simulated emergency and relationship to team behaviours: a multisite cross-sectional study. Bjog-an International Journal of Obstetrics and Gynaecology. Apr. 2011;118(5):596-607. [pmid: 21291509].
578 Siegel D, Younggren BN, Ness B, Kvool V. Operation Castle Cascade: managing multiple casualties from a simulated chemical weapons attack. Mil Med. May. 2003;168(5):351-4. [pmid: 12775167].
579 Signorini A, Segre AM, Polgreen PM. The use of twitter to track levels of disease activity and public concern in the U.S. during the influenza A H1N1 pandemic. PLoS ONE. 2011.
580 Silvagni AJ, Levy LA, McFee RB. Educating health professionals, first responders, and the community about bioterrorism and weapons of mass destruction. J Am Osteopath Assoc. Sep. 2002;102(9):491-9. [pmid: 12361182].
581 Simchen E, Sprung CL, Galai N, Zitser-Gurevich Y, Bar-Lavi Y, Gurman G, et al. Survival of critically ill patients hospitalized in and out of intensive care units under paucity of intensive care unit beds. Crit Care Med. Aug. 2004;32(8):1654-61. [pmid: 15286540].
582 Simon JD. Nuclear, biological, and chemical terrorism: understanding the threat and designing responses. Int J Emerg Ment Health. Spring. 1999;1(2):81-9. [pmid: 11227745].
583 Singer AJ, Singer AH, Halperin P, Kaspi G, Assaf J. Medical lessons from terror attacks in Israel. J Emerg Med. Jan. 2007;32(1):87-92. [pmid: 17239737].
584 Singer DE, Carr PL, Mulley AG, Thibault GE. Rationing intensive care--physician responses to a resource shortage. N Engl J Med. Nov. 10. 1983;309(19):1155-60. [pmid: 6413862].
585 Sinuff T, Kahnamoui K, Cook DJ, Luce JM, Levy MM. Rationing critical care beds: a systematic review. Crit Care Med. Jul. 2004;32(7):1588-97. [pmid: 15241106].
586 Smith CM, Graffeo CS. Regional impact of Hurricane Isabel on emergency departments in coastal southeastern Virginia. Academic Emergency Medicine. Dec. 2005;12(12):1201-5. [pmid: 16293892].
587 Smith EL. Highlights from the annual scientific assembly: weapons of mass destruction: organized medicine’s role in the national response to terrorism. South Med J. Dec. 2001;94(12):1223-9. [pmid: 11811866].
588 Smith G. Preparing for an influenza pandemic. Pharmaceutical Journal. 2005;29;275(7373):551.
589 Smith W, Dowell J. A case study of co-ordinative decision-making in disaster management. Ergonomics. 2000;43(8):1153-66. [pmid: 10975178].
590 Sockeel P, De Saint Roman C, Massoure MP, Nadaud J, Cinquetti G, Chatelain E. The Main Gate Syndrome: a new format in mass-casualty victim “surge” management?. J Chir (Paris). Sep–Oct. 2008;145(5):459-65. [pmid: 19106867].
591 Solberg Y, Nachtomi-Shick O, Shemer Y, Alcalay M. Terror in Japan: mass-intoxication with the nerve-agent sarin. Harefuah. 1998;135(7–8):268-71. 336. 5. [pmid: 9885671].
592 Soma K. Disaster risk management of mass poisoning. Chudoku Kenkyu. Mar. 2009;22(1):11. [pmid: 19344051].
593 Sommer DD, Fisher JA, Ramcharan V, Marshall S, Vidic DM. Improvised automatic lung ventilation for unanticipated emergencies. Crit Care Med. Apr. 1994;22(4):705-9. [pmid: 8143481].
594 Spiegel PB. Differences in world responses to natural disasters and complex emergencies. JAMA. Apr. 20. 2005;293(15):1915-8. [pmid: 15840867].
595 Sprung CL, Cohen R, Adini B. Chapter 1. Introduction Intensive Care Medicine. 2010;36(SUPPL 1):S4-10.
596 Sprung CL, Kesecioglu J. Chapter 5. Essential equipment, pharmaceuticals and supplies. Intensive Care Medicine. 2010;36(SUPPL 1):S38-44. [pmid: 20213420].
597 Sprung CL, Zimmerman JL, Christian MD, Joynt GM, Hick JL, Taylor B, et al. Recommendations for intensive care unit and hospital preparations for an influenza epidemic or mass disaster: summary report of the European Society of Intensive Care Medicine’s Task Force for intensive care unit triage during an influenza epidemic or mass disaster. Intensive Care Medicine. Mar. 2010;36(3):428-43. [pmid: 20135090].
598 State of Alaska Department of Health and Social Services DoPH. Emergency Operations Plan: Division of Public Health Department of Health and Social Services. 2005. Contract No.: Document Number|.
599 SteelFisher G, Blendon R, Ross LJ, Collins BC, Ben-Porath EN, Bekheit MM, et al. Public Response to an Anthrax Attack: Reactions to Mass Prophylaxis in a Scenario Involving Inhalation Anthrax from an Unidentified Source. Biosecurity and Bioterrorism-Biodefense Strategy Practice and Science. Sep. 2011;9(3):239-50.
600 SteelFisher G, Blendon R, Ross LJ, Collins BC, Ben-Porath EN, Bekheit MM, et al. Public response to an anthrax attack: reactions to mass prophylaxis in a scenario involving inhalation anthrax from an unidentified source. Biosecurity and Bioterrorism: Biodefense Strategy, Practice and Science. 2011;9(3):239-50.
601 Stein BD, Tanielian TL, Eisenman DP, Keyser DJ, Burnam MA, Pincus HA. Emotional and behavioral consequences of bioterrorism: planning a public health response. Milbank Q. 2004;82(3):413-55. table of contents. [pmid: 15330972].
602 Stein L. Mass casualty triage. Okla Nurse. Jun–Aug. 2008;53(2):18-9. quiz 20–1. [pmid: 18572826].
603 Stein LN. Scarce resources: altered standards of care in a disaster. Okla Nurse. Mar–May. 2007;52(1):22-3. quiz 4–5. [pmid: 17330709].
604 Stein M, Shemer J. Urban mass casualty terrorist incident: systematic management approach. Harefuah. Feb. 16. 1997;132(4):300-4. [pmid: 9153905].
605 Steiner N, Mǎnǎstireanu D, Fisher JM. Use of decommissioned hospitals as temporary care facilities for patients in a mass casualties influx. Management in Health. 2011;15(2):11-5.
606 Stergachis A, Wetmore CM, Pennylegion M, Beaton RD, Karras BT, Webb D, et al. Evaluation of a mass dispensing exercise in a Cities Readiness Initiative setting. Am J Health Syst Pharm. Feb. 1. 2007;64(3):285-93. [pmid: 17244878].
607 Stoil MJ. Virginia Tech’s implications. Behav Healthc. Dec. 2. 2007;27(12):10-3. [pmid: 18429585].
608 Stopford BM. Responding to the threat of bioterrorism: practical resources and references, and the importance of preparation. J Emerg Nurs. Oct. 2001;27(5):471-5. [pmid: 11577287].
609 Stopford BM, Jevitt L. Development of models for emergency preparedness: personal protective equipment, decontamination, isolation/quarantine, and laboratory capacity. Rockville, MD. U.S. Department of Health and Human Services, Agency for Healthcare Research and Quality. 2005. [cited RAND Library-NYAM.
610 Stroud C. Institute of Medicine (U.S.) Forum on Medical and Public Health Preparedness for Catastrophic Events. Crisis standards of care summary of a workshop series. [electronic resource] [Book; Format: electronic remote conference publication ; Literary form: not fiction ]. Washington, D.C. National Academies Press. 2010. [cited RAND Library-NYAM.
611 Stroud C, Altevogt BM, Goldfrank LR. Institute of Medicine’s Forum on Medical and Public Health Preparedness for Catastrophic Events: activities and goals. Disaster Med Public Health Prep. Oct. 2009;3(3):183-5. [pmid: 19865043].
612 Suarez SA, Quintero CG, de la Rosa JL. A Real Time Approach for Task Allocation in a Disaster Scenario. Demazeau Y, Dignum F, Corchado JM, Perez JB, editors. Advances in Practical Applications of Agents and Multiagent Systems. 2010:157-62.
613 Subbarao I, Lyznicki JM, Hsu EB, Gebbie KM, Markenson D, Barzansky B, et al. A consensus-based educational framework and competency set for the discipline of disaster medicine and public health preparedness. Disaster Medicine and Public Health Preparedness. 2008;2(1):57-68. [pmid: 18388659].
614 Sullivan B. Incorporating the principles of crisis communication into a crisis response plan. QRC Advis. Oct. 2000;16(12):1-7. [pmid: 11143144].
615 Supe A, Satoskar R. Health services responses to disasters in Mumbai sharing experiences. Indian J Med Sci. Jun. 2008;62(6):242-51. [pmid: 18603744].
616 Syrett JI, Benitez JG, Livingston WH 3rd, Davis EA. Will emergency health care providers respond to mass casualty incidents?. J Healthc Prot Manage. 2007;23(2):27-40. [pmid: 17907606].
617 Tadmor B, McManus J, Koenig KL. The art and science of surge: experience from Israel and the U.S. military. Acad Emerg Med. Nov. 2006;13(11):1130-4. [pmid: 17015414].
618 Taft Morales M, Margesson R. Library of Congress Congressional Research Service. Haiti earthquake crisis and response. [electronic resource] [cited RAND Library-NYAM. Available from: Copies available for loan: New York Academy of Medicine Grey Literature.
619 Tajima S. Fire department response to mass casualty chemical incidents. Chudoku Kenkyu. Jul. 2001;14(3):219-26. [pmid: 11692578].
620 Tanaka K. The Kobe earthquake: the system response. A disaster report from Japan. Eur J Emerg Med. Dec. 1996;3(4):263-9. [pmid: 9056140].
621 Tang N, Kelen GD. Role of tactical EMS in support of public safety and the public health response to a hostile mass casualty incident. Disaster Med Public Health Prep. Sep. 2007;1(1 Suppl):S55-6. [pmid: 18388618].
622 Tanigawa K. Planning and practice: simulation training for chemical disaster. Chudoku Kenkyu. Jan. 2005;18(1):17-39. [pmid: 15844363].
623 Tassani P, Madler C, Peter K. Mass accidents from the anesthesiologic viewpoint. Chirurg. Apr. 1991;62(4):243-6. [pmid: 1860350].
624 Taylor CW. Surge capacity: preparing your healthcare system. Emerg Med Serv. Aug. 2003;32(8):91-2. [pmid: 12942917].
625 Tekin A, Namias N, O’Keeffe T, Pizano L, Lynn M, Prater-Varas R, et al. A burn mass casualty event due to boiler room explosion on a cruise ship: Preparedness and outcomes. American Surgeon. 2005;71(3):210-5. [pmid: 15869134].
626 Thomas JC, Dasgupta N, Martinot A. Ethics in a pandemic: a survey of the state pandemic influenza plans. Am J Public Health. Apr. 2007;97(Suppl 1):S26-31. [pmid: 17413066].
627 Thomas JC, MacDonald PD, Wenink E. Ethical decision making in a crisis: a case study of ethics in public health emergencies. J Public Health Manag Pract. Mar–Apr. 2009;15(2):E16-21. [pmid: 19202402].
628 Thorstensson M, Morin M, Jenvald J. Monitoring and visualization support for management of medical resources in mass-casualty incidents. Proc Int Emerg Manage Soc. 1999:179-88.
629 Ticktin M. Pills, panics, precautions. Nurs Times. Mar. 24–30. 1999;95(12):55-6. [pmid: 10232249].
630 Traynor K. Pharmacists matter in pandemic response. American Journal of Health-System Pharmacy. 2008;1;65(19):1792-3.
631 Trotter G. Chemical terrorism and the ethics of decontamination. J Clin Ethics. Summer. 2004;15(2):149-60. [pmid: 15481166].
632 Trunkey DD. US Trauma Center Preparation for a Terrorist Attack in the Community. European Journal of Trauma and Emergency Surgery. Jun. 2009;35(3):244-64.
633 Tur-Kaspa I, Lev EI, Hendler I, Siebner R, Shapira Y, Shemer J. Preparing hospitals for toxicological mass casualties events. Crit Care Med. May. 1999;27(5):1004-8. [pmid: 10362427].
634 Turner T, Green S, Harris C. Supporting evidence-based health care in crises: what information do humanitarian organizations need?. Disaster Med Public Health Prep. Mar. 2011;5(1):69-72. [pmid: 21402829].
635 Tyler JV, Levinson DR. Nursing home emergency preparedness and response during recent hurricanes. Washington D.C. United States. Dept. of Health and Human Services, Office of Inspector General. 2005. [cited RAND Library-NYAM.
636 Umer M, Sepah YJ, Shahpurwala MM, Zafar H. Suicide bombings: process of care of mass casualties in the developing world. Disasters. Oct. 2009;33(4):809-21. [pmid: 19624704].
637 United Nations, International Strategy for Disaster Reduction. Local governments and disaster risk reduction good practices and lessons learned. [electronic resource]. Geneva. United Nations: International Strategy for Disaster Reduction. 2010. [cited RAND Library-NYAM.
638 United States Agency for Healthcare Research and Quality. Optimizing surge capacity : hospital assessment and planning. Rockville, M.D. Agency for Healthcare Research and Quality. 2004. [cited RAND Library-NYAM.
639 United States Agency for Healthcare Research and Quality. Bioterrorism and health system preparedness: surge capacity-education and training for a qualified workforce. Rockville, M.D. Agency for Healthcare Research and Quality. 2004. [cited RAND Library-NYAM.
640 United States Agency for Healthcare Research and Quality. Disaster planning drills and readiness assessment. Rockville, M.D. Agency for Healthcare Research and Quality. 2004. [cited RAND Library-NYAM.
641 United States Agency for Healthcare Research and Quality. Optimizing surge capacity: regional efforts in bioterrorism readiness. Rockville, M.D. Agency for Healthcare Research and Quality. 2004. [cited RAND Library-NYAM.
642 United States Agency for Healthcare Research and Quality. Bioterrorism and health system preparedness: bioterrorism and other public health emergencies. Rockville, M.D. Agency for Healthcare Research and Quality, U.S. Department of Health Human Services. 2005. [cited RAND Library-NYAM.
643 United States Agency for Healthcare Research and Quality; Health Systems Research Inc. Altered standards of care in mass casualty events. Rockville, M.D. Agency for Healthcare Research and Quality, U. S. Department of Health Human Services; Health Systems Research, Inc. Apr. 2005. [cited RAND Library-NYAM.
644 United States Congress Senate Committee on Homeland Security and Governmental Affairs, United States Government Accountability Office. Disaster recovery : experiences from past disasters offer insights for effective collaboration after catastrophic events : report to the Committee on Homeland Security and Governmental Affairs, US Senate. Washington, D.C. United States Government Accountability Office. 2009. [cited RAND Library-NYAM.
645 United States General Accounting Office. Hospital preparedness: most urban hospitals have emergency plans but lack certain capacities for bioterrorism response: report to congressional committees. Washington, D.C. United States General Accounting Office. 2003. [cited RAND Library-NYAM.
646 United States General Accounting Office. Bioterrorism: preparedness varied across state and local jurisdictions : report to congressional committees. Washington, D.C. United States General Accounting Office. 2003. [cited RAND Library-NYAM.
647 United States General Accounting Office. Bioterrorism: information technology strategy could strengthen federal agencies’ abilities to respond to public health emergencies: report to congressional requesters. Washington, D.C. United States General Accounting Office. 2003. [cited RAND Library-NYAM.
648 United States Government Accountability Office. Project BioShield : actions needed to avoid repeating past problems with procuring new anthrax vaccine and managing the stockpile of licensed vaccine : report to Congressional requesters. Washington, D.C. United States Government Accountability Office. 2007. [cited RAND Library-NYAM.
649 United States Government Accountability Office. September 11 : HHS needs to develop a plan that incorporates lessons from the responder health programs : report to Congressional requesters. Washington, D.C. United States Government Accountability Office. 2008. [cited RAND Library-NYAM.
650 United States Government Accountability Office. Disaster housing : FEMA needs more detailed guidance and performance measures to help ensure effective assistance after major disasters ; report to congressional requesters. Washington, D.C. United States Government Accountability Office. 2009. [cited RAND Library-NYAM.
651 United States Government Accountability Office, United States Congress House Committee on Transportation and Infrastructure. Subcommittee on Economic Development PB, and Emergency Management. Emergency preparedness : improved planning and coordination necessary for modernization and integration of public alert and warning system : report to the Subcommittee on Economic Development, Public Buildings, and Emergency Management, Committee on Transportation and Infrastructure, House of Representatives. Washington, D.C. United States Government Accountability Office. 2009. [cited RAND Library-NYAM.
652 United States House of Representatives Hospital emergency surge capacity: not ready for the “predictable surprise” available at: http://cdrp.net/amts/docs/HospitalEmergencySurgeCapacityReport.pdfWashington, DC2008 [updated 2008; cited 2009 May 07]; Available from
653 Utley M, Pagel C, Peters MJ, Petros A, Lister P. Does triage to critical care during a pandemic necessarily result in more survivors?. Crit Care Med. Jan. 2011;39(1):179-83. [pmid: 20975553].
654 van der Spek ED, Wouters P, van Oostendorp H. Code Red: Triage Or COgnition-based DEsign Rules Enhancing Decisionmaking TRaining In A Game Environment. British Journal of Educational Technology. May. 2011;42(3):441-55.
655 van Kooij E, Schrever I, Kizito W, Hennaux M, Mugenya G, Otieno E, et al. Responding to major burn disasters in resource-limited settings: lessons learned from an oil tanker explosion in Nakuru, Kenya. J Trauma. Sep. 2011;71(3):573-6. [pmid: 21336193].
656 Varney S, Hirshon JM, Dischinger P, Mackenzie C. Extending injury prevention methodology to chemical terrorism preparedness: the Haddon Matrix and sarin. Am J Disaster Med. Nov–Dec. 2006;1(1):18-27. [pmid: 18274040].
657 Vaughan KD. Haiti: lessons learnt. The West Indian medical journal. 2010;59(2):119-21. [pmid: 21275113].
658 Vawter DE, Garrett JE, Gervais KG, Prehn AW, DeBruin DA. Dueling Ethical Frameworks for Allocating Health Resources. American Journal of Bioethics. 2010;10(4):54-6. [pmid: 20379925].
659 Vermeersch N, Verborgh C. Mass casualty management: lessons for the future. Acta Anaesthesiol Belg. 2005;56(4):417-21. [pmid: 16416961].
660 Voelker R. IOM offers new guidance in crisis care. JAMA. Oct. 21. 2009;302(15):1634. [pmid: 19843892].
661 Vorob’ev PA. Emergency care for the victims in mass disasters in peacetime. Feldsher Akush. Apr. 1991;56(4):45-50. [pmid: 1874310].
662 Waisman Y, Amir L, Mor M, Feigenberg Z, Daniel Aharonson L, Peleg K, et al. Prehospital Response and Field Triage in Pediatric Mass Casualty Incidents: The Israeli Experience. Clinical Pediatric Emergency Medicine. 2006;7(1):52-8.
663 Walderhaug S, Meland PH, Mikalsen M, Sagen T, Brevik JI. Evacuation support system for improved medical documentation and information flow in the field. International Journal of Medical Informatics. Feb. 2008;77(2):137-51. [pmid: 17324620].
664 Walsh DP, Mellon MM. The emergency medicine specialist in combat triage: A new and untapped resource. Military Medicine. 1990. 1990;155(4):187-9. [pmid: 2110344].
665 Warwick MC. Psychological effects of weapons of mass destruction. Mo Med. Jan. 2002;99(1):15-6. [pmid: 11816349].
666 Weiner E. Addressing Emergency Preparedness and Response Competencies for Nurses through Simulation Experiences. Clinical Simulation in Nursing. 2006;2(2):e43-e7.
667 Weiss R. Using technology to improve crisis response. Health Prog. Mar–Apr. 10. 2003;84(2):61.
668 Welling L, Perez RS, van Harten SM, Patka P, Mackie DP, Kreis RW, et al. Analysis of the pre-incident education and subsequent performance of emergency medical responders to the Volendam cafe fire. Eur J Emerg Med. Dec. 2005;12(6):265-9. [pmid: 16276254].
669 Wellington L. Century Foundation, Robert Wood Johnson Foundation. Breathing easier? report of the Century Foundation working group on Bioterrorism preparedness. New York, NY. Century Foundation Press. 2004. [cited RAND Library-NYAM.
670 Wessely S. Commentary on “terrorism, trauma, and mass casualty triage”. Biosecur Bioterror. Jun. 2007;5(2):164-7. [pmid: 17608602].
671 Wheeler DS. Pandemic influenza and the critically ill pediatric patient: Addressing the right issues for the “worst case” scenario. Pediatric Critical Care Medicine. May. 2010;11(3):436-8. [pmid: 20453622].
672 Whooley M. EMS weapons of mass destruction pilot program. Emerg Med Serv. Nov. 2004;33(11):97. [pmid: 15682764].
673 Wieling E, Mittal M. JMFT special section on mass trauma. J Marital Fam Ther. Apr. 2008;34(2):127-31. [pmid: 18412821].
674 Wiese CH, Vagts DA, Kampa U, Pfeiffer G, Grom IU, Gerth MA, et al. Palliative care and end-of-life patients in emergency situations. Recommendations on optimization of out-patient care. Anaesthesist. Feb. 2011;60(2):161-71. [pmid: 21184035].
675 Wilkinson A, Matzo M. Palliative care and mass casualty events in rendering mass medical care with scarce resources: A planning guide. Rockville, MD. AHRQ, Agency for Healthcare Research and Quality. 2006. Contract No.: Document Number|.
676 Wills HH, Nelson C, Shelton SR, Parker AM, Zambrano JA, Chan EW, et al. Are communities ready to conduct rapid and large-scale dispensing of Medications during a public health emergency?. [electronic resources]. Santa Monica, CA. Rand Health. 2009. [cited RAND Library-NYAM.
677 World Health Organization. The management of nutrition in major emergencies. Geneva. World Health Organization. 2000. [cited RAND Library-NYAM.
678 Wray R, Jupka K. What does the public want to know in the event of a terrorist attack using plague?. Biosecur Bioterror. 2004;2(3):208-15. [pmid: 15588059].
679 Wray R, Rivers J, Whitworth A, Jupka K, Clements B. Public perceptions about trust in emergency risk communication: qualitative research findings. Int J Mass Emerg Disasters. 2006;24:45-75.
680 Wright DJ. Perceived barriers of non-U.S. healthcare providers to responding during mass casualty incidents. Am J Disaster Med. Nov–Dec. 2009;4(6):345-51. [pmid: 20104727].
681 Xie PZ, Wang XB, Bai X, Song F, Chen DJ, Liu J, et al. Medical support of mass casualties in maritime disasters in peacetime. Zhongguo Wei Zhong Bing Ji Jiu Yi Xue. Dec. 2010;22(12):763-4. [pmid: 21190610].
682 Yi W, Ozdamar L. A dynamic logistics coordination model for evacuation and support in disaster response activities. European Journal of Operational Research. Jun. 2007;179(3):1177-93.
683 Zafren K. Avalanche triage: Are two birds in the bush better than one in the hand?. Wilderness and Environmental Medicine. 2010;21(3):273-4. [pmid: 20832710].
684 Zhang C, He Q, Qian YM, Zhu ZM, Yin M, Ruan DK. First aid of casualties in Wenchuan earthquake. Zhongguo Gu Shang. Oct. 2008;21(10):724-5. [pmid: 19105356].
685 Zhang S, Jiang Y, Zhang J. Experiences of treatment of mass burn casualties. Zhonghua Zheng Xing Shao Shang Wai Ke Za Zhi. May. 1997;13(3):202-4. [pmid: 10452001].
686 Zheng Q, Cai S, Chen J. Implementation of “four-early principle” to raise the successful rate in mass burn casualties. Zhonghua Zheng Xing Shao Shang Wai Ke Za Zhi. Jul. 1999;15(4):247-9. [pmid: 11593595].
687 Zhou Y. Treatment of mass burns. Zhonghua Zheng Xing Shao Shang Wai Ke Za Zhi. Jul. 1999;15(4):250-1. [pmid: 11593596].
688 Zhu JM, Huang J, Liu DG, Han JY. Resources Allocation Problem for Local Reserve Depots in Disaster Management Based on Scenario Analysis. Zhang XS, Liu DG, Wang Y, editors. Operations Research and Its Applications, Proceedings. 2008:395-407.
689 Zimmerman JL, Sprung CL. Chapter 8. Medical procedures. Intensive Care Medicine. 2010;36(SUPPL 1):S65-9. [pmid: 20213423].
690 Zimmerman R, Restrepo CE, Culpen A, Remington WE, Kling A, Portelli I, et al. Risk communication for catastrophic events: Results from focus groups. Journal of Risk Research. 2010;13(7):913-35.
691 Zoraster R. Disaster triage: is it time to stop START?. Am J Disaster Med. Nov–Dec. 2006;1(1):7-9. [pmid: 18274037].
692 Zoraster RM. “Social worth” will not affect allocation of scarce resources in a pandemic or disaster: political correctness, sophistry, or reality?. Am J Disaster Med. Jan–Feb. 2009;4(1):5-7. [pmid: 19378663].

### Did not report outcomes of training using performance measures (N=14)

1 Chi CH, Chao WH, Chuang CC, Tsai MC, Tsai LM. Emergency medical technicians’ disaster training by tabletop exercise. Am J Emerg Med. Sep. 2001;19(5):433-6. [pmid: 11555806].
2 Decker SI, Galvan TJ, Sridaromont K. Integrating an exercise on mass casualty response into the curriculum. J Nurs Educ. Jul. 2005;44(7):339-40. [pmid: 16094797].
3 Emery RJ, Sprau DD, Morecook RC, Herbold J. Surge capacity volunteer perspectives on a field training exercise specifically designed to emphasize likely roles during a disaster response. Health Phys. Nov. 2009;97(5 Suppl):S155-60. [pmid: 19820470].
4 Grant WD, Secreti L. Joint civilian/national guard mass casualty exercise provides model for preparedness training. Mil Med. Aug. 2007;172(8):806-11. [pmid: 17803070].
5 Latimer CK, Brown JC, Gion TC, Wong C, Scheulen JJ, Kirsch TD, et al. Electronic mass casualty assessment and planning scenarios. Johns Hopkins APL Technical Digest (Applied Physics Laboratory). 2010;28(3):230-1.
6 Limmer D. Small investment, high yield. An easy way to teach triage without staging an entire mass-casualty incident. Emerg Med Serv. Jul. 2006;35(7):30. [pmid: 16878746].
7 Lonchena T. Diaster school. EMS Mag. Feb. 2008;37(2):59-63. [pmid: 18320857].
8 Milkhu CS, Howell DC, Glynne PA, Raptis D, Booth HL, Langmead L, et al. Mass casualty incidents: are NHS staff prepared? An audit of one NHS foundation trust. Emerg Med J. Sep. 2008;25(9):562-4. [pmid: 18723702].
9 Posner Z, Admi H, Menashe N. Ten-fold expansion of a burn unit in mass casualty: how to recruit the nursing staff. Disaster Manag Response. Oct–Dec. 2003;1(4):100-4. [pmid: 14666094].
10 Pryor E, Heck E, Norman L, Weiner B, Mathews R, Black J, et al. Integrated decision-making in response to weapons of mass destruction incidents: development and initial evaluation of a course for healthcare professionals. Prehosp Disaster Med. Jan–Feb. 2006;21(1):24-30. [pmid: 16602262].
11 Ruter A, Ortenwall P, Vikstrom T. Staff procedure skills in management groups during exercises in disaster medicine. Prehosp Disaster Med. Jul–Aug. 2007;22(4):318-21. [pmid: 18019099].
12 Vinson E. Managing bioterrorism mass casualties in an emergency department: lessons learned from a rural community hospital disaster drill. Disaster Manag Response. Jan–Mar. 2007;5(1):18-21. [pmid: 17306750].
13 Weiner E, Gordon J, Irwin M. An international online curriculum for nurses in emergency planning and response. Stud Health Technol Inform. 2006;122:1004. [pmid: 17102514].
14 Wetta-Hall R, Berg-Copas GM, Cusick Jost J, Jost G. Preparing for burn disasters: predictors of improved perceptions of competency after mass burn care training. Prehosp Disaster Med. Sep–Oct. 2007;22(5):448-53. [pmid: 18087916].

### Was not based on adequate consensus for KQ1 and 2 proposed strategies (N=277)

1 The Alberta and Xenia tornados: how two hospitals handled hundreds of victims under trying conditions. Hosp Secur Saf Manage. Nov. 2000;21(7):5-9.
2 Here are options for communicating. ED Manag. Dec. 2001;13(12):138-40. [pmid: 11769136].
3 Talking to each other in a crisis. Jt Comm Perspect. Dec. 2001;21(12):16-7. [pmid: 11766189].
4 Preparing for a mass casualty event. Jt Comm Perspect. Dec. 2001;21(12):10-1.
5 AHRQ researchers examine the role of informatics in responding to bioterrorism, mass disasters, and war. Comput Inform Nurs. Jan–Feb. 2003;21(1):1-2. [pmid: 12585267].
6 Surge capacity for mass-casualty disasters. Healthc Hazard Manage Monit. Dec. 2004;18(4):1-6.
7 Critical issues in preparing for a mass casualty event: highlights from a new community planning guide. Biosecur Bioterror. Sep. 2007;5(3):268-70. [pmid: 17903095].
8 Disaster surge fails to fluster ED staff. ED Manag. Jun. 2008;20(6):63-4. [pmid: 18807296].
9 Pandemic strikes--who receives no treatment?. ED Manag. Jul. 2008;20(7):76-7. [pmid: 18686894].
10 ‘ED of the future’ girded for disasters. ED Manag. Mar. 2008;20(3):33-5. [pmid: 18447236].
11 Planning together: community and hospital response to disasters. Healthc Hazard Manage Monit. May. 2008;21(9):1-9.
12 Comments from the Center for Biosecurity of UPMC on DHS Proposed Guidance for Responders during a Wide-Area Anthrax Attack. Biosecur Bioterror. Mar. 2010;8(1):85-8. [pmid: 20230236].
13 Medical Surge Capacity and Capability: A Management System for Integrating Medical and Health Resources During Large-Scale Emergencies: U.S. Department of Health and Human Services. September. 2007. Contract No.: Document Number|.
14 Abramson M, Chao W, Macker J, Mittu R. Coordination in disaster management and response: A unified approach. Jamali N, Scerri P, Sugawara T, editors. Massively Multi-Agent Technology. 2008:162-75.
15 Adini B, Goldberg A, Laor D, Cohen R, Bar-Dayan Y. Editorial comments--Staff procedure skills in management groups during exercises in disaster medicine. Prehosp Disaster Med. Jul–Aug. 2007;22(4):322-4. [pmid: 18816895].
16 Adini B, Goldberg A, Laor D, Cohen R, Zadok R, Bar-Dayan Y. Assessing levels of hospital emergency preparedness. Prehosp Disaster Med. Nov–Dec. 2006;21(6):451-7. [pmid: 17334195].
17 Allen GM, Parrillo SJ, Will J, Mohr JA. Principles of disaster planning for the pediatric population. Prehosp Disaster Med. Nov–Dec. 2007;22(6):537-40. [pmid: 18709943].
18 Alm AM, Gao T, White DM. Pervasive patient tracking for mass casualty incident response. AMIA Annu Symp Proc. 2006;842.
19 Ammartyothin S, Ashkenasi I, Schwartz D, Leiba A, Nakash G, Pelts R, et al. Medical response of a physician and two nurses to the mass-casualty event resulting in the Phi Phi Islands from the tsunami. Prehosp Disaster Med. May–Jun. 2006;21(3):212-4. [pmid: 16892887].
20 Antommaria AHM, Sweney J, Poss WB. Critical appraisal of: Triaging pediatric critical care resources during a pandemic: Ethical and medical considerations. Pediatric Critical Care Medicine. May. 2010;11(3):396-400. [pmid: 20453611].
21 Arisoylu M, Mishra R, Rao R, Lenert LA. 802.11 wireless infrastructure to enhance medical response to disasters. AMIA Annu Symp Proc. 2005:1-5. [pmid: 16778990].
22 Armstrong JH. Preparing for the predictable surprise: surgeons and disaster response. J Craniofac Surg. May. 2008;19(3):563-5. [pmid: 18520365].
23 Armstrong JH, Frykberg ER, Burris DG. Toward a national standard in primary mass casualty triage. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S8-10. [pmid: 18769269].
24 Arnold JL. Disaster myths and hurricane Katrina 2005: can public officals and the media learn to provide reponsible crisis communication during disasters?. Prehosp Disaster Med. Jan–Feb. 2006;21(1):1-3. [pmid: 16602259].
25 Arquilla B, Paladino L, Reich C, Brandler E, Lucchesi M, Shetty S. Using a joint triage model for multi-hospital response to a mass casualty incident in New York city. J Emerg Trauma Shock. May. 2009;2(2):114-6. [pmid: 19561971].
26 Arras JD. Rationing vaccine during an avian influenza pandemic: why it won’t be easy. Yale J Biol Med. Oct. 2005;78(5):287-300. [pmid: 17132335].
27 Asllani A, Dileepan P, Ettkin L. A methodology for using simulation to optimize emergency mass vaccination parameters. J Med Syst. Dec. 2007;31(6):453-9. [pmid: 18041277].
28 Association of State and Territorial Health Officials, National Association of County & City Health Officials (US), National Association of Community Health Centers. Collaborating with community health centers for preparedness. Arlington, VA. Association of State and Territorial Health Officials. 2008. [cited RAND Library-NYAM.
29 Association of State and Territorial Health Officials (US). The strategic national stockpile : selected promising practices. Arlington, VA. Association of State and Territorial Health Officials. 2008. [cited RAND Library-NYAM.
30 Auf der Heide E. Convergence behavior in disasters. Ann Emerg Med. Apr. 2003;41(4):463-6. [pmid: 12658244].
31 Bail HJ, Fischer P, Weidringer JW, Mahlke L, Matthes G, Preck OS, et al. Disaster medicine in Germany: The DGU disaster medicine network. Katastrophenmedizin in der Bundesrepublik Deutschland: Das Netzwerk Katastrophenmedizin der DGU. 2007;9(4):279-83.
32 Baker DJ, Telion C, Carli P. Multiple casualty incidents: the prehospital role of the anesthesiologist in Europe. Anesthesiol Clin. Mar. 2007;25(1):179-88. xi. [pmid: 17400164].
33 Balch D. Developing a National Inventory of Telehealth Resources for Rapid and Effective Emergency Medical Care: a white paper developed by the American Telemedicine Association Emergency Preparedness and Response Special Interest Group. Telemed J E Health. Aug. 2008;14(6):606-10. [pmid: 18729762].
34 Barajas K, Stewart WA, Combs EW. The Army chemical/biological SMART (SMART-CB) team: The nurse’s role. Critical Care Nursing Clinics of North America. 2003;15(2):257-64. [pmid: 12755191].
35 Barbera JA, Yeatts DJ, Macintyre AG. Challenge of hospital emergency preparedness: analysis and recommendations. Disaster Med Public Health Prep. Jun. 2009;3(2 Suppl):S74-82. [pmid: 19491592].
36 Barelli A, Biondi I, Soave M, Tafani C, Bononi F. The comprehensive medical preparedness in chemical emergencies: ‘the chain of chemical survival’. Eur J Emerg Med. Apr. 2008;15(2):110-8. [pmid: 18446078].
37 Barillo DJ, Dimick AR, Cairns BA, Hardin WD, Acker Iii JE, Peck MD. The Southern Region burn disaster plan. Journal of Burn Care and Research. 2006;27(5):589-95. [pmid: 16998389].
38 Barishansky RM, O’Connor K. Managing a major incident. Essential elements of a successful outcome. EMS Mag. Nov. 2007;36(11):41-2. [pmid: 18044392].
39 Barnes J. Mobile medical teams: do A&E nurses have the appropriate experience?. Emerg Nurse. Feb. 2006;13(9):18-23. [pmid: 16502631].
40 Beigi RH, Hodges J, Baldisseri M, English D, Magee-Womens Hosp, Ethics C. Clinical review: Considerations for the triage of maternity care during an influenza pandemic - one institution’s approach. Critical Care. 2010;14(3).
41 Benson M, Koenig KL, Schultz CH. Disaster triage: START, then SAVE--a new method of dynamic triage for victims of a catastrophic earthquake. Prehosp Disaster Med. Apr–Jun. 1996;11(2):117-24. [pmid: 10159733].
42 Bielajs I, Burkle FM Jr, Archer L, Smith E. Development of prehospital, population-based triage-management protocols for pandemics. Prehospital and Disaster Medicine. 2008;23(5):420-30. [pmid: 19189611].
43 Bland SA. Mass casualty management for radiological and nuclear incidents. J R Army Med Corps. Sep. 2004;150(3 Suppl 1):27-34. [pmid: 15615108].
44 Bogle LB, Boyd JJ, McLaughlin KA. Triaging Multiple Victims in an Avalanche Setting: The Avalanche Survival Optimizing Rescue Triage Algorithmic Approach. Wilderness and Environmental Medicine. 2010;21(1):28-34. [pmid: 20591351].
45 Bogucki S, Jubanyik K. Triage, rationing, and palliative care in disaster planning. Biosecur Bioterror. Jun. 2009;7(2):221-4. discussion 4. [pmid: 19635006].
46 Born CT, DeLong WG Jr. Organizing the orthopaedic trauma association mass casualty response team. Clin Orthop Relat Res. May. 2004;(422):114-6. [pmid: 15187842].
47 Bostick NA, Subbarao I, Burkle FM Jr, Hsu EB, Armstrong JH, James JJ. Disaster triage systems for large-scale catastrophic events. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S35-9. [pmid: 18769264].
48 Branson RD, Johannigman JA, Daugherty EL, Rubinson L. Surge capacity mechanical ventilation. Respir Care. Jan. 2008;53(1):78-88. discussion - 90. [pmid: 18173862].
49 Briggs SM. Disaster management teams. Curr Opin Crit Care. Dec. 2005;11(6):585-9. [pmid: 16292064].
50 Brown TL, Hernon C, Owens B. Incidence of vomiting in burns and implications for mass burn casualty management. Burns. Mar. 2003;29(2):159-62. [pmid: 12615463].
51 Bulson J, Bulson T. How can hospitals be better prepared? A case study of an exercise design program and its effect on a real-life event. J Healthc Prot Manage. 2010;26(2):89-94. [pmid: 20873503].
52 Buono C, Chan TC, Brown S, Lenert L. Role-tailored software systems for medical response to disasters: enhancing the capabilities of “mid-tier” responders. AMIA Annu Symp Proc. 2005;908.
53 Buono C, Huang R, Brown S, Chan TC, Killeen J, Lenert L. Role-tailored software systems for coordinating care at disaster sites: enhancing collaboration between the base hospitals with the field. AMIA Annu Symp Proc. 2006;867.
54 Burkle FM Jr, Hsu EB, Loehr M, Christian MD, Markenson D, Rubinson L, et al. Definition and functions of health unified command and emergency operations centers for large-scale bioevent disasters within the existing ICS. Disaster Med Public Health Prep. Nov. 2007;1(2):135-41. [pmid: 18388641].
55 Burrington-Brown J. Disaster planning for a mass-casualty event. Journal of the American Health Information Management Association. 2002;73(10):64A-C.
56 Caldicott DG, Edwards NA, Tingey D, Bonnin R. Medical response to a terrorist attack and weapons of mass destruction. Emerg Med (Fremantle). Sep. 2002;14(3):230-9. [pmid: 12487039].
57 Campbell C. The benefits of designing a stratification system for New York City pediatric intensive care units for use in regional surge capacity planning and management. J Community Health. Aug. 2010;35(4):337-47. [pmid: 20361242].
58 Carlascio DR, McSharry MC, LeJeune CJ, Lewis JH, Schneider CN, Marshall WJ. Air medical response to the 1990 Will County, Illinois, tornado. J Air Med Transp. Oct. 9. 1991;10(10):7-11. 3. 6. [pmid: 10115151].
59 Caro JJ, Coleman CN, Knebel A, DeRenzo EG. Unaltered Ethical Standards for Individual Physicians in the Face of Drastically Reduced Resources Resulting from an Improvised Nuclear Device Event. Journal of Clinical Ethics. Spr. 2011;22(1):33-41. [pmid: 21595353].
60 Castle N. Triage and transport decisions after mass casualty incidents. Emerg Nurse. Apr. 2006;14(1):22-5. [pmid: 16634325].
61 Chaffee MW. Hospital response to acute-onset disasters: the state of the science in 2005. Nurs Clin North Am. Sep. 2005;40(3):565-77. x. [pmid: 16112000].
62 Chan JT, Yeung RS, Tang SY. Hospital preparedness for chemical and biological incidents in Hong Kong. Hong Kong Med J. Dec. 2002;8(6):440-6. [pmid: 12459601].
63 Cherry RA, Trainer M. The current crisis in emergency care and the impact on disaster preparedness. BMC Emerg Med. 2008;8:7. [pmid: 18452615].
64 Childers AK, Taaffe KM, editors. Evacuating patients based on priority modeling. IIE Annual Conference and Expo 2008. 2008. Vancouver, BC. SCOPUS.
65 Chiu DKW, Lin DTT, Kafeza E, Wang MH, Hu HY, Hu H, et al. Alert based disaster notification and resource allocation. Information Systems Frontiers. Mar. 2010;12(1):29-47.
66 Chokshi NK, Behar S, Nager AL, Dorey F, Upperman JS. Disaster management among pediatric surgeons: preparedness, training and involvement. Am J Disaster Med. Jan–Feb. 2008;3(1):5-14. [pmid: 18450274].
67 Chu Y, Ganz A. WISTA: A wireless telemedicine system for disaster patient care. Mobile Networks and Applications. 2007;12(2–3):201-14.
68 Chu Y, Huang X, Ganz A, editors. WISTA: A wireless transmission system for disaster patient care. 2nd International Conference on Broadband Networks, BROADNETS 2005. 2005. Boston, MA. SCOPUS.
69 Chung S, Shannon M. Hospital planning for acts of terrorism and other public health emergencies involving children. Arch Dis Child. Dec. 2005;90(12):1300-7. [pmid: 16301559].
70 Cinti SK, Barnosky AR, Gay SE, Goold SD, Lozon MM, Kim K, et al. Bacterial pneumonias during an influenza pandemic: how will we allocate antibiotics?. Biosecur Bioterror. Sep. 2009;7(3):311-6. [pmid: 19821750].
71 Ciraulo DL, Barie PS, Briggs SM, Bjerke HS, Born CT, Capella J, et al. An update on the surgeons scope and depth of practice to all hazards emergency response. J Trauma. Jun. 2006;60(6):1267-74. [pmid: 16766970].
72 Cohen RS, Murphy B, Ahern T, Hackel A. DISASTER PLANNING - TRIAGING RESOURCE ALLOCATION IN NEONATOLOGY. Journal of Investigative Medicine. Jan. 2010;58(1):298. [pmid: 20009955].
73 Coleman CH. Allocating vaccines and antiviral medications during an influenza pandemic. Seton Hall Law Rev. 2009;39(4):1111-23. [pmid: 20718130].
74 Coleman CH, Reis A. Potential penalties for health care professionals who refuse to work during a pandemic. JAMA - Journal of the American Medical Association. 2008;26;299(12):1471-3.
75 Cone DC, Cummings BA. Hospital disaster staffing: if you call, will they come?. Am J Disaster Med. Nov–Dec. 2006;1(1):28-36. [pmid: 18274041].
76 Covejoy JC. Initial approach to patient management after large-scale disasters. Clinical Pediatric Emergency Medicine. 2002;3(4):217-23.
77 Crawford D, Gao T, White D. Information collection and dissemination: toward a portable, real-time information sharing platform for emergency response. AMIA Annu Symp Proc. 2006;898.
78 Crowther KG, Haimes YY, Taub G. Systemic valuation of strategic preparedness through application of the inoperability input-output model with lessons learned from Hurricane Katrina. Risk Anal. Oct. 2007;27(5):1345-64. [pmid: 18076501].
79 Daugherty EL. Health care worker protection in mass casualty respiratory failure: infection control, decontamination, and personal protective equipment. Respir Care. Feb. 2008;53(2):201-12. discussion 12–14. [pmid: 18218151].
80 Daugherty EL, Branson R, Rubinson L. Mass casualty respiratory failure. Current Opinion in Critical Care. Feb. 2007;13(1):51-6. [pmid: 17198049].
81 Day JM, Junglas I, Silva L. Information Flow Impediments in Disaster Relief Supply Chains. Journal of the Association for Information Systems. 2009;10(8):637-60.
82 Demchak B, Chan TC, Griswold WG, Lenert LA. Situational awareness during mass-casualty events: command and control. AMIA Annu Symp Proc. 2006;905.
83 Demchak B, Griswold WG, Lenert LA. Data quality for situational awareness during mass-casualty events. AMIA Annu Symp Proc. 2007:176-80. [pmid: 18693821].
84 DerGurahian J. Georgia’s surge plan. Seeking 17 portable field hospitals. Mod Healthc. Aug. 27. 2007;37(34):38. [pmid: 17957874].
85 Douglas V. Developing disaster management modules: a collaborative approach. Br J Nurs. May. 10–23. 2007;16(9):526-9. [pmid: 17551443].
86 Downar J, Seccareccia D. Associated Med Serv Inc Educ F. Palliating a Pandemic: “All Patients Must Be Cared For”. Journal of Pain and Symptom Management. Feb. 2010;39(2):291-5. [pmid: 20152591].
87 Einav S, Spira RM, Hersch M, Reissman P, Schecter W. Surgeon and hospital leadership during terrorist-related multiple-casualty events - A coup d’etat. Archives of Surgery. Aug. 2006;141(8):815-22. [pmid: 16927490].
88 Emery RJ, Sprau DD, Morecook RC. Risk communication considerations to facilitate the screening of mass populations for potential contamination with radioactive material. Health Phys. Nov. 2008;95(5 Suppl):S168-74. [pmid: 18849710].
89 Engel CC, Locke S, Reissman DB, DeMartino R, Kutz I, McDonald M, et al. Terrorism, trauma, and mass casualty triage: how might we solve the latest mind-body problem?. Biosecur Bioterror. Jun. 2007;5(2):155-63. [pmid: 17608601].
90 Everly GS Jr, Flynn BW. Principles and practical procedures for acute psychological first aid training for personnel without mental health experience. Int J Emerg Ment Health. Spring. 2006;8(2):93-100. [pmid: 16703847].
91 Felland LE, Katz A, Liebhaber A, Cohen GR. Developing health system surge capacity: community efforts in jeopardy. Res Briefs. Jun. 2008;(5):1-8.
92 Fernandez JB, Glotzer DL, Triola MM, Psoter WJ. A unique role for dental school faculty: telephone triage training and integration into a health departments’ emergency response planning. Am J Disaster Med. May–Jun. 2008;3(3):141-6. [pmid: 18666510].
93 Fiedrich F. Ieee. An HLA-based multiagent system for optimized resource allocation after strong earthquakes. 2006.
94 Fothergill A, Palumbo MV, Rambur B, Reinier K, McIntosh B. The volunteer potential of inactive nurses for disaster preparedness. Public Health Nursing. 2005;22(5):414-21. [pmid: 16229734].
95 Franco C, Toner E, Waldhorn R, Inglesby TV, O’Toole T. The national disaster medical system: past, present, and suggestions for the future. Biosecur Bioterror. Dec. 2007;5(4):319-25. [pmid: 18052820].
96 Friedman FD. Public relations in disaster management and planning for emergency physicians. J Emerg Med. Sep–Oct. 1995;13(5):661-8. [pmid: 8530787].
97 Friese G. Principles of mass casualty response to terrorist attacks. What American responders can learn from the Israeli experience. EMS Mag. Oct. 2007;36(10):91-7. [pmid: 17983100].
98 Fry EA, Lenert LA. MASCAL: RFID tracking of patients, staff and equipment to enhance hospital response to mass casualty events. AMIA Annu Symp Proc. 2005:261-5. [pmid: 16779042].
99 Gao T, Massey T, Bishop W, Bernstein D, Selavo L, Alm A, editors. Integration of triage and biomedical devices for continuous, real-time, automated patient monitoring. Proceedings of the 3rd IEEE-EMBS International Summer School and Symposium on Medical Devices and Biosensors, ISSS-MDBS 2006. 2006. Cambridge, MA. SCOPUS.
100 Gao T, White D. A next generation electronic triage to aid mass casualty emergency medical response. Conf Proc IEEE Eng Med Biol Soc. 2006;(Suppl):6501-4. [pmid: 17959436].
101 Glassman ES, Parrillo SJ. Use of alternate healthcare facilities as alternate transport destinations during a mass-casualty incident. Prehosp Disaster Med. Mar–Apr. 2010;25(2):178-82. [pmid: 20468000].
102 Gómez AM, Domínguez CJ, Pedrueza CI, Calvente RR, Lillo VM, Canas JM. Management and analysis of out-of-hospital health-related responses to simultaneous railway explosions in Madrid, Spain. European Journal of Emergency Medicine. 2007;14(5):247-55. [pmid: 17823558].
103 Gong Q, Batta R. Allocation and reallocation of ambulances to casualty clusters in a disaster relief operation. Iie Transactions. Jan. 2007;39(1):27-39.
104 Good L. Ethical decision making in disaster triage. J Emerg Nurs. Apr. 2008;34(2):112-5. [pmid: 18358347].
105 Gostin LO. Medical countermeasures for pandemic influenza: Ethics and the law. Journal of the American Medical Association. 2006;1;295(5):554-6.
106 Gougelet RM, Rea ME, Nicolalde RJ, Geiling JA, Swartz HM. The view from the trenches: part 1-emergency medical response plans and the need for EPR screening. Health Phys. Feb. 2010;98(2):118-27. [pmid: 20065673].
107 Greenfield E, Winfree J. Nursing’s role in the planning, preparation, and response to burn disaster or mass casualty events. J Burn Care Rehabil. Mar–Apr. 2005;26(2):166-9. [pmid: 15756119].
108 Grissom TE, Farmer JC. The provision of sophisticated critical care beyond the hospital: lessons from physiology and military experiences that apply to civil disaster medical response. Crit Care Med. Jan. 2005;33(1 Suppl):S13-21. [pmid: 15640673].
109 Hadef H, Bartier JC, Delplancq H, Dupeyron JP. Using baseline data to address the lack of hospital beds during mass-casualty incidents. Prehosp Disaster Med. Jul–Aug. 2008;23(4):377-9. [pmid: 18935955].
110 Hall SK. Management of chemical disaster victims. J Toxicol Clin Toxicol. 1995;33(6):609-16. [pmid: 8523481].
111 Hamilton J. Automated MCI patient tracking: managing mass casualty chaos via the Internet. JEMS. Apr. 2003;28(4):52-6. [pmid: 12736608].
112 Hammond J. Mass casualty incidents: planning implications for trauma care. Scand J Surg. 2005;94(4):267-71. [pmid: 16425621].
113 Hanfling D. Equipment, supplies, and pharmaceuticals: how much might it cost to achieve basic surge capacity?. Acad Emerg Med. Nov. 2006;13(11):1232-7. [pmid: 16801633].
114 Hassinen M, Marttila-Kontio M. Ieee. EMS Coordination in Large Scale Emergencies Using Automated Patient Monitoring. 2008.
115 Heath SE, Dorn R, Linnabary RD, Casper J, Hooks J, Marshall K. Integration of veterinarians into the official response to disasters. J Am Vet Med Assoc. Feb. 1. 1997;210(3):349-52. [pmid: 9057916].
116 Heller O, Aldar Y, Vosk M, Shemer J. An argument for equipping civilian hospitals with a multiple respirator system for a chemical warfare mass casualty situation. Isr J Med Sci. Nov-Dec. 1991;27(11–12):652-5. [pmid: 1757240].
117 Heritage Foundation (Washington, DC. Health care and homeland security : crossroads of emergency response : a resource guide and report of the Health Care and Homeland Security Conference. July 17–18, 2007. Washington, DC Heritage Foundation. 2008. [cited RAND Library-NYAM.
118 Hick JL, Chipman J, Loppnow G, Conterato M, Roberts D, Heegaard WG, et al. Hospital response to a major freeway bridge collapse. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S11-6. [pmid: 18769260].
119 Hick JL, Ho JD, Heegaard WG, Brunette DD, Lapine A, Ward T, et al. Emergency medical services response to a major freeway bridge collapse. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S17-24. [pmid: 18769261].
120 Hick JL, Koenig KL, Barbisch D, Bey TA. Surge capacity concepts for health care facilities: the CO-S-TR model for initial incident assessment. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S51-7. [pmid: 18769268].
121 Hick JL, Rubinson L, O’Laughlin DT, Christopher JC. Clinical review: Allocating ventilators during large-scale disasters - Problems, planning, and process. Critical Care. 2007;11(3).
122 Hick JL, Rubinson L, O’Laughlin DT, Farmer JC. Clinical review: allocating ventilators during large-scale disasters--problems, planning, and process. Crit Care. 2007;11(3):217. [pmid: 17601354].
123 Hicks JL, Barbera JA, Kelen GD. Refining surge capacity: conventional, contingency, and crisis capacity. Disaster Med Public Health Prep. 2009;3:S59-S67. [pmid: 19349869].
124 Hoard M, Homer J, Manley W, Furbee P, Haque A, Helmkamp J. Systems modeling in support of evidence-based disaster planning for rural areas. Int J Hyg Environ Health. 2005;208(1–2):117-25. [pmid: 15881985].
125 Hodge JG Jr, Gable LA, Calves SH. Volunteer health professionals and emergencies: assessing and transforming the legal environment. Biosecur Bioterror. 2005;3(3):216-23. [pmid: 16181044].
126 Hodge JG Jr, Gostin LO, Vernick JS. The pandemic and All-Hazards Preparedness Act: improving public health emergency response. JAMA. Apr. 18. 2007;297(15):1708-11. [pmid: 17440147].
127 Hogg W, Lemelin J, Huston P, Dahrouge S. Increasing epidemic surge capacity with home-based hospital care. Can Fam Physician. May. 2006;52:563-4. 70. 2. [pmid: 16739820].
128 Holt GR. Making difficult ethical decisions in patient care during natural disasters and other mass casualty events. Otolaryngol Head Neck Surg. Aug. 2008;139(2):181-6. [pmid: 18656712].
129 Hopmeier M, Abrahams J, Carr Z. Some considerations for mass casualty management in radiation emergencies. Health Phys. Jun. 2010;98(6):790-4. [pmid: 20445382].
130 Hotchkin DL, Rubinson L. Modified critical care and treatment space considerations for mass casualty critical illness and injury. Respir Care. Jan. 2008;53(1):67-74. discussion -7. [pmid: 18173861].
131 Hudson TL, Weichart T. A method of transporting critical care mass casualties. Disaster Manag Response. Sep. 2002:26-8. [pmid: 12685464].
132 Hughes LE, Derrickson S, Dominguez B, Schreiber M. Economical emergency response and lower profile states: A behavioral health reference for the rest of us. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2(2):102-8.
133 Inampudi VS, Ganz A. Web based tool for resource allocation in multiple mass casualty incidents. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:1710-3. [pmid: 19964011].
134 Iserson KV, Pesik N. Ethical resource distribution after biological, chemical, or radiological terrorism. Camb Q Healthc Ethics. Fall. 2003;12(4):455-65. [pmid: 14619379].
135 Ishii N, Nakayama S. Emergency medical care following the great Hanshin-Awaji earthquake: practices and proposals (a report from a university hospital located in the damaged region). Kobe J Med Sci. Jun. 1996;42(3):173-86. [pmid: 8973086].
136 Jacob B, Mawson AR, Payton M, Guignard JC. Disaster mythology and fact: Hurricane Katrina and social attachment. Public Health Rep. Sep–Oct. 2008;123(5):555-66. [pmid: 18828410].
137 Jenkins JL, McCarthy ML, Sauer LM, Green GB, Stuart S, Thomas TL, et al. Mass-casualty triage: time for an evidence-based approach. Prehosp Disaster Med. Jan–Feb. 2008;23(1):3-8. [pmid: 18491654].
138 Jia HZ, Ordonez F, Dessouky MM. Solution approaches for facility location of medical supplies for large-scale emergencies. Computers & Industrial Engineering. Mar. 2007;52(2):257-76.
139 Johnson DE. Hospitals are more ready for bioterrorism. Health Care Strateg Manage. Nov. 2001;19(11):2-3.
140 Joint Commission on Accreditation of Healthcare Organizations. Health care at the crossroads: strategies for creating and sustaining community-wide emergency preparedness systems. Oakbrook Terrace, IL. Joint Commission on Accreditation of Healthcare Organizations. 2003. [cited RAND Library-NYAM.
141 Jones EG, Dias MB, Stentz A. Ieee. Learning-enhanced market-based task allocation for oversubscribed domains. 2007.
142 Kaiser HE, Barnett DJ, Hayanga AJ, Brown ME, Filak AT. Medical students’ participation in the 2009 Novel H1N1 influenza vaccination administration: policy alternatives for effective student utilization to enhance surge capacity in disasters. Disaster Med Public Health Prep. Jun. 2011;5(2):150-3. [pmid: 21482704].
143 Kapur GB, Pillow MT, Nemeth I. Prehospital Care Algorithm for Blast Injuries due to Bombing Incidents. Prehosp Disaster Med. Nov–Dec. 2010;25(6):595-600. [pmid: 21181697].
144 Kelley RL. EMS response to mass shootings. EMS Mag. Oct. 2008;37(10):86-90. [pmid: 18959344].
145 Khan FJ, Hassan M. Disaster planning for mass trauma care: Implications for low income countries. Italian Journal of Public Health. 2010;7(2):32-7.
146 Kim DK, Yoo SK, Kim SH. Instant wireless transmission of radiological images using a personal digital assistant phone for emergency teleconsultation. J Telemed Telecare. 2005;11(Suppl 2):S58-61. [pmid: 16375799].
147 Kipnis K. Overwhelming casualties: medical ethics in a time of terror. Account Res. Jan–Mar. 2003;10(1):57-68. [pmid: 14552301].
148 Kissoon N, Bohn D. Use of extracorporeal technology during pandemics: Ethical and staffing considerations. Pediatric Critical Care Medicine. 2010;11(6):757-8. [pmid: 21057269].
149 Klein KR, Pepe PE, Burkle FM Jr, Nagel NE, Swienton RE. Evolving need for alternative triage management in public health emergencies: a Hurricane Katrina case study. Disaster Med Public Health Prep. Sep. 2008;2(Suppl 1):S40-4. [pmid: 18769266].
150 Koenig KL, Lim HCS, Tsai SH. Crisis Standard of Care: Refocusing Health Care Goals During Catastrophic Disasters and Emergencies. Journal of Experimental and Clinical Medicine. 2011;3(4):159-65.
151 Kondaveti R, Ganz A. Decision support system for resource allocation in disaster management. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:3425-8. [pmid: 19963582].
152 Kramer GH, Capello K, Hauck B, Moodie G, Dinardo A, Burns L, et al. A methodology for improving throughput using portal monitors. Radiation Protection Dosimetry. 2009;134(3–4):152-8. [pmid: 19383803].
153 Kraus CK, Levy F, Kelen GD. Lifeboat ethics: considerations in the discharge of inpatients for the creation of hospital surge capacity. Disaster Med Public Health Prep. Jul. 2007;1(1):51-6. [pmid: 18388604].
154 Kuschner WG, Pollard JB, Ezeji-Okoye SC. Ethical triage and scarce resource allocation during public health emergencies: tenets and procedures. Hosp Top. Summer. 2007;85(3):16-25. [pmid: 17711810].
155 Kutz I, Bleich A. Mental health interventions in a general hospital following terrorist attacks: the Israeli experience. Journal of Aggression, Maltreatment & Trauma. 2005;10(1/2):425-37.
156 Landesman LY. Public health management of disasters the pocket guide. Washington DC. American Public Health Association. 2006. [cited RAND Library-NYAM.
157 Latasch L, Jung G, Ries R, Stark S. New concepts of medical care of 1000 and more injured people (in regard of the soccer world championship 2006). Neuere medizinische versorgungskonzepte (zur WM 2006) bei 1000 und mehr verletzten. 2006;9(3):258-63.
158 Lee A, Chuh AA. Facing the threat of influenza pandemic - roles of and implications to general practitioners. BMC Public Health. 2010;10:661. [pmid: 21044300].
159 Lee VJ, Low E. Coordination and resource maximization during disaster relief efforts. Prehosp Disaster Med. Jan-Feb. 2006;21(1):s8-12. [pmid: 16602267].
160 Lehavi O, Leiba A, Dahan Y, Schwartz D, Benin-Goren O, Schwartz R, et al. Lessons learned from chlorine intoxications in swimming pools: the challenge of pediatric mass toxicological events. Prehosp Disaster Med. Jan–Feb. 2008;23(1):90-5. [pmid: 18491668].
161 Lenert LA, Palmer DA, Chan TC, Rao R. An Intelligent 802.11 Triage Tag for medical response to disasters. AMIA Annu Symp Proc. 2005:440-4. [pmid: 16779078].
162 Levi L, Michaelson M, Admi H, Bregman D, Bar-Nahor R. National strategy for mass casualty situations and its effects on the hospital. Prehosp Disaster Med. Jan–Mar. 2002;17(1):12-6. [pmid: 12357558].
163 Levitin HW, Siegelson HJ, Dickinson S, Halpern P, Haraguchi Y, Nocera A, et al. Decontamination of mass casualties--re-evaluating existing dogma. Prehosp Disaster Med. Jul–Sep. 2003;18(3):200-7. [pmid: 15141859].
164 Lien O, Maldin B, Franco C, Gronvall GK. Getting medicine to millions: New strategies for mass distribution. Biosecur Bioterror. 2006;4(2):176-82. [pmid: 16792485].
165 Limehouse W, Foster R. Creating a standardized system for allocation of scarce clinical resources in response to an all hazards mass casualty disaster. J S C Med Assoc. Jun. 2011;107(3):70-3. [pmid: 22057706].
166 Linzer N, Sweifach J, Heft-LaPorte H. Triage and ethics: social workers on the front line. Journal of Human Behavior in the Social Environment. 2008;18(2):184-203.
167 Lipp M, Paschen H, Daubländer M, Bickel-Pettrup R, Dick W. Disaster management in hospitals. Current Anaesthesia and Critical Care. 1998;9(2):78-85.
168 Lokuge B, Drahos P, Neville W. Pandemics, antiviral stockpiles and biosecurity in Australia: what about the generic option?. Medical Journal of Australia. 2006;184(184):1.
169 Lowe CG. Pediatric prehospital medicine in mass casualty incidents. J Trauma. Aug. 2009;67(2 Suppl):S161-7. [pmid: 19667852].
170 MacDonald PDM, Nelson AL, Hightow-Weidman L, Leone PA. Disease intervention specialists as a resource in a public health emergency. Biosecurity and Bioterrorism: Biodefense Strategy, Practice and Science. 2007;5(3):239-48.
171 Mace SE, Sharieff G, Bern A, Benjamin L, Burbulys D, Johnson R, et al. Pediatric issues in disaster management, part 2: evacuation centers and family separation/reunification. Am J Disaster Med. May–Jun. 2010;5(3):149-61. [pmid: 20701172].
172 Mace SE, Sharieff G, Bern A, Benjamin L, Burbulys D, Johnson R, et al. Pediatric issues in disaster management, Part 1: the emergency medical system and surge capacity. Am J Disaster Med. Mar–Apr. 2010;5(2):83-93. [pmid: 20496641].
173 Macintyre AG, Christopher GW, Eitzen E Jr, Gum R, Weir S, DeAtley C, et al. Weapons of mass destruction events with contaminated casualties: effective planning for health care facilities. JAMA. Jan. 12. 2000;283(2):242-9. [pmid: 10634341].
174 Mack D. Team EMS. Clarifying EMS roles at mass casualty incidents. JEMS. Jul. 1999;24(7):36-43. [pmid: 10538557].
175 Mack D, Heightman AJ. Stay on the air. The importance of maintaining communication at mass casualty incidents. JEMS. Apr. 2002;27(4):42-9. [pmid: 11968571].
176 Maher C, Lushniak BD. Availability of medical countermeasures for bioterrorism events: US legal and regulatory options. Clinical Pharmacology and Therapeutics. 2009;85(6):669-71. [pmid: 19387435].
177 Manley WG, Furbee PM, Coben JH, Smyth SK, Summers DE, Althouse RC, et al. Realities of disaster preparedness in rural hospitals. Disaster Manag Response. Jul–Sep. 2006;4(3):80-7. [pmid: 16904618].
178 Manthous CA, Jackson WL Jr. The 9–11 commission’s invitation to imagine: a pathophysiology-based approach to critical care of nuclear explosion victims. Critical Care Medicine. 2007;35(3):716-23. [pmid: 17255868].
179 Markovitz BP. Pediatric critical care surge capacity. J Trauma. Aug. 2009;67(2 Suppl):S140-2. [pmid: 19667847].
180 Marti R, Robles S, Martin-Campillo A, Cucurull J. Providing early resource allocation during emergencies: The mobile triage tag. Journal of Network and Computer Applications. Nov. 2009;32(6):1167-82.
181 Matzo M, Ziegler FE, Ziegler AE. Palliative care considerations in disaster planning with scarce resources. Okla Nurse. Mar–May. 2009;54(1):11-2. quiz 3. [pmid: 19263950].
182 May T, Aulisio MP. Access to hospitals in the wake of terrorism: challenges and needs for maintaining public confidence. Disaster Manag Response. Jul–Sep. 2006;4(3):67-71. [pmid: 16904615].
183 McCabe OL, Kaminsky MJ, McHugh PR. Clinical assessment in disaster mental health: a logic of case formulation. Am J Disaster Med. Nov–Dec. 2007;2(6):297-306. [pmid: 18297950].
184 McCabe OL, Mosley AM, Gwon HS, Everly GS Jr, Lating JM, Links JM, et al. The tower of ivory meets the house of worship: psychological first aid training for the faith community. Int J Emerg Ment Health. Summer. 2007;9(3):171-80. [pmid: 18372659].
185 McCurdy NJ, Griswold WG, Lenert LA. RealityFlythrough: enhancing situational awareness for medical response to disasters using ubiquitous video. AMIA Annu Symp Proc. 2005:510-4. [pmid: 16779092].
186 McMahon MM. Fostering innovative use of disaster supplies. Disaster Manag Response. Jul-Sep. 2007;5(3):67. [pmid: 17719506].
187 Mehta S. Disaster and mass casualty management in a hospital: how well are we prepared?. J Postgrad Med. Apr–Jun. 2006;52(2):89-90. [pmid: 16679668].
188 Melnychuk RM, Kenny NP. Pandemic triage: the ethical challenge. Canadian Medical Association Journal. Nov. 2006;175(11):1393-4. [pmid: 17116907].
189 Mericka P, Hosek F. The importance of stored supplies of biological skin covers in territorial management of mass burn casualties. Acta Chir Plast. 2002;44(3):90-6. [pmid: 12514996].
190 Mezzetti MG. Triage: Military and civilian experience. Current Anaesthesia and Critical Care. 1998;9(2):48-51.
191 Milner SM, Rylah LT. War burns: a simplified resuscitation protocol. Br J Hosp Med. Aug. 18–31. 1993;50(4):163-7. [pmid: 8401892].
192 Milner SM, Rylah LT, Bennett JD. The Burn Wheel: a practical guide to fluid resuscitation. Burns. Jun. 1995;21(4):288-90. [pmid: 7662130].
193 Minnesota Department of Health. Patient care strategies for scarce resource situations. Available from http://www.health.state.mn.us/oep/healthcare/standards.pdf. 2008. Contract No.: Document Number|.
194 Miyamoto M, Sako M, Kimura M, Kanno T, Inoue M, Takeda H, et al. Great earthquakes and medical information systems, with special reference to telecommunications. J Am Med Inform Assoc. May–Jun. 1999;6(3):252-8. [pmid: 10332658].
195 Morse SS, Qureshi K, Gebbie EN, editors. Development of a public health surge capacity system from a pool of university health science campus employees. Abstract 69496. APHA 131st Annual Meeting. 2003 Nov 15–19. San Francisco, CA. Reference Mining.
196 Mozingo DW, Barillo DJ, Holcomb JB. The Pope Air Force Base aircraft crash and burn disaster. J Burn Care Rehabil. Mar–Apr. 2005;26(2):132-40. [pmid: 15756114].
197 Mrvos R, Piposzar JD, Stein TM, Locasto D, Krenzelok EP. Regional pharmaceutical preparation for biological and chemical terrorism. Journal of Toxicology - Clinical Toxicology. 2003;41(1):17-21. [pmid: 12645963].
198 NACCHO: National Association of County and City Health Officals, NACCHO-National Association of County & City Health Officials. Local health department guide to pandemic influenza planning : version 1.0. Washington, DC. NACCHO-National Association of County and City Health Officals. 2006. [cited RAND Library-NYAM.
199 Nager AL, Khanna K. Emergency department surge: models and practical implications. J Trauma. Aug. 2009;67(2 Suppl):S96-9. [pmid: 19667863].
200 Neuhaus P, Noack O, Majchrzak T, Ückert F, editors. Using a business rule management system to improve disposition of traumatized patients, Studies in health technology and informatics. 2010. Cape Town. SCOPUS.
201 Nocera A, Garner A. An Australian mass casualty incident triage system for the future based upon triage mistakes of the past: the Homebush Triage Standard. Aust N Z J Surg. Aug. 1999;69(8):603-8. [pmid: 10472920].
202 Ochsner MG, Harviel JD, Stafford PW, Blankenship C, Bosse MJ, Timberlake GA, et al. Development and organization for casualty management on a 1,000-bed hospital ship in the Persian Gulf. J Trauma. Apr. 1992;32(4):501-12. discussion 12–3. [pmid: 1569624].
203 O’Laughlin DT, Hick JL. Ethical issues in resource triage. Respir Care. Feb. 2008;53(2):190-7. discussion 7–200. [pmid: 18218150].
204 Omert L, Reynolds HN, Wiles CE. Continuous arteriovenous hemofiltration with dialysis (CAVH-D): an alternative to hemodialysis in the mass casualty situation. J Emerg Med. 1991;9(Suppl 1):51-6. [pmid: 1955683].
205 Padmanabhan N, Burstein F, Churilov L, Wassertheil J, Hornblower B, Parker N, editors. A mobile emergency triage decision support system evaluation. Proceedings of the Annual Hawaii International Conference on System Sciences. 2006. Kauai, HI. SCOPUS.
206 Palmer DA, Rao R, Lenert LA. An 802.11 wireless blood pulse-oximetry system for medical response to disasters. AMIA Annu Symp Proc. 2005;1072.
207 Paranthaman K, Conlon CP, Parker C, McCarthy N. Resource allocation during an influenza pandemic. Emerging Infectious Diseases. 2008;14(3):520-2. [pmid: 18325284].
208 Parker CL, Barnett DJ, Everly GS Jr, Links JM. Expanding disaster mental health response: a conceptual training framework for public health professionals. Int J Emerg Ment Health. Spring. 2006;8(2):101-9. [pmid: 16703848].
209 Partridge R, Alexander J, Lawrence T, Suner S. Medical counterbioterrorism: the response to provide anthrax prophylaxis to New York City US Postal Service employees. Ann Emerg Med. Apr. 2003;41(4):441-6. [pmid: 12658240].
210 Patrone D, Resnik D. Pandemic Ventilator Rationing and Appeals Processes. Health Care Analysis. Jun. 2011;19(2):165-79. [pmid: 20354793].
211 Paturas JL, Smith D, Smith S, Albanese J. Collective response to public health emergencies and large-scale disasters: putting hospitals at the core of community resilience. J Bus Contin Emer Plan. Jul. 2010;4(3):286-95. [pmid: 20826391].
212 Perry RW, Lindell MK. Hospital planning for weapons of mass destruction incidents. J Postgrad Med. Apr–Jun. 2006;52(2):116-20. [pmid: 16679675].
213 Perry RW, Lindell MK. Hospital planning for weapons of mass destruction incidents. J Healthc Prot Manage. 2007;23(1):27-39. [pmid: 17970447].
214 Pfeiffer J, Avery MD, Benbenek M, Prepas R, Summers L, Wachdorf CM, et al. Maternal and newborn care during disasters: thinking outside the hospital paradigm. Nurs Clin North Am. Sep. 2008;43(3):449-67. x. [pmid: 18674675].
215 Phin NF, Davies L. Resource allocation during an influenza pandemic. Emerging Infectious Diseases. 2008;14(10):1676. [pmid: 18826850].
216 Pinkert M, Bloch Y, Schwartz D, Ashkenazi I, Nakhleh B, Massad B, et al. Leadership as a component of crowd control in a hospital dealing with a mass-casualty incident: lessons learned from the October 2000 riots in Nazareth. Prehosp Disaster Med. Nov–Dec. 2007;22(6):522-6. [pmid: 18709941].
217 Potin M, Senechaud C, Carsin H, Fauville JP, Fortin JL, Kuenzi W, et al. Mass casualty incidents with multiple burn victims: rationale for a Swiss burn plan. Burns. Sep. 2010;36(6):741-50. [pmid: 20185244].
218 Powell T, Christ KC, Birkhead GS. Allocation of ventilators in a public health disaster. Disaster Med Public Health Prep. Mar. 2008;2(1):20-6. [pmid: 18388654].
219 Priest C, Bahl M. Nursing during catastrophic disaster: a case study from New Orleans. Journal of Nursing Law. 2008;12(4):157-64.
220 Qureshi K, Gershon RR, Sherman MF, Straub T, Gebbie E, McCollum M, et al. Health care workers’ ability and willingness to report to duty during catastrophic disasters. J Urban Health. Sep. 2005;82(3):378-88. [pmid: 16000654].
221 Rea ME, Gougelet RM, Nicolalde RJ, Geiling JA, Swartz HM. Proposed triage categories for large-scale radiation incidents using high-accuracy biodosimetry methods. Health Phys. Feb. 2010;98(2):136-44. [pmid: 20065675].
222 Rega PP, Bork CE, Burkholder-Allen K, Bisesi MS, Gold JP. Single-Breath-Count Test: an important adjunct in the triaging of patients in a mass-casualty incident due to botulism. Prehosp Disaster Med. May–Jun. 2010;25(3):219-22. [pmid: 20586014].
223 Reilly MJ, Markenson D. Utilizing paramedics for in-patient critical care surge capacity. Am J Disaster Med. May–Jun. 2010;5(3):163-8. [pmid: 20701173].
224 Ritz RH, Previtera JE. Oxygen supplies during a mass casualty situation. Respir Care. Feb. 2008;53(2):215-24. discussion 24–5. [pmid: 18218152].
225 Roberts AR. Applying Roberts’ Triple ABCD Model in the aftermath of crisis-inducing and trauma-inducing community disasters. Int J Emerg Ment Health. Summer. 2006;8(3):175-82. [pmid: 16944790].
226 Rosenfeld JV, Fitzgerald M, Kossmann T, Pearce A, Joseph A, Tan G, et al. Is the Australian hospital system adequately prepared for terrorism?. Med J Aust. Dec. 5–19. 2005;183(11–12):567-70. [pmid: 16336131].
227 Rothstein MA. Should Health Care Providers Get Treatment Priority in an Influenza Pandemic?. Journal of Law Medicine & Ethics. Sum. 2010;38(2):412-9.
228 Rubinson L, Christian MD. Allocating mechanical ventilators during mass respiratory failure: Kudos to New York State, but more work to be done. Disaster Med Public Health Prep. Mar. 2008;2(1):7-10. [pmid: 18388649].
229 Saghafinia M, Araghizade H, Nafissi N, Asadollahi R. Treatment management in disaster: a review of the Bam earthquake experience. Prehosp Disaster Med. Nov–Dec. 2007;22(6):517-21. [pmid: 18709940].
230 Sasser S. Field triage in disasters. Prehosp Emerg Care. Jul–Sep. 2006;10(3):322-3. [pmid: 16801271].
231 Scarfone RJ, Sullivan FJ, Henretig FM. Decontamination and the use of personal protective equipment. Pediatric Emergency Care. 2006;22(6):445-55. [pmid: 16801850].
232 Schneider CP, McDonald MD. “The king of terrors” revisited: the smallpox vaccination campaign and its lessons for future biopreparedness. J Law Med Ethics. Winter. 2003;31(4):580-9. [pmid: 14968660].
233 Schultz CH, Koenig KL. State of research in high-consequence hospital surge capacity. Acad Emerg Med. Nov. 2006;13(11):1153-6. [pmid: 16946288].
234 Selgelid MJ, Bennett B, Gostin L, Magnusson R, Martin R. Pandethics. Public Health. [Journal article]. 2009;123(3):255-9. [pmid: 19223051].
235 Shalev AY. The role of mental health professionals in mass casualty events. Isr J Psychiatry Relat Sci. 1994;31(4):243-5. [pmid: 7875947].
236 Shapira SC, Shemer J. Medical management of terrorist attacks. Israel Medical Association Journal. 2002;4(7):489-92. [pmid: 12120456].
237 Sheeley ME, Mahoney N. A new reality: mass casualty teams. Nurs Manage. Apr. 2007;38(4):40A-B. D, F, passim. [pmid: 17293774].
238 Shih FY, Koenig KL. Improving surge capacity for biothreats: experience from Taiwan. Acad Emerg Med. Nov. 2006;13(11):1114-7. [pmid: 17015413].
239 Shoemaker WC, Kvetan V, Fyodorov V, Kram HB. Clinical algorithm for initial fluid resuscitation in disasters. Crit Care Clin. Apr. 1991;7(2):363-81. [pmid: 2049644].
240 Simmons S, Alverson D, Poropatich R, D’Iorio J, DeVany M, Doarn CR. Applying telehealth in natural and anthropogenic disasters. Telemed J E Health. Nov. 2008;14(9):968-71. [pmid: 19035809].
241 Smith E, Morgans A, Biggs J, Buchanan R. Managing health information during disasters: a survey of Victorian hospitals’ current specialised health information systems. HIM J. 2007;36(1):23-9. [pmid: 18195394].
242 Sprung CL, Kesecioglu J. Essential equipment, pharmaceuticals and supplies. Intensive Care Medicine. Apr. 2010;36:S38-S44. [pmid: 20213420].
243 Staudenmayer K, Schecter WP. Civilian hospital response to mass casualty events: basic principles. Bulletin of the American College of Surgeons. 2007;92(8):16-20. [pmid: 17715580].
244 Stein LNM. Scarce resource situations. Oklahoma Nurse. 2010;55(2):7.
245 Sternberg E, Lee GC. New York City’s healthcare transportation during a disaster: a preparedness framework for a wicked problem. Prehosp Disaster Med. Mar–Apr. 2009;24(2):95-107. [pmid: 19591302].
246 Story C. Preplanning for an MCI (mass casualty incident). JEMS. Nov. 1993;18(11):52-7. 60. 2. 3. [pmid: 10129833].
247 Streger MR. Mass casualty and disaster communications. Emerg Med Serv. Apr. 1999;28(4):59-62. [pmid: 10351461].
248 Swartz HM, Flood AB, Gougelet RM, Rea ME, Nicolalde RJ, Williams BB. A critical assessment of biodosimetry methods for large-scale incidents. Health Phys. Feb. 2010;98(2):95-108. [pmid: 20065671].
249 Tabatabaie M, Ardalan A, Abolghasemi H, Naieni KH, Pourmalek F, Ahmadi B, et al. Estimating blood transfusion requirements in preparation for a major earthquake: the Tehran, Iran study. Prehospital and Disaster Medicine. 2010;25.
250 Tabery J, Mackett CW III. Ethics of triage in the event of an influenza pandemic. Disaster Medicine and Public Health Preparedness. 2008;2(2):114-8. [pmid: 18525374].
251 Talving P, Dubose J, Barmparas G, Inaba K, Demetriades D. Role of selective management of penetrating injuries in mass casualty incidents. European Journal of Trauma and Emergency Surgery. 2009;35(3):225-39.
252 Thomas CW, Vanderford ML, Crouse Quinn S. Evaluating emergency risk communications: a dialogue with the experts. Health Promot Pract. Oct. 2008;9(4 Suppl):5S-12S. [pmid: 18936254].
253 Thompson AK, Faith K, Gibson JL, Upshur RE. Pandemic influenza preparedness: an ethical framework to guide decision-making. BMC Med Ethics. 2006;7:E12. [pmid: 17144926].
254 Toner E, Waldhorn R, Franco C. A national disaster medical system for the 21st century. Biosecur Bioterror. Sep. 2007;5(3):192-3. [pmid: 17903087].
255 Toner E, Waldhorn R, Franco C, Courtney B, Rambbhla K, Norwood A, et al. Hospitals Rising to the Challenge: The First Five Years of the US Hospital Preparedness Program and Priorities Going Forward: Prepared by the Center for Biosecurity of UPMC for the U.S. Department of Health and Human Services under Contract No. HHSO100200700038C. 200 Contract No.: Document Number|.
256 Trust for America’s Health Preparing for potential health emergencies and bioterrorism attacks. [electronic resource]. Washington, DC. Trust for America’s Health. 2010. [cited RAND Library-NYAM.
257 United States Agency for Healthcare Research and Quality. The role of information technology and surveillance systems in bioterrorism readiness. Rockville, M.D. Agency for Healthcare Research and Quality. 2005. [cited RAND Library-NYAM.
258 United States Agency for Healthcare Research and Quality, Health Systems Research I. Nursing homes in public health emergencies : special needs and potential roles. Rockville, MD (540 Gaither Road, Rockville 20850). Agency for Healthcare Research and Quality, U.S. Dept. of Health and Human Services. 2005. [cited RAND Library-NYAM.
259 Vandenberg V, Amara R, Crabtree J, Fruhwirth K, Rifenburg J, Garner W. Burn Surge for Los Angeles County, California. Journal of Trauma-Injury Infection and Critical Care. Aug. 2009;67(2):S143-S6.
260 Vaughan W. Mass-casualty exercise design for EMS agencies. Emerg Med Serv. Aug. 2004;33(8):59-63. [pmid: 15368975].
261 Veenema TG, Toke J. When standards of care change in mass-casualty events. Am J Nurs. Sep. 2007;107(9):72A-H.
262 Walz BJ, Bissell RA, Maguire B, Judge JA 2nd. Vaccine administration by paramedics: a model for bioterrorism and disaster response preparation. Prehosp Disaster Med. Oct–Dec. 2003;18(4):321-6. [pmid: 15310044].
263 Ward MJ. Attack on the Pentagon. The initial fire & EMS response. JEMS. Apr. 2002;27(4):22-30. 2. 4. [pmid: 11968569].
264 Wheeler DS, Poss WB. Mass casualty management in a changing world. Pediatr Ann. Feb. 2003;32(2):98-105. [pmid: 12616933].
265 Wiederhold BK. Use VR handhelds in mass casualty disasters. Cyberpsychol Behav Soc Netw. Feb. 2010;13(1):119-20. [pmid: 20528302].
266 Wilgis J. Strategies for providing mechanical ventilation in a mass casualty incident: distribution versus stockpiling. Respir Care. Jan. 2008;53(1):96-100. discussion -3. [pmid: 18173864].
267 Wilkens EP, Klein GM. Mechanical ventilation in disaster situations: a new paradigm using the AGILITIES Score System. American journal of disaster medicine. 2010;5(6):369-84. [pmid: 21319555].
268 Wilkerson W, Avstreih D, Gruppen L, Beier KP, Woolliscroft J. Using immersive simulation for training first responders for mass casualty incidents. Acad Emerg Med. Nov. 2008;15(11):1152-9. [pmid: 18976333].
269 Wilkinson D. Dealing with at-risk populations in radiological/nuclear emergencies. Radiat Prot Dosimetry. 2009;134(3–4):136-42. [pmid: 19414481].
270 Wise RA. The creation of emergency health care standards for catastrophic events. Acad Emerg Med. Nov. 2006;13(11):1150-2. [pmid: 17015416].
271 Wormuth CE, Witkowsky A. Center for Strategic and International Studies (Washington, DC. Managing the next domestic catastrophe : ready (or not)? : a beyond Goldwater-Nichols Phase 4 report. Washington, D.C. Center for Strategic and International Studies. 2008. [cited RAND Library-NYAM.
272 Yellowlees P, Burke MM, Marks SL, Hilty DM, Shore JH. Emergency telepsychiatry. J Telemed Telecare. 2008;14(6):277-81. [pmid: 18776070].
273 Yin H, He H, Arbon P, Zhu J, Tan J, Zhang L. Optimal qualifications, staffing and scope of practice for first responder nurses in disaster. J Clin Nurs. 2011. Sep. 19.
274 Young D. CDC. briefs communities about mass dispensing. Am J Health Syst Pharm. Aug. 1. 2004;61(15):1541-6. [pmid: 15372823].
275 Zane RD, Biddinger P, Ide L, Phillips S, Hurd D, Buatti L, et al. Use of “shuttered” hospitals to expand surge capacity. Prehosp Disaster Med. Mar–Apr. 2008;23(2):121-7. [pmid: 18557291].
276 Zilm F, Berry R, Pietrzak MP, Paratore A. Integrating disaster preparedness and surge capacity in emergency facility planning. J Ambul Care Manage. Oct–Dec. 2008;31(4):377-85. [pmid: 18806597].
277 Zimmerman RK. Rationing of influenza vaccine during a pandemic: Ethical analyses. Vaccine. Mar. 2007;25(11):2019-26. [pmid: 17258359].

### Was not based on adequate consensus for KQ4 (N=17)

1 Developing practical emergency management education programs. Jt Comm Perspect. Dec. 2001;21(12):3.
2 National Conference prepares first receivers for mass casualty incidents. Healthc Hazard Manage Monit. Jan. 2006;19(5):1-7.
3 Albores P, Shaw D. Government preparedness: Using simulation to prepare for a terrorist attack. Computers & Operations Research. Jun. 2008;35(6):1924-43.
4 Culley JM, Effken JA. Development and validation of a mass casualty conceptual model. J Nurs Scholarsh. Mar. 2010;42(1):66-75. [pmid: 20487188].
5 Drenkard K, Rigotti G, Hanfling D, Fahlgren TL, LaFrancois G. Healthcare system disaster preparedness, part 1: readiness planning. J Nurs Adm. Sep. 2002;32(9):461-9. [pmid: 12360118].
6 Henderson DK, Malanoski MP, Corapi G, Passamani E, Notobartolo C, Gillette C, et al. Bethesda hospitals’ emergency preparedness partnership: A model for transinstitutional collaboration of emergency responses. Disaster Medicine and Public Health Preparedness. 2009;3(3):168-73. [pmid: 19834325].
7 Hewitt AM, Spencer SS, Ramloll R, Trotta H. Expanding CERC beyond public health: sharing best practices with healthcare managers via virtual learning. Health Promotion Practice. [Journal article]. 2008;9(4 suppl):83S-7S. [pmid: 18936263].
8 Hotz ME, Fliedner TM, Meineke V. Radiation accident preparedness: a European approach to train physicians to manage mass radiation casualties. Health Phys. Jun. 2010;98(6):894-7. [pmid: 20445401].
9 Houser SH, Houser HW. Are we preparing health services administration students to respond to bioterrorism and mass casualty management?. J Health Adm Educ. Spring. 2006;23(2):169-80. [pmid: 16700442].
10 Keil M. H5N1 influenza pandemic planning: Should medical students be left out?. Clinical Teacher. 2007;4(3):124-7.
11 Kobayashi L, Shapiro MJ, Suner S, Williams KA. Disaster medicine: the potential role of high fidelity medical simulation for mass casualty incident training. Med Health R I. Jul. 2003;86(7):196-200. [pmid: 12973894].
12 Natarajan S, Ganz A. Distributed visual analytics for collaborative emergency response management. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:1714-7. [pmid: 19964012].
13 Parrish AR, Oliver S, Jenkins D, Ruscio B, Green JB, Colenda C. A short medical school course on responding to bioterrorism and other disasters. Acad Med. Sep. 2005;80(9):820-3. [pmid: 16123460].
14 Phua YS, Miller JD, Wong She RB. Total care requirements of burn patients: Implications for a disaster management plan. Journal of Burn Care and Research. 2010;31(6):935-41. [pmid: 21105290].
15 Polivka BJ, Stanley SA, Gordon D, Taulbee K, Kieffer G, McCorkle SM. Public health nursing competencies for public health surge events. Public Health Nurs. Mar–Apr. 2008;25(2):159-65. [pmid: 18294184].
16 Schreiber S, Yoeli N, Paz G, Barbash GI, Varssano D, Fertel N, et al. Hospital preparedness for possible nonconventional casualties: an Israeli experience. Gen Hosp Psychiatry. Sep–Oct. 2004;26(5):359-66. [pmid: 15474635].
17 Stevens G, Jones A, Smith G, Nelson J, Agho K, Taylor M, et al. Determinants of paramedic response readiness for CBRNE threats. Biosecur Bioterror. Jun. 2010;8(2):193-202. [pmid: 20569060].

## Long Form Rejects

### Insufficient Evidence for KQ1 Tested Strategies (N=22)

1 Barillo DJ, Jordan MH, Jocz RJ, Nye D, Cancio LC, Holcomb JB. Tracking the daily availability of burn beds for national emergencies. J Burn Care Rehabil. Mar–Apr. 2005;26(2):174-82. [pmid: 15756121].
2 Beaton RD, Oberle MW, Wicklund J, Stevermer A, Boase J, Owens D. Evaluation of the Washington State National Pharmaceutical Stockpile dispensing exercise: Part I--Patient volunteer findings. J Public Health Manag Pract. Sep–Oct. 2003;9(5):368-76. [pmid: 15503601].
3 Beaton RD, Stevermer A, Wicklund J, Owens D, Boase J, Oberle MW. Evaluation of the Washington State National Pharmaceutical Stockpile dispensing exercise, part II--dispensary site worker findings. J Public Health Manag Pract. Jan–Feb. 2004;10(1):77-85. [pmid: 15018345].
4 Chaignat CL, Monti V, Soepardi J, Petersen G, Sorensen E, Narain J, et al. Cholera in disasters: do vaccines prompt new hopes?. Expert Rev Vaccines. May. 2008;7(4):431-5. [pmid: 18444890].
5 Currier M, King DS, Wofford MR, Daniel BJ, Deshazo R. A Katrina experience: lessons learned. Am J Med. Nov. 2006;119(11):986-92. [pmid: 17071168].
6 de Ville de Goyet C. Health lessons learned from the recent earthquakes and Tsunami in Asia. Prehosp Disaster Med. Jan–Feb. 2007;22(1):15-21. [pmid: 17484358].
7 Franco C, Toner E, Waldhorn R, Maldin B, O’Toole T, Inglesby TV. Systemic collapse: Medical care in the aftermath of Hurricane Katrina. Biosecurity and Bioterrorism. 2006;4(2):135-46. [pmid: 16792481].
8 Franco C, Toner E, Waldhorn R, Maldin B, O’Toole T, Inglesby TV. Mutual aid agreements: essential legal tools for public health preparedness and response. Am J Public Health. Apr. 2007;97(Suppl 1):S62-8. [pmid: 17413085].
9 Gavagan TF, Smart K, Palacio H, Dyer C, Greenberg S, Sirbaugh P, et al. Hurricane Katrina: Medical response at the Houston astrodome/reliant center complex. Southern Medical Journal. Sep. 2006;99(9):933-9. [pmid: 17004527].
10 Heightman AJ. Katrina exposes known weaknesses. JEMS. Oct. 2005;30(10):12.
11 Huang CM, Chan E, Hyder AA. Web 2.0 and internet social networking: a new tool for disaster management?--lessons from Taiwan. BMC Med Inform Decis Mak. 2010;10:57. [pmid: 20925944].
12 Kavita K, Lee A, Pong Y. Emerging victorious against an outbreak: integrated communication management of SARS in Singapore media coverage and impact of the SARS campaign in moving a nation to be socially responsible. Journal of Creative Communications. [Journal article]. 2007;2(3):383-403.
13 Leiba A, Schwartz D, Eran T, Blumenfeld A, Laor D, Goldberg A, et al. DISAST-CIR: Disastrous incidents systematic analysis through components, interactions and results: application to a large-scale train accident. J Emerg Med. Jul. 2009;37(1):46-50. [pmid: 18024063].
14 Lifshitz I, Adler J, Katz J. Model for preparedness of a public institution for a terrorist attack. Prehosp Disaster Med. Sep–Oct. 2008;23(5):467-71. [pmid: 19189617].
15 Marres G, Bemelman M, van der Eijk J, Leenen L. Major Incident Hospital: Development of a Permanent Facility for Management of Incident Casualties. European Journal of Trauma and Emergency Surgery. Jun. 2009;35(3):203-11.
16 Riederer-Trainor C, Wilkinson T, Snook WD, Hoff GL, Griffin R, Archer R. When bioterrorism strikes: communication issues for the local health department. Health Promot Pract. Oct. 2005;6(4):424-9. [pmid: 16210684].
17 Rozeman PA, Mayeaux EJ Jr. Hurricanes Katrina and Rita: evacuee healthcare efforts remote from hurricane affected areas. South Med J. Dec. 2006;99(12):1329-33. [pmid: 17233188].
18 Shemer J, Heller O, Danon YL. Civilian-military health services contingency program for a mass casualty situation and wartime in Israel. Isr J Med Sci. Nov-Dec. 1991;27(11–12):613-5. [pmid: 1757232].
19 Turegano-Fuentes F, Perez-Diaz D, Sanz-Sanchez M, Alonso JO. Overall Asessment of the Response to Terrorist Bombings in Trains, Madrid, 11 March 2004. European Journal of Trauma and Emergency Surgery. Oct. 2008;34(5):433-41.
20 Weeramanthri TS, Robertson AG, Dowse GK, Effler PV, Leclercq MG, Burtenshaw JD, et al. Response to pandemic (H1N1) 2009 influenza in Australia - lessons from a State health department perspective. Aust Health Rev. Nov. 2010;34(4):477-86. [pmid: 21108910].
21 Weinstock DM, Case C Jr, Bader JL, Chao NJ, Coleman CN, Hatchett RJ, et al. Radiologic and nuclear events: contingency planning for hematologists/oncologists. Blood. Jun. 15. 2008;111(12):5440-5. [pmid: 18287516].
22 Yamada S, Gunatilake RP, Roytman TM, Gunatilake S, Fernando T, Fernando L. The Sri Lanka tsunami experience. Disaster Manag Response. Apr–Jun. 2006;4(2):38-48. [pmid: 16580983].

### Insufficient Evidence for KQ2 Tested Strategies (N=106)

1 Almogy G, Rivkind AI. Surgical lessons learned from suicide bombing attacks. Journal of the American College of Surgeons. 2006;202(2):313-9. [pmid: 16427558].
2 Armstrong JH, Frykberg ER. Lessons from the response to the Virginia Tech shootings. Disaster Medicine and Public Health Preparedness. 2007;1(1 Suppl):S7-8. [pmid: 18388621].
3 Assa A, Landau DA, Barenboim E, Goldstein L. Role of air-medical evacuation in mass-casualty incidents - a train collision experience. Prehospital and Disaster Medicine. 2009;24(3):271-6. [pmid: 19618366].
4 Assa A, Landau DA, Barenboim E, Goldstein L. Role of air-medical evacuation in mass-casualty incidents--a train collision experience. Prehospital and disaster medicine : the official journal of the National Association of EMS Physicians and the World Association for Emergency and Disaster Medicine in association with the Acute Care Foundation. 2009;24(3):271-6.
5 Avitzour M, Libergal M, Assaf J, Adler J, Beyth S, Mosheiff R, et al. A multicasualty event: Out-of-hospital and in-hospital organizational aspects. Academic Emergency Medicine. 2004;11(10):1102-4. [pmid: 15466156].
6 Banner G. The Rhode Island Medical Emergency Distribution System (MEDS). Disaster Manag Response. Apr–Jun. 2004;2(2):53-7. [pmid: 15133456].
7 Bar-El Y, Michaelson M, Hyames G, Skorecki K, Reisner SA, Beyar R. An academic medical center under prolonged rocket attack--organizational, medical, and financial considerations. Acad Med. Sep. 2009;84(9):1203-10. [pmid: 19707058].
8 Bar-Joseph G, Michaelson M, Halberthal M. Managing mass casualties. Curr Opin Anaesthesiol. Apr. 2003;16(2):193-9. [pmid: 17021459].
9 Barthel ER, Pierce JR, Goodhue CJ, Ford HR, Grikscheit TC, Upperman JS. Availability of a pediatric trauma center in a disaster surge decreases triage time of the pediatric surge population: a population kinetics model. Theor Biol Med Model. Oct. 12. 2011;8(1):38. [pmid: 21992575].
10 Bascetta CA. United States Government Accountability Office. Disaster preparedness : preliminary observations on the evacuation of hospitals and nursing homes due to hurricanes : [letter to] congressional committees. Washington, D.C. United States Government Accountability Office. 2006. [cited RAND Library-NYAM.
11 Behney A, Breit M, Phillips C. Pediatric mass casualty: are you ready?. J Emerg Nurs. Jun. 2006;32(3):241-5. [pmid: 16730279].
12 Bemelman M, Leenen L. Mass Casualty Event During a Musical Parade: Lessons Learned. European Journal of Trauma and Emergency Surgery. Oct. 2008;34(5):451-6.
13 Bland SA, Lockey DJ, Davies GE, Kehoe AD. Military perspective on the civilian response to the London bombings July 2005. J R Army Med Corps. Mar. 2006;152(1):13-6. [pmid: 16749464].
14 Blank S, Moskin LC, Zucker JR. An ounce of prevention is a ton of work: mass antibiotic prophylaxis for anthrax, New York City, 2001. Emerg Infect Dis. Jun. 2003;9(6):615-22. [pmid: 12780998].
15 Buck DA, Trainor JE, Aguirre BE. A critical evaluation of the incident command system and NIMS. Journal of Homeland Security and Emergency Management. 2006;3(3).
16 Cairns BA, Stiffler A, Price F, Peck MD, Meyer AA. Managing a combined burn trauma disaster in the post-9/11 world: Lessons learned from the 2003 West Pharmaceutical plant explosion. Journal of Burn Care and Rehabilitation. 2005;26(2):144-50. [pmid: 15756116].
17 Cameron PA, Mitra B, Fitzgerald M, Scheinkestel CD, Stripp A, Batey C, et al. Black Saturday: the immediate impact of the February 2009 bushfires in Victoria, Australia. Medical Journal of Australia. Jul. 2009;191(1):11-6. [pmid: 19580529].
18 Cancio LC. Airplane crash in Guam, August 6, 1997: The aeromedical evacuation response. Journal of Burn Care and Research. 2006;27(5):642-8. [pmid: 16998396].
19 Carr C, Durrheim D, Eastwood K, Massey P, Jaggers D, Caelli M, et al. Australia’s first pandemic influenza mass vaccination clinic exercise: Hunter New England Area Health Service, NSW, Australia. Australian Journal of Emergency Management. 2011;26(1):47-53.
20 Carresi AL. The 2004 Madrid train bombings: An analysis of pre-hospital management. Disasters. 2008;32(1):41-65. [pmid: 18217917].
21 Cecchine G, Wermuth MA, Molander RC, McMahon KS, Malkin JD, Brower J, et al. Triage for civil support using military medical assets to respond to terrorist attacks. Santa Monica, CA. RAND Corporation. 2004. Contract No.: Document Number|.
22 Chai JK, Sheng ZY, Yang HM, Hao DF, Shen CA, Jia XM, et al. Treatment strategies for mass burn casualties. Chin Med J (Engl). Mar. 5. 2009;122(5):525-9. [pmid: 19323902].
23 Challen K, Walter D. Accelerated discharge of patients in the event of a major incident: observational study of a teaching hospital. BMC Public Health. 2006;6(108). 26. April. 2006.
24 Chan TC, Buono CJ, Killeen JP, Griswold WG, Huang R, Lenert L. Tablet computing for disaster scene managers. AMIA Annu Symp Proc. 2006;875.
25 Chavez CW, Binder B. A hospital as victim and responder: the Sepulveda VA Medical Center and the Northridge earthquake. J Emerg Med. Jul–Aug. 1996;14(4):445-54. [pmid: 8842918].
26 Chavez T, Cubano M, Hovijitra R. Mass casualty aboard USS Kitty Hawk (CV 63) January 2005--lessons learned. Mil Med. Jul. 2005;170(7):iii-vi. [pmid: 16130631].
27 Chen K. The role tabletop exercise using START in improving triage ability in disaster medical assistance team. Ann Disaster Med. 2003;1:79-83.
28 Corcoran SP, Niven AS, Reese JM. Critical Care Management of Major Disasters: A Practical Guide to Disaster Preparation in the Intensive Care Unit. J Intensive Care Med. 2011. Jan. 10.
29 Cyganik KA. Disaster preparedness in Virginia Hospital Center-Arlington after Sept 11, 2001. Disaster Management and Response. 2003;1(3):80-6. [pmid: 12888746].
30 Dann EJ, Bonstein L, Arbov L, Kornberg A, Rahimi-Levene N. Blood bank protocols for large-scale civilian casualty events: experience from terrorist bombing in Israel. Transfus Med. Apr. 2007;17(2):135-9. [pmid: 17430470].
31 Davis DP, Poste JC, Hicks T, Polk D, Rymer TE, Jacoby I. Hospital bed surge capacity in the event of a mass-casualty incident. Prehosp Disaster Med. May–Jun. 2005;20(3):169-76. [pmid: 16018505].
32 Distefano SM, Graf JM, Lowry AW, Sitler GC. Getting kids from the Big Easy hospitals to our place (not easy): preparing, improvising, and caring for children during mass transport after a disaster. Pediatrics. May. 2006;117(5 Pt 3):S421-7. [pmid: 16735277].
33 Drory M, Posen J, Vilner D, Ginzburg K, Lederman B. An Israeli model of a hospital emergency information center. Prehosp Disaster Med. Jan–Mar. 1999;14(1):13-6. [pmid: 10537593].
34 Ennis WJ. Disaster management, triage-based wound care, and patient safety: reflections on practice following an earthquake. Ostomy Wound Manage. Nov. 2010;56(11):61-9. [pmid: 21131698].
35 Ersoy N, Akpinar A. Triage decisions of emergency physicians in Kocaeli and the principle of justice. Ulus Travma Acil Cerrahi Derg. May. 2010;16(3):203-9. [pmid: 20517743].
36 Freishtat RJ, Wright JL, Holbrook PR. Issues in children’s hospital disaster preparedness. Clinical Pediatric Emergency Medicine. Dec. 2002;3(4):224-30.
37 Friedl HP, Trentz O, Hoffmann R, Kossmann T. Clinical care problems in mass casualties. Chirurg. 1991;62(4):239-42. [pmid: 1860349].
38 Gaudette R, Schnitzer J, George E, Briggs SM. Lessons learned from the September 11th World Trade Center disaster: Pharmacy preparedness and participation in an International Medical and Surgical Response Team. Pharmacotherapy. 2002;22(3 II):271-81. [pmid: 11898887].
39 Gautschi OP, Cadosch D, Rajan G, Zellweger R. Earthquakes and trauma: review of triage and injury-specific, immediate care. Prehosp Disaster Med. Mar–Apr. 2008;23(2):195-201. [pmid: 18557301].
40 Gebbie EN, Morse SS, Hanson H, McCollum MC, Reddy V, Gebbie KM, et al. Training for and maintaining public health surge capacity: a program for disease outbreak investigation by student volunteers. Public Health Rep. Jan–Feb. 2007;122(1):127-33. [pmid: 17236619].
41 Gebhart ME, Pence R. START Triage: Does It Work?. Disaster Management and Response. 2007;5(3):68-73. [pmid: 17719507].
42 Giovachino M, Calhoun T, Carey N, Coleman B, Gonzalez G, Hardeman B, et al. Optimizing a District of Columbia Strategic National Stockpile dispensing center. J Public Health Manag Pract. Jul–Aug. 2005;11(4):282-90. [pmid: 15958925].
43 Goans RE. A note on the number of survey stations required in a mass casualty radiation event. Health Phys. Dec. 2007;93(6):705-6. [pmid: 17993852].
44 Goh SH, Tiah L, Lim HC, Ng EK. Disaster preparedness: Experience from a smoke inhalation mass casualty incident. Eur J Emerg Med. Dec. 2006;13(6):330-4. [pmid: 17091053].
45 Gray BH, Hebert K. Urban Institute. After Katrina : hospitals in Hurricane Katrina, challenges facing custodial institutions in a disaster. Washington, DC. Urban Institute. 2006. [cited RAND Library-NYAM.
46 Grissom CK, Brown SM, Kuttler KG, Boltax JP, Jones J, Jephson AR, et al. A modified Sequential Organ Failure Assessment score for critical care triage. Disaster Medicine and Public Health Preparedness. 2010;4(4):277-84. [pmid: 21149228].
47 Guthrie E, Wells A, Pilgrim H, Mackway-Jones K, Minshull P, Pattinson S, et al. The Manchester bombing: providing a rational response. Journal of Mental Health. 1999;8(2):149-57.
48 Hadjiiski O, Dimitrov D. First aid and transportation of burned patients during mass disasters. Am J Emerg Med. Oct. 1996;14(6):613-4. [pmid: 8857818].
49 Harrington DT, Biffl WL, Cioffi WG. The station nightclub fire. Journal of Burn Care and Rehabilitation. 2005;26(2):141-3. [pmid: 15756115].
50 Hartel W, Steinmann R. The early care of severely injured people in mass casualties. Chirurg. 1991;62(4):233-8. [pmid: 1860348].
51 Hayden RT, Wick MT, Rodriguez AB, Caliendo AM, Mitchell MJ, Ginocchio CC. A survey-based assessment of United States clinical laboratory response to the 2009 H1N1 influenza outbreak. Archives of Pathology & Laboratory Medicine. 2010;134(11):1671-8. [pmid: 21043821].
52 Haynes BE, Freeman C, Rubin JL, Koehler GA, Enriquez SM, Smiley DR. Medical response to catastrophic events: California’s planning and the Loma Prieta earthquake. Annals of Emergency Medicine. 1992;21(4):368-74. [pmid: 1554172].
53 Ingrassia PL, Prato F, Geddo A, Colombo D, Tengattini M, Calligaro S, et al. Evaluation of medical management during a mass casualty incident exercise: an objective assessment tool to enhance direct observation. J Emerg Med. Nov. 2010;39(5):629-36. [pmid: 19570646].
54 Jacobs LM, Gabram SG, Stohler SA. The integration of a helicopter emergency medical service in a mass casualty response system. Prehosp Disaster Med. Oct–Dec. 1991;6(4):451-4. [pmid: 10148887].
55 Johnson LJ, Travis AR. Trauma response to the Asian tsunami: Krabi Hospital, Southern Thailand. Emerg Med Australas. Apr. 2006;18(2):196-8. [pmid: 16669946].
56 Kanter RK. Pediatric mass critical care in a pandemic. Pediatr Crit Care Med. 2010. Oct. 28.
57 Kanter RK, Moran JR. Pediatric hospital and intensive care unit capacity in regional disasters: expanding capacity by altering standards of care. Pediatrics. Jan. 2007;119(1):94-100. [pmid: 17200275].
58 Kelen GD, McCarthy ML, Kraus CK, Ding R, Hsu EB, Li G, et al. Creation of surge capacity by early discharge of hospitalized patients at low risk for untoward events. Disaster Med Public Health Prep. Jun. 2009;3(2 Suppl):S10-6. [pmid: 19349868].
59 Kizer KW, Cushing TS, Nishimi RY. The Department of Veterans Affairs’ role in Federal Emergency Management. Ann Emerg Med. Sep. 2000;36(3):255-61. [pmid: 10969234].
60 Klein JS, Weigelt JA. Disaster management. Lessons learned. Surg Clin North Am. Apr. 1991;71(2):257-66. [pmid: 2003249].
61 Kluger Y, Mayo A, Soffer D, Aladgem D, Halperin P. Functions and principles in the management of bombing mass casualty incidents: lessons learned at the Tel-Aviv Souraski Medical Center. Eur J Emerg Med. Dec. 2004;11(6):329-34. [pmid: 15542990].
62 Kopp JB, Ball LK, Cohen A, Kenney RJ, Lempert KD, Miller PE, et al. Kidney patient care in disasters: lessons from the hurricanes and earthquake of 2005. Clin J Am Soc Nephrol. Jul. 2007;2(4):814-24. [pmid: 17699499].
63 Kossmann T, Wittling I, Buhren V, Sutter G, Trentz O. Transferred triage to a level I trauma center in a mass catastrophe of patients; many of them with burns. Acta Chir Plast. 1991;33(3):145-50. [pmid: 1722600].
64 Kramer GC, Michell MW, Oliveira H, Brown TL, Herndon D, Baker RD, et al. Oral and enteral resuscitation of burn shock the historical record and implications for mass casualty care. Eplasty. 2010;10.
65 Larsen P. Emergency preparedness: the best defense for major disasters. J Healthc Mater Manage. Aug. 1991;9(7):19-20. 2. 4. 6. 8. [pmid: 10112142].
66 Lee WH, Chiu TF, Ng CJ, Chen JC. Emergency medical preparedness and response to a Singapore airliner crash. Acad Emerg Med. Mar. 2002;9(3):194-8. [pmid: 11874774].
67 Lee WH, Ghee C, Wu KH, Hung SC. Barriers to surge capacity of an overcrowded emergency department for a serious foodborne disease outbreak. Emerg Med J. Oct. 2010;27(10):779-83. [pmid: 20378747].
68 Leiba A, Goldberg A, Hourvitz A, Weiss G, Peres M, Karskass A, et al. Who should worry for the “worried well”? Analysis of mild casualties center drills in non-conventional scenarios. Prehosp Disaster Med. Nov–Dec. 2006;21(6):441-4. [pmid: 17334193].
69 Lim JH, Yoon D, Jung G, Kim WJ, Lee HCS. Medical needs of tsunami disaster refugee camps: Experience in southern Sri Lanka. Family Medicine. Jun. 2005;37(6):422-8. [pmid: 15933915].
70 Lynch AC, Koller T, Cocciardi JA. Creating isolation surge capacity. J Healthc Prot Manage. 2008;24(2):33-8. [pmid: 18800657].
71 Lynn M, Gurr D, Memon A, Kaliff J. Management of conventional mass casualty incidents: ten commandments for hospital planning. J Burn Care Res. Sep–Oct. 2006;27(5):649-58. [pmid: 16998397].
72 Ma B, Wei W, Xia ZF, Tang HT, Zhu SH, Wang Y, et al. Mass chemical burn casualty: Emergency management of 118 patients with alkali burn during a Matsa typhoon attack in Shanghai, China in 2005. Burns. Aug. 2007;33(5):565-71. [pmid: 17513055].
73 Massey T, Gao T, Welsh M, Sharp JH, Sarrafzadeh M. The design of a decentralized electronic triage system. AMIA Annu Symp Proc. 2006:544-8. [pmid: 17238400].
74 Mattox K, McSwain N, Frykberg E, Epley E, Mederos E, McDevitt S, et al. Position statement from the steering committee of the Atlantic-Gulf States Disaster Medical Coalition: integrated collaborative networks will facilitate mass casualty medical response. J Am Coll Surg. Oct. 2007;205(4):612-6. [pmid: 17903738].
75 McCunn M, Ashburn MA, Floyd TF, Schwab CW, Harrington P, Hanson CW 3rd, et al. An organized, comprehensive, and security-enabled strategic response to the Haiti earthquake: a description of pre-deployment readiness preparation and preliminary experience from an academic anesthesiology department with no preexisting international disaster response program. Anesth Analg. Dec. 2010;111(6):1438-44. [pmid: 20841417].
76 Meites E, Farias D, Raffo L, Albalak R, Carlino OL, McDonald LC, et al. Hospital capacity during an influenza pandemic-Buenos Aires, Argentina, 2009. Infect Control Hosp Epidemiol. Jan. 2011;32(1):87-90. [pmid: 21087127].
77 Meredith LS, Zazzali JL, Shields S, Eisenman DP, Alsabagh H. Psychological effects of patient surge in large-scale emergencies: a quality improvement tool for hospital and clinic capacity planning and response. Prehosp Disaster Med. Mar–Apr. 2010;25(2):107-14. [pmid: 20467987].
78 Nwadiaro HC, Yiltok SJ, Kidmas AT. Immediate mass casualty management in Jos University Teaching Hospital: a successful trial of Jos protocol. West Afr J Med. Jul–Sep. 2000;19(3):230-4. [pmid: 11126091].
79 O’Brien C, Selod S, Lamb KV. A national initiative to train long-term care staff for disaster response and recovery. J Public Health Manag Pract. Mar. 2009;15(2 Suppl):S20-4. [pmid: 19202396].
80 Okumura T, Suzuki K, Fukuda A, Kohama A, Takasu N, Ishimatsu S, et al. The Tokyo subway sarin attack: disaster management, Part 2: Hospital response. Acad Emerg Med. Jun. 1998;5(6):618-24. [pmid: 9660290].
81 O’Neill PA. The ABC’s of disaster response. Scand J Surg. 2005;94(4):259-66. [pmid: 16425620].
82 Paunksnis A, Barzdziukas V, Kurapkiene S, Vaicaitiene R, Sereika V. An assessment of telemedicine possibilities in massive casualties situations. Roczniki Akademii Medycznej w Białymstoku (1995). 2005;50:201-3. [pmid: 16358966].
83 Phillips FB, Williamson JP. Local health department applies incident management system for successful mass influenza clinics. J Public Health Manag Pract. Jul–Aug. 2005;11(4):269-73. [pmid: 15958923].
84 Pinkert M, Lehavi O, Goren OB, Raiter Y, Shamis A, Priel Z, et al. Primary triage, evacuation priorities, and rapid primary distribution between adjacent hospitals--lessons learned from a suicide bomber attack in downtown Tel-Aviv. Prehosp Disaster Med. Jul–Aug. 2008;23(4):337-41. [pmid: 18935948].
85 Pinkert M, Leiba A, Zaltsman E, Erez O, Blumenfeld A, Avinoam S, et al. The significance of a small, level-3 ‘semi evacuation’ hospital in a terrorist attack in a nearby town. Disasters. Sep. 2007;31(3):227-35. [pmid: 17714165].
86 Probst C, Hildebrand F, Gänsslen A, Krettek C, Adams HA. Hospital emergency response plan for mass casualty care. Der Notfallplan des Krankenhauses bei Massenanfall von Verletzten (MANV). 2008;45(1):40-50.
87 Ran Y, Hadad E, Daher S, Ganor O, Yegorov Y, Katzenell U, et al. Triage and Air Evacuation Strategy for Mass Casualty Events: A Model Based on Combat Experience. Military Medicine. Jun. 2011;176(6):647-51. [pmid: 21702381].
88 Ressel R, Reihart M, Brown S, Hinkle R, Wireback S, Gilger A. West Nickel Mines School shooting: how a rural MCI was successfully managed. JEMS. May. 2008;33(5):48-56. [pmid: 18482651].
89 Risavi BL, Salen PN, Heller MB, Arcona S. A two-hour intervention using START improves prehospital triage of mass casualty incidents. Prehosp Emerg Care. Apr–Jun. 2001;5(2):197-9. [pmid: 11339732].
90 Roccaforte JD, Cushman JG. Disaster preparedness, triage, and surge capacity for hospital definitive care areas: optimizing outcomes when demands exceed resources. Anesthesiol Clin. Mar. 2007;25(1):161-77. xi. [pmid: 17400163].
91 Roy N. The Asian Tsunami: PAHO disaster guidelines in action in India. Prehosp Disaster Med. Sep–Oct. 2006;21(5):310-5. [pmid: 17297900].
92 Schwartz D, Pinkert M, Leiba A, Oren M, Haspel J, Levi Y, et al. Significance of a Level-2, “selective, secondary evacuation” hospital during a peripheral town terrorist attack. Prehosp Disaster Med. Jan–Feb. 2007;22(1):59-66. [pmid: 17484365].
93 Sever MS, Vanholder R, Lameire N. Management of crush-related injuries after disasters. New England Journal of Medicine. [Journal article]. 2006;354(10):1052-63. [pmid: 16525142].
94 Shepherd J, Gerdes C, Nipper M, Naul LG. Are you ready?-lessons learned from the Fort Hood shooting in Texas. Emerg Radiol. 2010. Nov. 24.
95 Silenas R, Akins R, Parrish AR, Edwards JC. Developing disaster preparedness competence: an experiential learning exercise for multiprofessional education. Teach Learn Med. Jan–Mar. 2008;20(1):62-8. [pmid: 18444187].
96 Sosna J, Sella T, Shaham D, Shapira SC, Rivkind A, Bloom AI, et al. Facing the new threats of terrorism: radiologists’ perspectives based on experience in Israel. Radiology. Oct. 2005;237(1):28-36. [pmid: 16100082].
97 Stohler SA, Jacobs LM, Gabram SG. Roles of a helicopter emergency medical service in mass casualty incidents. J Air Med Transp. Jan. 1991;10(1):7-13.
98 Sztajnkrycer MD, Baez AA, Luke A. FAST ultrasound as an adjunct to triage using the START mass casualty triage system: a preliminary descriptive system. Prehosp Emerg Care. Jan–Mar. 2006;10(1):96-102. [pmid: 16418098].
99 Tay J, Ng YF, Cutter J, James L. Influenza A (H1N1–2009) Pandemic in Singapore - Public Health Control Measures Implemented and Lessons Learnt. Annals Academy of Medicine Singapore. Apr. 2010;39(4):313-24.
100 Timm N, Reeves S. A mass casualty incident involving children and chemical decontamination. Disaster Manag Response. Apr–Jun. 2007;5(2):49-55. [pmid: 17517363].
101 van Harten SM, Welling L, Perez RS, Patka P, Kreis RW. Management of multiple burn casualties from the Volendam disaster in the emergency departments of general hospitals. Eur J Emerg Med. Dec. 2005;12(6):270-4. [pmid: 16276255].
102 Vanholder R, Van Biesen W, Hoste E, van der Tol A, Sever MS. The role of the Renal Disaster Relief Task Force in the prevention and treatment of Crush syndrome in mass disasters. Acta Clin Belg Suppl. 2007;(2):405-7. [pmid: 18284010].
103 Villarreal MS. Quality management tool for mass casualty emergency responses and disasters. Prehosp Disaster Med. Jul–Sep. 1997;12(3):200-9. [pmid: 10187015].
104 Vincent DS, Berg BW, Ikegami K. Mass-casualty triage training for international healthcare workers in the Asia-Pacific region using manikin-based simulations. Prehosp Disaster Med. May–Jun. 2009;24(3):206-13. [pmid: 19618356].
105 Wolinsky PR, Tejwani NC, Testa NN, Zuckerman JD. Lessons learned from the activation of a disaster plan: 9/11. Journal of Bone and Joint Surgery - Series A. 2003;85(9):1844-6.
106 Xiang B, Cheng W, Liu J, Huang L, Li Y, Liu L. Triage of pediatric injuries after the 2008 Wen-Chuan earthquake in China. J Pediatr Surg. Dec. 2009;44(12):2273-7. [pmid: 20006008].

### Insufficient Evidence for KQ1 Proposed Strategies (N=8)

1 Bascetta CA. Veterans health care: VA’s medical support role in emergency preparedness. Washington, D.C. United States Government Accountability Office. 2005. [cited RAND Library-NYAM.
2 Bascetta CA. United States Congress.Senate.Committee on the Budget, United States Congress.Senate.Committee on Finance, United States Congress.House.Committee on Homeland Security, United States Congress.House.Committee on Oversight and Government Reform. Emergency preparedness : states are planning for medical surge, but could benefit from shared guidance for allocating scarce medical resources : report to congressional requesters. Washington, D.C. Government Accountability Office. 2008. [cited RAND Library-NYAM.
3 Carpenter M, Hodge JG Jr, Pepe RP. Deploying and using volunteer health practitioners in response to emergencies: proposed uniform state legislation provides liability protections and workers’ compensation coverage. Am J Disaster Med. Jan–Feb. 2008;3(1):17-23. [pmid: 18450275].
4 Conn R, Welch FJ, Popovich ML. Management of vaccine inventories as a critical health resource. IEEE Eng Med Biol Mag. Nov–Dec. 2008;27(6):61-5. [pmid: 19004697].
5 Eastman N, Philips B, Rhodes A. Triaging for adult critical care in the event of overwhelming need. Intensive Care Medicine. 2010;36(6):1076-82. [pmid: 20349037].
6 Hodge JG Jr, Gable LA, Calves SH. The legal framework for meeting surge capacity through the use of volunteer health professionals during public health emergencies and other disasters. J Contemp Health Law Policy. Fall. 2005;22(1):5-71. [pmid: 16680989].
7 Knebel A, Phillips SJ, Institute A. United States Agency for Healthcare Research and Quality., United States Dept. of Health and Human Services.Office of the Assistant Secretary for Preparedness and Response., Centers for Disease Control and Prevention (U.S.). Home health care during an influenza pandemic issues and resources. Rockville, MD. Agency for Healthcare Research and Quality. 2008. [cited RAND Library-NYAM.
8 WHO (World Health Organization). Project on addressing ethical issues in pandemic influenza planning: Equitable access to therapeutic and prophylactic measures. 2006. [updated 2006; cited 2009 September, 08]; Available from: http://www.who.int/eth/ethics/PIEthicsdraftpaperWG120oct06.pdf.

### Insufficient Evidence for KQ2 Proposed Strategies (N=70)

1 Best practices for hospital-based first receivers of victims from mass casualty incidents involving release of hazardous substances. [Washington.
2 Medical ethics in the event of disasters. Bull Med Ethics. Oct. 1994;(102):9-11. [pmid: 11654133].
3 Ethical considerations in the allocation of organs and other scarce medical resources among patients. Council on Ethical and Judicial Affairs, American Medical Association. Arch Intern Med. Jan. 9. 1995;155(1):29-40. [pmid: 7802518].
4 Special Issue: Definitive care for the critically ill during a disaster. Chest. 2008;133(5 supplement):1s-6-6s.
5 Ethical Considerations for Decision Making Regarding Allocation of Mechanical Ventilators during a Severe Influenza Pandemic or Other Public Health Emergency. Prepared by the Ventilator Document Workgroup for the Ethics Subcommittee of the Advisory Committee to the Director. 2009. Contract No.: Document Number|.
6 The next challenge in healthcare preparedness: catastrophic health events. Biosecur Bioterror. Mar. 2010;8(1):93-5. [pmid: 20230238].
7 A Regional Planning Guide for Maintaining Essential Health Services in a Scarce Resource Environment: Recommendations from Georgia Hospital Region F Essential Health Services Project: The Georgia Hospital Association Research and Eduation Foundation, Inc (GHAREF) in conjuction with the Medical Center of Central Georgia (MCCG) and Health Districts 4 and 52 with CDC funding for the Georgia Division of Emergency Preparedness-Georgia Department of Community Health. July. 30. 2010. Contract No.: Document Number|.
8 A Framework for Maintaining Essential Health Services in a Crises Care Environment: Recommendations from Georgia Hospital Region F Essential Health Services Project: The Georgia Hospital Association Research and Eduation Foundation, Inc (GHAREF) in conjuction with the Medical Center of Central Georgia (MCCG) and Health Districts 4 and 52 with CDC funding for the Georgia Division of Emergency Preparedness-Georgia Department of Community Health. July. 30. 2010. Contract No.: Document Number|.
9 We Stand On Guard for Thee: Ethical Considerations in Preparedness Planning for Pandemic Influenza. : A report of the University of Toronto Joint Centre for Bioethics Pandemic Influenza Working Group. November. 2005. Contract No.: Document Number|.
10 American Association for Respiratory Care. Guidelines for acquisition of ventilators to meet demands for pandemic flu and mass casualty incidents. 2008. [updated 2008; cited 2008 July 01]; Available from: http://www.aarc.org/resources/vent_guidelines.pdf.
11 American College of Emergency Physicians. Best Practices for Hospital Preparedness. April. 2009. Contract No.: Document Number|.
12 Ashkenazi I, Kessel B, Olsha O, Khashan T, Oren M, Haspel J, et al. Defining the problem, main objective, and strategies of medical management in mass-casualty incidents caused by terrorist events. Prehosp Disaster Med. Jan–Feb. 2008;23(1):82-9. [pmid: 18491667].
13 Barnett DJ, Taylor HA, Hodge JG Jr, Links JM. Resource allocation on the frontlines of public health preparedness and response: report of a summit on legal and ethical issues. Public Health Rep. Mar–Apr. 2009;124(2):295-303. [pmid: 19320372].
14 Barnitz L, Berkwits M. The health care response to pandemic influenza. Ann Intern Med. Jul. 18. 2006;145(2):135-7. [pmid: 16801625].
15 Ben-Abraham R, Shapira I, Kalmovich B, Rudick V, Weinbroum AA. Supraglottic devices: a possible role in prehospital toxic mass casualty event?. J Med. 2004;35(1–6):105-14. [pmid: 18084869].
16 Benjamin G, McGeary MGH, McCutchen SR. Institute of Medicine (U.S.). Committee on Medical Preparedness for a Terrorist Nuclear Event. Assessing medical preparedness to respond to a terrorist nuclear event workshop report. [electronic resource]. Washington, D.C. National Academies Press. 2009. [cited RAND Library-NYAM.
17 Bennett D, Jahankhani H. The UK Government’s Critical National Infrastructure Policy for Emergency Services Communications Platforms: Vulnerabilities in the TETRA Architecture. Jahankhani H, Hessami AG, Hsu F, editors. Global Security, Safety, and Sustainability, Proceedings. 2009:43-55.
18 Borra A, Perez LJ, Min T, Puavilai W, Seo N, Tipsunthonsak N. Panel 2.5: mass-casualty management and hospital care. Prehosp Disaster Med. Nov–Dec. 2005;20(6):412-3. [pmid: 16496625].
19 Boyer EW, Fitch J, Shannon M. Pediatric hospital surge capacity in public health emergencies. Pub. No. 09-0014. Rockville, MD. Agency for Healthcare Research and Quality, (AHRQ). 2009. Contract No.: Document Number|.
20 Chan TC, Killeen J, Griswold W, Lenert L. Information technology and emergency medical care during disasters. Acad Emerg Med. Nov. 2004;11(11):1229-36. [pmid: 15528589].
21 Christian MD, Hawryluck L, Wax RS, Cook T, Lazar NM, Herridge MS, et al. Development of a triage protocol for critical care during an influenza pandemic. Canadian Medical Association Journal. Nov. 2006;175(11):1377-81. [pmid: 17116904].
22 Coleman CN, Hrdina C, Bader JL, Norwood A, Hayhurst R, Forsha J, et al. Medical response to a radiologic/nuclear event: integrated plan from the Office of the Assistant Secretary for Preparedness and Response, Department of Health and Human Services. Ann Emerg Med. Feb. 2009;53(2):213-22. [pmid: 18387707].
23 Coleman CN, Weinstock DM, Casagrande R, Hick JL, Bader JL, Chang F, et al. Triage and treatment tools for use in a scarce resources-crisis standards of care setting after a nuclear detonation. Disaster Med Public Health Prep. Mar. 2011;5(Suppl 1):S111-21. [pmid: 21402803].
24 Cone DC, Koenig KL. Mass casualty triage in the chemical, biological, radiological, or nuclear environment. Eur J Emerg Med. Dec. 2005;12(6):287-302. [pmid: 16276260].
25 Crippen D, Krin C, Lorich D, Mattox K. Disaster medicine: the caring contradiction. Crit Care. 2010;14(2):133. [pmid: 20359314].
26 Crupi RS, Asnis DS, Lee CC, Santucci T, Marino MJ, Flanz BJ. Meeting the challenge of bioterrorism: lessons learned from West Nile virus and anthrax. Am J Emerg Med. Jan. 2003;21(1):77-9. [pmid: 12563588].
27 De Jong MJ, Benner R, Benner P, Richard ML, Kenny DJ, Kelley P, et al. Mass casualty care in an expeditionary environment: developing local knowledge and expertise in context. J Trauma Nurs. Jan–Mar. 2010;17(1):45-58. [pmid: 20234239].
28 DeBruin D, Parilla E, Liaschenko J, Leider JP, Brunnquell DJ, Garrett JE, et al. Implementing ethical frameworks for rationing scarce resources in Minnesota during severe influenza pandemic. 2010. Reference Mining; 2010.
29 Devereaux A, Christian MD, Dichter JR, Geiling JA, Rubinson L. Summary of suggestions from the Task Force for Mass Critical Care summit, January 26–27, 2007. Chest. May. 2008;133(5 Suppl):1S-7S. [pmid: 18460502].
30 Ferrer RR, Balasuriya D, Iverson E, Upperman JS. Pediatric disaster preparedness of a hospital network in a large metropolitan region. Am J Disaster Med. Jan–Feb. 2010;5(1):27-34. [pmid: 20349700].
31 Flynn DF, Goans RE. Nuclear terrorism: triage and medical management of radiation and combined-injury casualties. Surg Clin North Am. Jun. 2006;86(3):601-36. [pmid: 16781272].
32 Foltin G, Tunik M, Curran J, Marshall L, Bove J, van Amerongen R, et al. Pediatric nerve agent poisoning: medical and operational considerations for emergency medical services in a large American city. Pediatr Emerg Care. Apr. 2006;22(4):239-44. [pmid: 16651913].
33 Gomersall CD, Tai DYH, Loo S, Derrick JL, Goh M, Buckley TA, et al. Expanding ICU facilities in an epidemic: recommendations based on experience from the SARS epidemic in Hong Kong and Singapore. Intensive Care Medicine. 2006;32(7):1004-13. [pmid: 16570146].
34 Greenberg MI, Hendrickson RG. Report of the CIMERC/Drexel University Emergency Department Terrorism Preparedness Consensus Panel. Acad Emerg Med. Jul. 2003;10(7):783-8. [pmid: 12837654].
35 Hadef H, Bartier JC, Pelaccia T. SAGEC 67, a free-access database linking at least three countries, for finding spare beds in the event of a mass casualty incident. Eur J Emerg Med. Aug. 2009;16(4):183-7. [pmid: 19318965].
36 Hick JL, Christian MD, Sprung CL. Surge capacity and infrastructure considerations for mass critical care. Intensive Care Medicine. Apr. 2010;36:S11-S20. [pmid: 20213417].
37 Hick JL, Hanfling D, Burstein JL, DeAtley C, Barbisch D, Bogdan GM, et al. Health care facility and community strategies for patient care surge capacity. Ann Emerg Med. Sep. 2004;44(3):253-61. [pmid: 15332068].
38 Hick JL, Hanfling D, Cantrill SV. Allocating Scarce Resources in Disasters: Emergency Department Principles. Ann Emerg Med. 2011. Aug. 18.
39 Hick JL, O’Laughlin DT. Concept of operations for triage of mechanical ventilation in an epidemic. Acad Emerg Med. Feb. 2006;13(2):223-9. [pmid: 16400088].
40 Hoejenbos MJ, McManus J, Hodgetts T. Is there one optimal medical treatment and evacuation chain for all situations: “scoop-and-run” or “stay-and-play”. Prehosp Disaster Med. Jul-Aug. 2008;23(4):s74-8. [pmid: 18935964].
41 Hrdina CM, Coleman CN, Bogucki S, Bader JL, Hayhurst RE, Forsha JD, et al. The “RTR” medical response system for nuclear and radiological mass-casualty incidents: a functional TRiage-TRansport-treatment medical response model. Prehospital and Disaster Medicine. 2009;24(3):167-78. [pmid: 19618351].
42 Kanter RK, Cooper A. Mass critical care: pediatric considerations in extending and rationing care in public health emergencies. Disaster Med Public Health Prep. Dec. 2009;3(Suppl 2):S166-71. [pmid: 19794308].
43 Kirby J. Enhancing the fairness of pandemic critical care triage. J Med Ethics. Dec. 2010;36(12):758-61. [pmid: 20940175].
44 Kobrinskiy BA, Petlakh VI, Wootton R, Patil NG, Scott RE, Ho K. Telepaediatric support for a field hospital in Chechnya. Telehealth in the developing world. [Book chapter]. 2009:262-72.
45 Kopp JB, Ball LK, Cohen A, Kenney RJ, Lempert KD, Miller PE, et al. Kidney patient care in disasters: emergency planning for patients and dialysis facilities. Clin J Am Soc Nephrol. Jul. 2007;2(4):825-38. [pmid: 17699500].
46 Lang JL, Croker K. H1N1 09 influenza—An aeromedical perspective. Australasian Emergency Nursing Journal. 2010;13(3):53-60.
47 Leo JD, Thomas D, Alhadeff G. A unique hospital physician disaster response system for a nonemployed medical staff. Am J Disaster Med. Mar–Apr. 2009;4(2):95-100. [pmid: 19522126].
48 Lin JY, Anderson-Shaw L. Rationing of resources: ethical issues in disasters and epidemic situations. Prehosp Disaster Med. May–Jun. 2009;24(3):215-21. [pmid: 19618357].
49 Lowe CG. Pediatric and neonatal interfacility transport medicine after mass casualty incidents. J Trauma. Aug. 2009;67(2 Suppl):S168-71. [pmid: 19667853].
50 Mahoney EJ, Biffl WL, Cioffi WG. Mass-casualty incidents: how does an ICU prepare?. J Intensive Care Med. Jul–Aug. 2008;23(4):219-35. [pmid: 18504261].
51 Malish R, Oliver DE, Rush RM Jr, Zarzabal E, Sigmon MJ, Burkle FM Jr. Potential roles of military-specific response to natural disasters -- analysis of the rapid deployment of a mobile surgical team to the 2007 Peruvian earthquake. Prehosp Disaster Med. Jan–Feb. 2009;24(1):3-8. [pmid: 19557951].
52 Matzo M, Wilkinson A, Lynn J, Gatto M, Phillips S. Palliative care considerations in mass casualty events with scarce resources. Biosecur Bioterror. Jun. 2009;7(2):199-210. [pmid: 19635004].
53 Moser R Jr, Connelly C, Baker L, Barton R, Buttrey J, Morris S, et al. Development of a state medical surge plan, Part II: Components of a medical surge plan. Disaster Manag Response. Jan–Mar. 2006;4(1):19-24. [pmid: 16360636].
54 National Center for Injury Prevention and Control. Interim planning guidance for preparedness and response to a mass casualty event resulting from terrorist use of explosives. Atlanta, GA. Centers for Disease Control and Prevention. 2010. Contract No.: Document Number|.
55 Neal DJ, Barbera JA, Harrald JR. PLUS prehospital mass-casualty triage: a strategy for addressing unusual injury mechanisms. Prehosp Disaster Med. May–Jun. 2010;25(3):227-36. [pmid: 20586016].
56 New York State Workgroup on Ventilator Allocation in an Influenza Pandemic, New York State DOH/ NYS Task Force on Life & the Law. Allocation of Ventilators in an Influenza Pandemic: Planning Document, Draft for Public Comment. March. 15. 2007. Contract No.: Document Number|.
57 Pfenninger EG, Domres BD, Stahl W, Bauer A, Houser CM, Himmelseher S. Medical student disaster medicine education: the development of an educational resource. Int J Emerg Med. 2010;3(1):9-20. [pmid: 20414376].
58 Rice MJ, Gwertzman A, Finley T, Morey TE. Anesthetic practice in Haiti after the 2010 earthquake. Anesth Analg. Dec. 2010;111(6):1445-9. [pmid: 20889938].
59 Rubin GJ, Dickmann P. How to reduce the impact of “low-risk patients” following a bioterrorist incident: lessons from SARS, anthrax, and pneumonic plague. Biosecur Bioterror. Mar. 2010;8(1):37-43. [pmid: 20230231].
60 Saffle JR, Gibran N, Jordan M. Defining the ratio of outcomes to resources for triage of burn patients in mass casualties. Journal of Burn Care and Rehabilitation. 2005;26(6):478-82. [pmid: 16278561].
61 Scanlon J. Chemically contaminated casualties: different problems and possible solutions. Am J Disaster Med. Mar–Apr. 2010;5(2):95-105. [pmid: 20496642].
62 Sever MS, Kellum J, Hoste E, Vanholder R. Application of the RIFLE criteria in patients with crush-related acute kidney injury after mass disasters. Nephrol Dial Transplant. 2010. Jul. 19.
63 Shirley PJ, Mandersloot G. Clinical review: the role of the intensive care physician in mass casualty incidents: planning, organisation, and leadership. Crit Care. 2008;12(3):214. [pmid: 18492221].
64 Stratton SJ, Tyler RD. Characteristics of medical surge capacity demand for sudden-impact disasters. Acad Emerg Med. Nov. 2006;13(11):1193-7. [pmid: 16885401].
65 Taiminen T, Tuominen T, Strandberg J, Sourander A, Salokangas RK. Emergency psychiatric treatment of survivors of the Estonia disaster. Nord Med. 1995;110(2):62-4. [pmid: 7854915].
66 Temte JL. Preparing for an influenza pandemic: vaccine prioritization. Fam Pract Manag. Jan. 2006;13(1):32-4. [pmid: 16457462].
67 Viswanathan K, Wizemann T, Altevogt BM. Forum on Medical and Public Health Preparedness for Catastrophic Events. Institute of Medicine. 2011.
68 Wagner SK. Disaster preparedness. D.C. medical center unveils mass casualty design concepts. Hosp Health Netw. May. 2008;82(5):22. [pmid: 18557334].
69 Washington ML, Mason J, Meltzer MI. Maxi-Vac: planning mass smallpox vaccination clinics. J Public Health Manag Pract. Nov–Dec. 2005;11(6):542-9. [pmid: 16224290].
70 White DB, Katz MH, Luce JM, Lo B. Who should receive life support during a public health emergency? Using ethical principles to improve allocation decisions. Ann Intern Med. Jan. 20. 2009;150(2):132-8. [pmid: 19153413].

### Did not address resource allocations for KQ 3 (N=23)

1 Ambarish P, Nivedita P, Mansher S, Akshay S, Gayatri S. YouTube as a source of information on the H1N1 influenza pandemic. American Journal of Preventive Medicine. [Journal article]. 2010;38(3):e1-e3.
2 Andrulis DP, Siddiqui N, Purtle J. Drexel University SoPHCfHE. California’s emergency preparedness efforts for culturally diverse communities : status, challenges and directions for the future. Philadelphia, Pa. Drexel University School of Public Health. 2008. [cited RAND Library-NYAM.
3 Beaton RD, Oberle MW, Wicklund J, Stevermer A, Boase J, Owens D. Evaluation of the Washington State National Pharmaceutical Stockpile dispensing exercise: Part I--Patient volunteer findings. J Public Health Manag Pract. Sep–Oct. 2003;9(5):368-76. [pmid: 15503601].
4 Blando JD, Robertson C, Bresnitz E. Communicating information in an emergency preparedness pill distribution campaign. Biosecur Bioterror. Mar. 2008;6(1):57-65. [pmid: 18386973].
5 DeLia D, CCJ, Brownlee S, Abramo J. Rutgers Center for State Health Policy, Schulman R, & Bucuvalas (Firm). New Jersey Health Care Opinion Poll : public concern about hospital capacity. New Brunswick, NJ. Rutgers Center for State Health Policy. 2008. [cited RAND Library-NYAM.
6 Gullo K. Harris Interactive (Firm). Vast majorities of U.S. adults believe federal, state and local governments should have been better prepared to look after sick and frail residents in New Orleans in the wake of Hurricane Katrina. Rochester, N.Y. Harris Interactive Inc. 2005. [cited RAND Library-NYAM.
7 Guth D, Alloway GA. University of Kansas School of Journalism and Mass Communications. Untapped potential : evaluating state emergency management agency web sites 2008. Lawrence, KS. University of Kansas, School of Journalism and Mass Communications. 2008. [cited RAND Library-NYAM.
8 Henderson JN, Henderson LC, Raskob GE, Boatright DT. Chemical (VX) terrorist threat: public knowledge, attitudes, and responses. Biosecur Bioterror. 2004;2(3):224-8. [pmid: 15588061].
9 Lake Snell Perry and Associates, Robert Wood Johnson Foundation. Americans speak out on bioterrorism and U.S. preparedness to address risk. Princeton, N.J. Lake Snell Perry & Associates, Inc. 2002. [cited RAND Library-NYAM.
10 Lasker RD. Redefining readiness : terrorism planning through the eyes of the public: appendix to the study report. New York, NY. Center for the Advancement of Collaborative Strategies in Health, New York Academy of Medicine. 2004. [cited RAND Library-NYAM.
11 Lasker RD. Center for the Advancement of Collaborative Strategies in Health, New York Academy of Medicine. With the public’s knowledge : a user’s guide to the Redefining Readiness small group discussion process. New York, NY. New York Academy of Medicine. 2009. [cited RAND Library-NYAM.
12 Lasker RD. New York Academy of Medicine Center for the Advancement of Collaborative Strategies in Health. Redefining readiness: terrorism planning through the eyes of the public. New York, NY. Center for the Advancement of Collaborative Strategies in Health, New York Academy of Medicine. 2004. [cited RAND Library-NYAM.
13 Mathew AB, Kelly K. Tomás Rivera Policy Institute, Asian Pacific American Legal Center of Southern California. Disaster preparedness in urban immigrant communities : lessons learned from recent catastrophic events and their relevance to Latino and Asian Communities in Southern California Los Angeles, California Tomás Rivera Policy Institute. 2008. [cited RAND Library-NYAM.
14 May AL. Aspen Institute. First informers in the disaster zone : the lessons of Katrina. Washington, DC. Aspen Institute. 2006. [cited RAND Library-NYAM.
15 McGough M, Frank LL, Tipton S, Tinker TL, Vaughan E. Communicating the risks of bioterrorism and other emergencies in a diverse society: a case study of special populations in North Dakota. Biosecurity and Bioterrorism: Biodefense Strategy, Practice and Science. 2005;3(3):235-45.
16 Mullin S. New York City’s communication trials by fire, from West Nile to SARS. Biosecurity and Bioterrorism: Biodefense Strategy, Practice and Science. [Journal article]. 2003;1(4):267-72.
17 National Council on Disability (US). Effective emergency management : making improvements for communities and people with disabilities. Washington, D.C. National Council on Disability. 2009. [cited RAND Library-NYAM.
18 Rinchiuso-Hasselmann A, Starr DT, McKay RL, Medina E, Raphael M. Public compliance with mass prophylaxis guidance. Biosecur Bioterror. Sep. 2010;8(3):255-63. [pmid: 20825336].
19 Rowel R. Maryland Dept. of Health and Mental Hygiene. A guide to enhance grassroots risk communication among low-income populations [electronic resource]. Annapolis, MD. Maryland Dept. of Health and Mental Hygiene. 2009. [cited RAND Library-NYAM.
20 Shugarman LR, Chandra A, Taylor SL, Stern S, Beckjord EB, Parker AM, et al. Analysis of risk communication strategies and approaches with at - risk populations to enhance emergency preparedness, response, and recovery. Santa Monica, CA. Rand Health. 2008. [cited RAND Library-NYAM.
21 University of California BSoPH. Lessons learned from Hurricane Katrina : how local health departments can prepared to meet the needs of vulnerable populations in emergencies. Berkeley, Calif. University of California, Berkeley School of Public Health. 2006. [cited RAND Library-NYAM.
22 Veatch RM. Disaster preparedness and triage: justice and the common good. Mt Sinai J Med. Jul. 2005;72(4):236-41. [pmid: 16021317].
23 Wray RJ, Becker SM, Henderson N, Glik D, Jupka K, Middleton S, et al. Communicating with the public about emerging health threats: lessons from the Pre-Event Message Development Project. Am J Public Health. Dec. 2008;98(12):2214-22. [pmid: 18382011].

### Did not assess the public’s opinions directly (N=4)

1 Lowrey W, Evans W, Gower KK, Robinson JA, Ginter PM, McCormick LC, et al. Effective media communication of disasters: pressing problems and recommendations. BMC Public Health. 2007;7:97. [pmid: 17553153].
2 Trotter G. The ethics of coercion in mass casualty medicine. Baltimore. Johns Hopkins University Press. 2007.
3 University of Toronto Joint Centre for Bioethics Pandemic Influenza Working Group. Stand on Guard for Thee: Ethical considerations in preparedness planning for pandemic influenza. November. 2005. See also L. Rubinson, et al. “Augmentation of hospital critical care capacity after bioterrorist attacks or epidemics: Recommendations of the Working Group on Emergency Mass Critical Care,” Critical Care Medicine, 2005, 33(10):E1–13. See also J. D. Arras, “Ethical Issues in the Distribution of Influenza Vaccines,” Hastings Center Report, In Press, 2005.
4 Wolf L, Hensel W. Valuing lives: Allocating scarce medical resources during a public health emergency and the Americans with Disabilities Act (perspective). PLoS Curr. 2011;3:RRN1271. [pmid: 22031448].