# Evidence Tables

Appendix Table C-1a Tested Strategies to reduce or manage less urgent demand (KQ1)

Appendix Table C-1b Tested Strategies to optimize use of existing resources (KQ1)

Appendix Table C-1c Tested Strategies to augment existing resources (KQ1)

Appendix Table C-2 Tested Strategies lacking comparison groups (KQ1)

Appendix Table C-3 Proposed strategies to allocation scarce resources during mass casualty events (KQ1)

Appendix Table C-4a Tested Strategies to reduce or manage less urgent demand (KQ2)

Appendix Table C-4b Tested Strategies to optimize use of existing resources (KQ2)

Appendix Table C-4c Tested Strategies to augment existing resources (KQ2)

Appendix Table C-4d Tested Strategies for crisis standards of care (KQ2)

Appendix Table C-5 Tested Strategies Lacking Comparisons Groups (KQ2)

Appendix Table C-6 Proposed strategies to allocate scarce resources during mass casualty events (KQ2)

Appendix Table C-7 Public perceptions and concerns about allocating scarce resources during mass casualty events (KQ3)

Appendix Table C-8 Strategies to engage providers in allocating scarce resources during mass casualty events(KQ4)