# Data Abstraction Tools

Short Form

This is the short form, containing these seven questions: Is the language of the article in English, does this study directly address a KQ, what type of study is this, if this study is not being included do we need to separately mine it for references, is this a potential background article, if this study is excluded should it be a soft exclude, and is this excluded article very high yield.

Long Form: KQ1 and 2 Tested Strategies

This is the KQ 1–2 long form, containing unnumbered questions divided into these six sections: Key inclusion criteria to be reconciled first, study design and characteristics, outcomes assessment, quality, applicability, and general.

KQ4 Long Form

This is the KQ 4 long form, containing 27 questions divided into these six sections: Key inclusion criteria to be reconciled first, study design and characteristics, outcomes assessment, quality, applicability, and general.