# Literature Search Strategy

INITIAL SEARCHES RAN JANUARY 21, 2011, COVERING 1990-January 2011. FINAL UPDATE SEARCHES PERFORMED ON NOVEMBER 8, 2011 COVERING JANUARY 2011-NOVEMBER 2011.

SEARCH #1 (updated 11/8/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

PubMed 2011–2011

SEARCH STRATEGY:

disasters[mesh] OR disaster*[tiab] OR emergencies OR emergency planning OR emergency preparedness OR mass casualt* OR ((triage[ti] OR triaging[ti]) AND disaster*) OR pandemic[ti]

AND

surge OR scarce OR scarcity OR allocat* OR ration OR mass OR (triage AND (ethic* OR protocol)) OR “emergency medical care” OR (emergency medical care services[mh] AND ration) OR remote consultation[mh] OR “crisis standards” OR “altered care” OR “adapted care” OR “crisis standards of care” OR “altered standards of care”

NOT: Letters, Case Reports, Clinical Trials

NOT: animal*NOT Human*

NOT:(“human remains” OR “identifying human bodies” OR autops* OR “end of life planning” OR pig OR pigs OR porcine OR cow OR cows OR bovine OR horse OR horses OR dog OR dogs OR cat OR cats OR mice OR mouse OR hamster OR hamsters OR rat OR rats OR “identification of human bodies” OR epidemiology OR appendectomy OR “dental identification” OR “water insecurity” OR “mass gatherings” OR “dental identification” OR (food AND ration) OR clinicaltrials.gov OR “total hip replacement” OR (mass AND cancer) OR ECMO OR forensic* OR drought OR “abdominal aortic aneurysm” OR (oil AND spill) OR “global warming” OR “partner violence” OR “violence prevention”)

NUMBER OF ITEMS RETRIEVED: 223

SEARCH #2 (updated 11/8/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

CINAHL – 2011–2011

(Disaster* OR emergencies OR emergency planning OR emergency preparedness OR mass casualt* OR ((TI triage OR TI triaging) AND disaster*) OR TI pandemic)

AND

(surge OR scarce OR scarcity OR allocat* OR (triage AND (ethic* OR protocol)

OR “emergency medical care” OR (“emergency medical services” AND ration) OR “remote consultation” OR “crisis standards” OR “altered care” OR “adapted care” OR “crisis standards of care” OR “altered standards of care”)

And Human

Not Letters

Limiters - Date of Publication from: 20110101-20111231; Peer Reviewed; Exclude MEDLINE records; Human

NUMBER OF ITEMS RETRIEVED: 7 (1 duplicate) = 6

SEARCH #3 (updated 11/8/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

Cochrane – 2011–2011

“mass casualt*” OR “disaster preparedness” OR (Triag* AND (disaster OR mass))

NUMBER OF ITEMS RETRIEVED: 6

SEARCH #4 (RUN 11/8/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

Embase – 2011–2012

‘mass disaster’/exp OR disaster*:ab,ti OR ‘emergencies’/exp OR ‘emergency’/exp AND ‘planning’/exp OR ‘emergency’/exp AND preparedness OR ‘mass’/exp AND casualt* OR ((triage:ti OR triaging:ti)AND disaster*) OR pandemic:ti AND [embase]/lim

AND

‘emergency medical care’/exp OR (‘emergency medical services’/exp AND ration) OR ‘remote consultation’/exp OR ‘crisis standards’ OR ‘altered care’ OR ‘adapted care’ OR ‘crisis standards of care’ OR ‘altered standards of care’ OR surge OR scarce OR scarcity OR allocat* OR ration OR ‘mass’/exp OR (‘triage’/exp AND (ethic* OR protocol)) AND [embase]/lim

AND [humans]/lim AND [1990–2011]/py

NOT

pandemic NEAR/3 vaccin*

NUMBER OF ITEMS RETRIEVED: 21 results (8 duplicates) = 13 results

SEARCH #5 (updated 11/8/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

Web of Science – 2011–2011

TS=disaster* OR TS=emergencies OR TS=emergency planning OR TS=emergency preparedness OR TS=mass casualt* OR (TI=triage OR TI=triaging) AND TS=disaster*) OR TI=pandemic

AND

TS=surge OR TS=scarce OR TS=scarcity OR TS=allocat* OR TS=triage AND TS= (ethic* OR protocol) OR TS=“emergency medical care” OR TS= (“emergency medical services” AND ration) OR TS=“remote consultation” OR TS=“emergency medical care” OR TS= (“emergency medical services” AND ration) OR TS=“remote consultation” OR TS=“crisis standards” OR TS=“altered care” OR TS=“adapted care” OR TS=“crisis standards of care” OR TS=“altered standards of care”

NOT: Letter

NOT:

(TS=“human remains” OR TS=“identifying human bodies” OR TS=autops* OR TS=“end of life planning” OR TS=pig OR TS=pigs OR TS=porcine OR TS=cow OR TS=cows OR TS=bovine OR TS=horse OR TS=horses OR TS=dog OR TS=dogs OR TS=cat OR TS=cats OR TS=mice OR TS=mouse OR TS=hamster OR TS=hamsters OR TS=rat OR TS=rats OR TS=“identification of human bodies” OR TS=epidemiology OR TS=appendectomy OR TS= “dental identification” OR TS=“water insecurity” OR TS=“mass gatherings” OR TS=“dental identification” OR TS= (food AND ration) OR TS=clinicaltrials.gov OR TS=“total hip replacement” OR TS= (mass AND cancer) OR TS=ECMO OR TS=forensic* OR TS=drought OR TS=“abdominal aortic aneurysm” OR TS= (oil AND spill) OR TS=“global warming” OR TS= “partner violence” OR TS= “violence prevention” OR TS=geological OR TS=“clinical trial” OR TS=“urban modeling” OR TS=“urban simulation” OR )

Refined by: [excluding] Subject Areas=( ENGINEERING, MECHANICAL OR WATER RESOURCES OR ECOLOGY OR CONSTRUCTION & BUILDING TECHNOLOGY OR MATHEMATICS, INTERDISCIPLINARY APPLICATIONS OR ENGINEERING, GEOLOGICAL OR METEOROLOGY & ATMOSPHERIC SCIENCES OR VETERINARY SCIENCES OR ENGINEERING, OCEAN OR MEDICAL INFORMATICS OR OCEANOGRAPHY )

NUMBER OF ITEMS RETRIEVED: 273 (before deduping); 227 after de-duping

SEARCH #6 (RUN 11/10/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

Global Health – 1990–2011

1 S DISASTER? OR MASS()CASUALT? OR EMERGENCY(5N)PLAN? OR EMERGENCY(5N)PREPAR? OR EMERGENCY()MEDICAL()CARE OR REMOTE()SERVICES OR EMERGENCIES OR PANDEMIC?
S2 S TRIAG?/TI AND DISASTER?
S3 S S1 OR S2
S4 S SURGE OR SCARCE OR SCARCITY OR ALLOCAT? OR RATION OR RATIONED OR RATIONING OR MASS
S5 S TRIAGE AND (ETHIC? OR PROTOCOL?)
S6 S S3 OR S4
S7 S S3 AND S6
S8 S S3 AND S4
S9 S S8 OR S5
S10 S EMERGENCY()MEDICAL()CARE()SERVICE? AND (RATION OR RATIONED OR RATIONING)
S11 S EMERGENCY()MEDICAL AND (RATION OR RATIONED OR RATIONING)
S12 S REMOTE?(2N)CONSULT?
S13 S CRISIS(2N)STANDARD? OR ALTERED()CARE OR ADAPTED()CARE
S14 S S9 OR S11 OR S12 OR S13
S15 S S14/ENG
S16 S S15/1990:2011

NUMBER OF ITEMS RETRIEVED: 137 – 51 duplicates – 86

SEARCH #7 (RUN 4/16/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

SCOPUS – 1990–2011

TITLE-ABS-KEY(disaster*) OR emergencies OR {emergency planning} OR emergency preparedness OR mass casualt* OR TITLE(triage) OR TITLE(pandemic)

AND

surge OR scarce OR scarcity OR allocat* OR ration OR mass OR (triage AND (ethic* OR protocol))

OR({emergency medical care} OR {remote consultation}) AND ration OR

{crisis standards} OR {altered care} OR {adapted care} OR {crisis standards of care} OR {altered standards of care} OR {crisis care}

AND

PUBYEAR AFT 2011

NOT

{human remains} OR {identifying human bodies} OR autops* OR {end of life planning} OR pig OR pigs OR porcine OR cow OR cows OR bovine OR horse OR horses OR dog OR dogs OR cat OR cats OR mice OR mouse OR hamster OR hamsters OR rat OR rats OR {identification of human bodies} OR epidemiology OR appendectomy OR {dental identification} OR {water insecurity} OR {mass gatherings} OR {dental identification} OR (food AND ration) OR clinicaltrials.gov OR {total hip replacement} OR (mass AND cancer) OR ecmo OR forensic* OR drought OR {abdominal aortic aneurysm} OR (oil AND spill) OR {global warming} OR {partner violence} OR {violence prevention})

NUMBER OF ITEMS RETRIEVED: 218 -114(weeding) – 45 (deduping)= 59

SEARCH #8 (updated 11/8/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

NLMLocatorPlus– 2011–2011

Mass Casualty as a phrase in Title

OR

Disaster in Title

AND

Medicine in Title

NUMBER OF ITEMS RETRIEVED: 15 titles kept 3

(these are in a separate.txt file: NLMupdatedresults.txt)

SEARCH #9 (RUN 11/14/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

NYAM Grey Literature Report– 2011-

Key word: mass casualty OR disaster OR disasters

NUMBER OF ITEMS RETRIEVED: 12

(these citations are in a separate word document: NYAM_UpdateDisaster_MassCasualty_11_2011.doc)

SEARCH #1 (RUN 1/21/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

PubMed – 1990–2011

SEARCH STRATEGY:

disasters[mesh] OR disaster*[tiab] OR emergencies OR emergency planning OR emergency preparedness OR mass casualt* OR ((triage[ti] OR triaging[ti]) AND disaster*) OR pandemic[ti]

AND

surge OR scarce OR scarcity OR allocat* OR ration OR mass OR (triage AND (ethic* OR protocol)) OR “emergency medical care” OR (emergency medical care services[mh] AND ration) OR remote consultation[mh] OR “crisis standards” OR “altered care” OR “adapted care” OR “crisis standards of care” OR “altered standards of care”

NOT: Letters, Case Reports, Clinical Trials

NOT: animal*NOT Human*

NOT:(“human remains” OR “identifying human bodies” OR autops* OR “end of life planning” OR pig OR pigs OR porcine OR cow OR cows OR bovine OR horse OR horses OR dog OR dogs OR cat OR cats OR mice OR mouse OR hamster OR hamsters OR rat OR rats OR “identification of human bodies” OR epidemiology OR appendectomy OR “dental identification” OR “water insecurity” OR “mass gatherings” OR “dental identification” OR (food AND ration) OR clinicaltrials.gov OR “total hip replacement” OR (mass AND cancer) OR ECMO OR forensic* OR drought OR “abdominal aortic aneurysm” OR (oil AND spill) OR “global warming” OR “partner violence” OR “violence prevention”)

OR:

Levin D[au] AND pandemic[ti]

NUMBER OF ITEMS RETRIEVED: 2472

SEARCH #2 (RUN 1/27/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

CINAHL – 1990–2011

Disaster* OR emergencies OR emergency planning OR emergency preparedness OR mass casualt* OR ((TI triage OR TI triaging) AND disaster*) OR TI pandemic

AND

surge OR scarce OR scarcity OR allocat* OR (triage AND (ethic* OR protocol)

OR “emergency medical care” OR (“emergency medical services” AND ration) OR “remote consultation” OR “crisis standards” OR “altered care” OR “adapted care” OR “crisis standards of care” OR “altered standards of care”

And Human

Not Letters

Date of Publication from: 19900101-20111231; Peer Reviewed; Exclude MEDLINE records

NUMBER OF ITEMS RETRIEVED: 83 (AFTER DEDUPING) 76

SEARCH #3 (RUN 1/27/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

Cochrane – 1990–2011

“mass casualt*” OR “disaster preparedness” OR (Triag* AND (disaster OR mass))

NUMBER OF ITEMS RETRIEVED: 56

SEARCH #4 (RUN 1/27/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

Embase – 1990–2011

‘mass disaster’/exp OR disaster*:ab,ti OR ‘emergencies’/exp OR ‘emergency’/exp AND ‘planning’/exp OR ‘emergency’/exp AND preparedness OR ‘mass’/exp AND casualt* OR ((triage:ti OR triaging:ti)AND disaster*) OR pandemic:ti AND [embase]/lim

AND

‘emergency medical care’/exp OR (‘emergency medical services’/exp AND ration) OR ‘remote consultation’/exp OR ‘crisis standards’ OR ‘altered care’ OR ‘adapted care’ OR ‘crisis standards of care’ OR ‘altered standards of care’ OR surge OR scarce OR scarcity OR allocat* OR ration OR ‘mass’/exp OR (‘triage’/exp AND (ethic* OR protocol)) AND [embase]/lim

AND [humans]/lim AND [1990–2011]/py

NOT

pandemic NEAR/3 vaccin*

NUMBER OF ITEMS RETRIEVED: 129 results (before de-duping) 70 (after de-duping & hand removal)

SEARCH #5 (RUN 1/27/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

Web of Science – 1990–2011

TS=disaster* OR TS=emergencies OR TS=emergency planning OR TS=emergency preparedness OR TS=mass casualt* OR (TI=triage OR TI=triaging) AND TS=disaster*) OR TI=pandemic

AND

TS=surge OR TS=scarce OR TS=scarcity OR TS=allocat* OR TS=triage AND TS= (ethic* OR protocol) OR TS=“emergency medical care” OR TS= (“emergency medical services” AND ration) OR TS=“remote consultation” OR TS=“emergency medical care” OR TS= (“emergency medical services” AND ration) OR TS=“remote consultation” OR TS=“crisis standards” OR TS=“altered care” OR TS=“adapted care” OR TS=“crisis standards of care” OR TS=“altered standards of care”

NOT: Letter

NOT:

(TS=“human remains” OR TS=“identifying human bodies” OR TS=autops* OR TS=“end of life planning” OR TS=pig OR TS=pigs OR TS=porcine OR TS=cow OR TS=cows OR TS=bovine OR TS=horse OR TS=horses OR TS=dog OR TS=dogs OR TS=cat OR TS=cats OR TS=mice OR TS=mouse OR TS=hamster OR TS=hamsters OR TS=rat OR TS=rats OR TS=“identification of human bodies” OR TS=epidemiology OR TS=appendectomy OR TS= “dental identification” OR TS=“water insecurity” OR TS=“mass gatherings” OR TS=“dental identification” OR TS= (food AND ration) OR TS=clinicaltrials.gov OR TS=“total hip replacement” OR TS= (mass AND cancer) OR TS=ECMO OR TS=forensic* OR TS=drought OR TS=“abdominal aortic aneurysm” OR TS= (oil AND spill) OR TS=“global warming” OR TS= “partner violence” OR TS= “violence prevention” OR TS=geological OR TS=“clinical trial” OR TS=“urban modeling” OR TS=“urban simulation” OR )

Refined by: [excluding] Subject Areas=( ENGINEERING, MECHANICAL OR WATER RESOURCES OR ECOLOGY OR CONSTRUCTION & BUILDING TECHNOLOGY OR MATHEMATICS, INTERDISCIPLINARY APPLICATIONS OR ENGINEERING, GEOLOGICAL OR METEOROLOGY & ATMOSPHERIC SCIENCES OR VETERINARY SCIENCES OR ENGINEERING, OCEAN OR MEDICAL INFORMATICS OR OCEANOGRAPHY )

NUMBER OF ITEMS RETRIEVED: 748 (before deduping); 506 after de-duping (and screening)

SEARCH #6 (RUN 2/1/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

Global Health – 1990–2011

1 10670 S DISASTER? OR MASS()CASUALT? OR EMERGENCY(5N)PLAN? OR EMERGENCY(5N)PREPAR? OR EMERGENCY()MEDICAL()CARE OR REMOTE()SERVICES OR EMERGENCIES OR PANDEMIC?
S2 16 S TRIAG?/TI AND DISASTER?
S3 10670 S S1 OR S2
S4 93610 S SURGE OR SCARCE OR SCARCITY OR ALLOCAT? OR RATION OR RATIONED OR RATIONING OR MASS
S5 54 S TRIAGE AND (ETHIC? OR PROTOCOL?)
S6 103284 S S3 OR S4
S7 10670 S S3 AND S6
S8 996 S S3 AND S4
S9 1026 S S8 OR S5
S10 0 S EMERGENCY()MEDICAL()CARE()SERVICE? AND (RATION OR RATIONED OR RATIONING)
S11 1 S EMERGENCY()MEDICAL AND (RATION OR RATIONED OR RATIONING)
S12 21 S REMOTE?(2N)CONSULT?
S13 3 S CRISIS(2N)STANDARD? OR ALTERED()CARE OR ADAPTED()CARE
S14 1048 S S9 OR S11 OR S12 OR S13
S15 974 S S14/ENG
S16 930 S S15/1990:2011

NUMBER OF ITEMS RETRIEVED: 930

SEARCH #7 (RUN 4/16/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

SCOPUS – 1990–2011

TITLE-ABS-KEY(disaster*) OR emergencies OR {emergency planning} OR emergency preparedness OR mass casualt* OR TITLE(triage) OR TITLE(pandemic)

AND

surge OR scarce OR scarcity OR allocat* OR ration OR mass OR (triage AND (ethic* OR protocol))

OR({emergency medical care} OR {remote consultation}) AND ration OR

{crisis standards} OR {altered care} OR {adapted care} OR {crisis standards of care} OR {altered standards of care} OR {crisis care}

AND

PUBYEAR AFT 1989

NOT

{human remains} OR {identifying human bodies} OR autops* OR {end of life planning} OR pig OR pigs OR porcine OR cow OR cows OR bovine OR horse OR horses OR dog OR dogs OR cat OR cats OR mice OR mouse OR hamster OR hamsters OR rat OR rats OR {identification of human bodies} OR epidemiology OR appendectomy OR {dental identification} OR {water insecurity} OR {mass gatherings} OR {dental identification} OR (food AND ration) OR clinicaltrials.gov OR {total hip replacement} OR (mass AND cancer) OR ecmo OR forensic* OR drought OR {abdominal aortic aneurysm} OR (oil AND spill) OR {global warming} OR {partner violence} OR {violence prevention})

NUMBER OF ITEMS RETRIEVED: after deduping 1270 – after weeding 428

SEARCH #8 (RUN 1/28/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

NLMLocatorPlus– 1990–2011

Mass Casualty as a phrase in Title

OR

Disaster in Title

AND

Medicine in Title

NUMBER OF ITEMS RETRIEVED: 141 titles kept 42

SEARCH #9 (RUN 1/31/2011)

DATABASE SEARCH & TIME PERIOD COVERED:

NYAM Grey Literature Report– 1990–2011

Key word: mass casualty OR disaster OR disasters

NUMBER OF ITEMS RETRIEVED: 290