# Acronyms and Abbreviations

AGPRs: automatic gas-powered resuscitators
AHRQ: Agency for Healthcare Research and Quality
ASPR: Office of the Assistant Secretary for Preparedness and Response
CalMAT: California Medical Assistance Team
CDC: Centers for Disease Control and Prevention
CDPHE: Colorado Department of Public Health and Environment
CENTRAL: Cochrane Central Register of Controlled Trials
CER: comparative effectiveness review
CHC: community health centers
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CME: continuing medical education
CT: computerized tomography
CVM: Colorado’s Volunteer Mobilizer
DARE: Cochrane Database of Abstracts of Reviews of Effects
DHS: Department of Homeland Security
DHHS: Department of Health and Human Services
DMAT: Disaster Medical Assistance Team
DOD: Department of Defense
DoE: Department of Energy
ED: emergency department
EMS: emergency medical services
EPC: Evidence-based Practice Center
ESAR VHP: Emergency System for Advance Registration of Volunteer Health Professionals
ESCAPE: Enhancing Surge Capacity and Partnership Effort
FAST: Focused Assessment by Sonography in Trauma
GAO: Government Accountability Office
HHS: Health and Human Services
HMO: health maintenance organization
ICU: intensive care unit
IOM: Institute of Medicine
KQ: Key Question
LIMS: Laboratory Information System
LTC: long-term care
MAC: multi-agency coordination
MCE: mass casualty event
MRC: Medical Reserve Corps
NHSS: National Health Security Strategy
NIH: National Institutes of Health
NORTHCOM: Northern Command
NREPP: National Registry of Evidence Based Programs and Practices
NSF: National Science Foundation
OHPIP: Ontario Health Plan for an Influenza Pandemic
OHSU: Oregon Health Sciences University
OR: operating room
PAHO: Pan American Health Organization
PICOTS: populations, interventions, comparators, outcomes, timeframes, and settings
POD: point of dispensing
RCT: randomized controlled trial
SARS: severe acute respiratory syndrome
SNF: skilled nursing facility
SNS: Strategic National Stockpile
SOFA: Sequential Organ Failure Assessment
SRC: Scientific Resource Center
TEP: technical expert panel
VHA: Veterans Health Administration
WHO: World Health Organization