# Acknowledgments

The authors would like to thank Aram Dobalian, M.P.H., Director of the Department of Veterans Affairs Emergency Management Evaluation Center (VEMEC) at the VA Greater Los Angeles Healthcare System (VAGLAHS), and Kristi Koenig, M.D., professor of emergency medicine at the University of California, Irvine, for their invaluable input and guidance on the report. Both are nationally recognized experts in disaster medicine and health system preparedness.

The authors would also like to thank members of the public who submitted comments on a draft version of this report.