# Results

## Results of the Literature Search

The literature search and hand searching process identified 17,749 citations that were deemed potentially relevant to Key Questions 1 and/or 2 (Figure 2). We excluded 3,207 duplicate citations from the electronic search results. Most duplicates came from concurrently searching MEDLINE^®^, The Cochrane Library, CINAHL, and PsycINFO.

Figure 2 Summary of literature search (number of articles)

*Total exceeds the # in the exclusion box because reviewers were allowed to mark more than 1 reason for exclusion

†Other reasons for exclusion include: study addressed health IT but was not an RCT, no original data, no abstractable data, methodological paper, descriptive studies. Other exclusions were heterogeneous.

Figure 2. Results of the literature search. This figure shows the number of articles captured by the searches by database and the total number of articles screened after deduplication is 17749. Of these, 6051 were included for abstract screening and a total of 860 full text articles were screened for applicability. After articles review 569 articles were excluded for a variety of reasons, and 327 were included in the final review.

During the title screening process, we excluded 11,698 citations that clearly did not apply to the key questions. The abstract screening process excluded 5,191 citations that did not meet one or more of the eligibility criteria for this study listed in Chapter 2. At the article-screening phase, we excluded an additional 567 articles that did not meet one or more of the eligibility criteria. Ultimately we were left with 327 articles that were applicable to Key Questions 1 and/or 2—184 for Key Question 1, 206 for Key Question 2, and 63 articles that were applicable to both Key Questions 1 and 2 (see Appendix F for a list of excluded articles). We did not search for studies in the gray literature because we found a more than adequate number of applicable studies in the main search.

## Description of the Types of Studies Retrieved

The primary research team agreed that RCTs provided the best evidence for measuring how well health IT applications enable PCC. Therefore, all 184 studies relevant to Key Question 1 were RCTs. The team also agreed that all study designs should be included when searching for articles investigating barriers and facilitators for using health IT application in PCC (Key Question 2). The 206 articles addressing barriers and facilitators were for the most part RCTs, qualitative studies, and usability studies.

## Key Question 1a Are health IT applications that address one or more components of PCC effective in improving health care process outcomes, and how do these improvements vary by type of health IT application?

### General Study Characteristics

We identified 97 articles evaluating how health IT applications, that address PCC, affect process outcomes (Appendix G, Evidence Tables 1–3). These studies predominantly targeted the clinical conditions diabetes mellitus, hypertension, congestive heart failure, cancer and asthma (Table 5). They predominantly employed health IT applications that were classified as clinical decision aids, IT-guided disease management, electronic medical records, telemedicine, and telemonitoring systems (Table 6). They most commonly addressed the PCC components that were classified as patient engagement in care, quality improvement, quality and safety, prevention and health promotion, and integrated care (Table 7). They predominantly studied the process outcomes of adherence to standards of care for testing and treatment and use of health care resources (Tables 8–11). The study results suggested process outcomes generally improve with the health IT interventions that address one or more components of PCC.

Table 5 Studies addressing the effect of health IT applications on process outcomes in specific target conditions, target populations, and care focus areas

Target Care Focus Area | N (Specific Reference)
Heart disease | 15^45^ 70–83
Diabetes mellitus | 11^20–28^ 30 84
Hypertension | 9^50–57^ 85
Asthma | 6^58–62^ 86
Cancer | 4^46–49^
Mental health | 3^64–66^
Smoking cessation | 3^67–69^
Alcohol abuse | 1^87^
Chronic obstructive pulmonary disease | 2^88^ 89
Pregnancy | 3^90–92^
All the preventive procedures for families enrolled in the study | 1^93^
Ambulatory patients | 1^94^
Blood transfusion | 1^95^
Chronic condition/health problem | 1^96^
Anemia, diabetes mellitus, glandular fever, hypercholesterolemia, hypertension, liver problems, urine complaints | 1^97^
Domestic violence | 1^98^
Emergency department patients | 1^99^
Evaluate the use of both medical services and drugs before and after the implementation of computer decisionmaking support. | 1^100^
Fever without apparent source in 1–36 month old. | 1^101^
Genetic counseling | 1^102^
Hemophilia | 1^103^
Hyperlipidemia | 1^104^
Infection antibiotic management and prophylaxis | 1^105^
Influenza immunization in high-risk adult patients | 1^106^
Menopause/ hormone replacement therapy | 1^107^
Multiple conditions | 1^43^
Osteoporosis | 1^108^
Overactive bladder symptoms | 1^109^
Patients over 65 who are prescribed certain medications (age-specific prescribing) | 1^110^
Patients with trauma as the primary risk factor for acute respiratory distress syndrome | 1^111^
Polypharmacy and falls in ambulatory rural elderly | 1^112^
Preventive medicine (routine laboratory monitoring to reduce the risk of adverse medication events) | 2^113^ 114
Recurrent headache | 1^115^
Skin lesions | 1^116^
Sleep apnea | 1^117^
Spinal cord injuries | 1^118^
Thrombotic or bleeding events | 1^119^
Upper respiratory infections | 1^120^
Wound care | 1^121^
Other or unspecified | 12^122–134^

IT: Information Technology

Table 6 Studies addressing the effect of health IT applications on process outcomes

Health IT Application | N (Specific Reference)
Care Management Tools
Clinical decision aids | 34^70^ 78 81 123–125 128 129 132–157
IT-guided disease management | 17^74^ 81 82 126 137 140 146 151 158–166
Electronic medical records | 17^72^ 80 81 122 128 138 141 150 154 160–163 167–170
IT-guided self-management | 6^72^ 84 86 114 171 172
Computer-assisted self-care | 5^155^ 158 171 173 174
Care coordination tools | 5^146^ 164 169 175 176
Computerized order entry | 2^92^ 133
Electronic prescribing | 1^92^
Disease registry | 1^155^
Telehealth
Telemedicine | 10^71^ 79 127 173 177–182
Telemonitoring systems | 11^45^ 73 80 81 159 167 173 183–186
Personal Health Record and Patient Portal Related Applications
Education via information technology | 8^86^ 123 159 165 167 172 187 188
mHealth | 5^131^ 146 166 183 189
Interactive lifestyle counseling | 2^84^ 190
Patient portals | 2^122^ 165
Personal health records | 1^72^
Secure Electronic Messaging
Communication via e-mail | 9^72^ 75 76 122 141 159 167 187 191
Information exchange | 6^159^ 166 168 187 190 192
Shared Decisionmaking
Shared decisionmaking tools | 5^78^ 91 188 189 192

E-mail: Electronic Mail, IT: Information Technology, mHealth: Mobile Health

Table 7 Studies addressing the effect of health IT applications on process outcomes, broken down by specific components of PCC^*^

Component of PCC | N (Specific References)
Coordination and Integration of Care
Quality improvement | 25^45^ 77 79 81 84 86 92 114 132 136 138 146–148 150 158 161 162 168 170 173 179 180 183 193
Quality and safety | 20^71^ 91 124 126 132 134 142 145 158 163 165 168 178 182 184 186 190 192 194 195
Integrated care | 21^77^ 127–129 131 144 146 153 161 162 164 167 168 170–172 184 188 191 194 196
Prevention and health promotion | 21^70^ 84 122 133 135 141 144 145 147 148 157 159 160 165 169 172 177 180 181 188 196
Routine patient feedback to practice | 9^73^ 79 86 149 165 174 184 189 196
Transition and continuity | 2^77^ 151
Whole-Person Orientation
Respecting patients’ values, preferences and needs | 9^81^ 92 125 155 170 171 182 187 189
Alleviation of fear and anxiety | 6^137^ 140 153 166 167 173
Emotional support | 3^131^ 152 189
Physical comfort | 180 197
Exploring the disease and illness condition | 3^149^ 152 182
Enhanced Clinician-Patient Relationship
Patient engagement in care | 49^70^ 72 74 76–82 84 86 114 123 125 127 128 131 135 139 140 143 144 146 148 150 152–156 159 164 167–171 173 174 176 180 183 185 189 191 192 196 197
Patient empowerment | 16^73–75^ 78 81 123 137 140 146 150 152–155 159 185
Finding common ground | 1^155^
Clinical Information Systems
Practice-based learning | 2^141^ 158
Publicly available information on practices | 1^166^
Socio-Cultural Competence
Community outreach | 2^78^ 177
Family and friend involvement | 2^146^ 151

IT: Information Technology, PCC: Patient-Centered Care

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 8a Summary of the impact of health IT applications on process outcomes for patients with diabetes mellitus

Study, Year | Health IT Application | Interventions Compared | Outcomes Measure | Positive Impact^*^
Filippi, 2003^20^ | Clinical decision aids | Electronic reminder integrated into a routine computer system in order to increase the use of antiplatelet drugs for diabetic patients vs. patients receiving a letter but no electronic reminder | Number of high-risk diabetic patients with antiplatelet drug prescriptions | +
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Fractions of patients without baseline registration of HbA1c | +
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Fractions of patients without a baseline registration of blood pressure | −
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Fractions of patients without a baseline registration of serum cholesterol | +
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Fractions of patients without a registered number of cigarettes, | +
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Fractions of patients without registered CV inheritance | +
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Fractions of patients without registered height/weight or BMI | +
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Fractions of patients without at least one variable making risk score calculation possible | +
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Percentage of registered patients who are smokers | +
Hetlevik, 2000^21^ | Clinical decision aids | Diabetes mellitus patients whose physicians used a CDSS vs. diabetes mellitus patients whose physicians used pre-existing routines for treatment | Percentage of registered patients with CV risk inheritance | +
Glasgow, 2000^29^ | IT-guided self-management, interactive lifestyle counseling | Telephone followup vs. the basic intervention condition received by all participants, which involved a meeting with a health counselor at a central location and having specific dietary goals set with the aid of a multimedia touch screen computer | Proportion received touch screen goal setting | +
Glasgow, 2000^29^ | IT-guided self-management, interactive lifestyle counseling | Community resources vs. the basic intervention condition received by all participants involved a meeting with a health counselor at a central location and having specific dietary goals set with the aid of a multimedia touch screen computer | Proportion received touch screen goal setting | +
Glasgow, 2000^29^ | IT-guided self-management, interactive lifestyle counseling | Telephone followup support and community resources vs. the basic intervention condition received by all participants involved a meeting with a health counselor at a central location and having specific dietary goals set with the aid of a multimedia touch screen computer | Proportion received touch screen goal setting | −
Gomez, 2002^28^ | Telemedicine | Group using DIABTel telemedicine system vs. usual care group (patients used a blood glucose meter with memory One Touch™ Profile from LifeScan) and they registered the monitoring data in their conventional logbook. No intermediate visits were scheduled but patients were free to make phone calls to the Diabetes Centre when needed. | Therapeutic medication prescriptions increased | +
Persell, 2008^24^ | Telemonitoring systems | Eliciting physicians’ input and directly contacting patients by mail and phone vs. reminder to physician only | All patients - regular aspirin use | +
Persell, 2008^24^ | Telemonitoring systems | Eliciting physicians’ input and directly contacting patients by mail and phone vs. reminder to physician only | Regular aspirin use excluding long-term aspirin users and patients reporting medical contraindication | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Well-Doc Intervention vs. control group. The intervention group received cell phone-based software designed by endocrinologists and certified diabetes educator. Patients randomized to the control group received glucometers, adequate blood glucose testing strips and lancets for the duration of the trial. | Medication intensified | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | | Medication errors identified | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | | Physician received logbook | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | | New diagnosis depression | −
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | | Provider management improved | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | | Physician received data | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | | Physician received more patient data | +
Ralston, 2009^30^ | Communication via email, education via IT, electronic medical records, telemonitoring systems | Web-based care management vs. usual care | Inpatient days | 0
Ralston, 2009^30^ | Communication via email, education via IT, electronic medical records, telemonitoring systems | Web-based care management vs. usual care | Outpatient visits | 0
Ralston, 2009^30^ | Communication via email, education via IT, electronic medical records, telemonitoring systems | Web-based care management vs. usual care | Primary care provider visits | 0
Ralston, 2009^30^ | Communication via email, education via IT, electronic medical records, telemonitoring systems | Web-based care management vs. usual care | Specialty physician visits | 0
Sequist, 2005^22^ | Clinical decision aids | Physicians received either evidence-based electronic reminders within the electronic medical record vs. usual care | Number of diabetes reminders per patient | −
Sequist, 2005^22^ | Clinical decision aids | Physicians received either evidence-based electronic reminders within the electronic medical record vs. usual care | Mean coronary artery disease Reminders per patient | −
Smith, 2008^27^ | Telemedicine | Virtual consultation vs. no virtual consultation | ADA-NCQA provider score, median | −
Smith, 2008^27^ | Telemedicine | Virtual consultation vs. no virtual consultation | Minnesota community aggregate optimal diabetes score | +
Smith, 2008^27^ | Telemedicine | Virtual consultation vs. no virtual consultation | Mean total cost | +
Smith, 2008^27^ | Telemedicine | Virtual consultation vs. no virtual consultation | Mean outpatient cost | +
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | No. of patients who had HbA1c monitoring within 6 months | +
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | No. of patients who had LDL cholesterol monitoring within 1 year | +
Ziemer, 2006^25^ | Care coordination tools, IT-guided disease management | Health care providers received clinical reminders vs. usual care | Effect of the interventions on therapy intensification | 0
Ziemer, 2006^25^ | Care coordination tools, IT-guided disease management | Health care providers received clinical reminders vs. usual care | Therapy intensification on change in HbA1c level | 0
Ziemer, 2006^25^ | Care coordination tools, IT-guided disease management | Health care providers received feedback vs. usual care | Effect of the interventions on therapy intensification | 0
Ziemer, 2006^25^ | Care coordination tools, IT-guided disease management | Health care providers received feedback vs. usual care | Therapy intensification on change in HbA1c level | 0
Ziemer, 2006^25^ | Care coordination tools, IT-guided disease management | Health care providers received clinical reminders and feedback vs. usual care | Effect of the interventions on therapy Intensification | 0
Ziemer, 2006^25^ | Care coordination tools, IT-guided disease management | Health care providers received clinical reminders and feedback vs. usual care | Therapy intensification on change in HbA1c level | 0

ADA-NCQA: American Diabetes Association-National Committee for Quality Assurance, BMI: Body Mass Index, CDSS: Clinical Decision Support System, CV: Cardiovascular, E-mail: Electronic Mail, HbA1c: Glycated Hemoglobin, IT: Information Technology, LDL: Low-Density Lipoprotein, mHealth: Mobile Health

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 8b Overall grade of the quality of evidence in diabetes mellitus studies addressing health care process outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.27
2 | Number of studies | 11
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | No
5 | Overall grade of evidence | Moderate

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Table 9a Summary of the impact of health IT applications on process outcomes for patients with heart disease

Study, Year | Health IT Application | Interventions Compared | Outcomes Measure | Positive Impact
Bailey, 2007^38^ | Clinical decision aids, IT-guided disease management, electronic medical records, telemonitoring systems | Computerized alerts identifying hospitalized patients with elevated troponin I levels routed to clinical pharmacists vs. usual care group | Proportion of eligible patients discharged on a regimen of ACE inhibitor | +
Bailey, 2007^38^ | Clinical decision aids, IT-guided disease management, electronic medical records, telemonitoring systems | Computerized alerts identifying hospitalized patients with elevated troponin I levels routed to clinical pharmacists vs. usual care group | Proportion of eligible patients discharged on aspirin | −
Bailey, 2007^38^ | Clinical decision aids, IT-guided disease management, electronic medical records, telemonitoring systems | Computerized alerts identifying hospitalized patients with elevated troponin I levels routed to clinical pharmacists vs. usual care group | Proportion of eligible patients discharged on a beta-blocker | +
Bailey, 2007^38^ | Clinical decision aids, IT-guided disease management, electronic medical records, telemonitoring systems | Computerized alerts identifying hospitalized patients with elevated troponin I levels routed to clinical pharmacists vs. usual care group | Proportion of eligible patients discharged on a statin | +
Bailey, 2007^38^ | Clinical decision aids, IT-guided disease management, electronic medical records, telemonitoring systems | Computerized alerts identifying hospitalized patients with elevated troponin I levels routed to clinical pharmacists vs. usual care group | Proportion of eligible patients discharged on all 4 classes of medications | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Home care-related costs / patient | −
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Overall costs / patient | −
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Home care-related costs to produce a 5 % improvement in KCCQ summary score | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Overall costs to produce a 5 % improvement in KCCQ summary score | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Home care-related costs / patient | −
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Overall costs / patient | −
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Home care-related costs to produce a 5 % improvement in KCCQ summary score | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Overall costs to produce a 5 % improvement in KCCQ summary score | +
Jerant, 2001 40 | Telemonitoring systems | Home telecare videoconferencing vs. usual care | Median health care utilization | +
Jerant, 2001 40 | Telemonitoring systems | Home telecare videoconferencing vs. usual care | Mean health care utilization | +
Jerant, 2001 40 | Telemonitoring systems | Nurse phone calls with nurse vs. usual care | Median health care utilization | +
Jerant, 2001 40 | Telemonitoring systems | Nurse phone calls with nurse vs. usual care | Mean health care utilization | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median consultation times | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median clinician verbal dominance in 10 minutes preceding decision | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors information-seeking | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors pause | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median patients negative talk | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors nodding | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors head shake | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors smiling | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors point at the patient | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors touching/pointing at tool | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors eye-gaze toward tool | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median Patients eye-gaze toward tool | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median consultation times | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median clinician verbal dominance in 10 minutes preceding decision | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors information-seeking | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors pause | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median patients negative talk | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors nodding | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors head shake | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors smiling | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors point at the patient | −
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors touching/pointing at tool | 0
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors eye-gaze toward tool | +
Kaner, 2007^33^ | Clinical decision aids, shared decisionmaking tools | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median patients eye-gaze toward tool | +
Kucher, 2005^34^ | Clinical decision aids, education via IT | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | Prophylactic measures were ordered | +
Kucher, 2005^34^ | Clinical decision aids, education via IT | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | mechanical prophylaxis | +
Kucher, 2005^34^ | Clinical decision aids, education via IT | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | pharmacologic prophylaxis | +
Lowensteyn, 1998^35^ | Information exchange | Computerized coronary risk profile to physician vs. no profile risk to physician | ratio of high risk / low risk patients returning for followup | +
McCrossan, 2007^41^ | Telemedicine | Videoconferencing for children with congenital heart disease vs. teleconferencing | Proportion concern about video conferencing by parents | +
McCrossan, 2007^41^ | Telemedicine | Videoconferencing for children with congenital heart disease vs. teleconferencing | Proportion no action needed for video conferencing | +
McCrossan, 2007^41^ | Telemedicine | Videoconferencing for children with congenital heart disease vs. teleconferencing | Proportion inform consultant about video conferencing | +
McCrossan, 2007^41^ | Telemedicine | Videoconferencing for children with congenital heart disease vs. teleconferencing | Proportion advised NHS action about video conferencing | +
Murray, 1999^39^ | IT-guided disease management | Pharmacist with access to electronic treatment suggestions via pharmacy module used by pharmacists vs. usual care | % time spent filling prescription | −
Murray, 1999^39^ | IT-guided disease management | Pharmacist with access to electronic treatment suggestions via pharmacy module used by pharmacists vs. usual care | % time spent advising or informing | +
Murray, 1999^39^ | IT-guided disease management | Pharmacist with access to electronic treatment suggestions via pharmacy module used by pharmacists vs. usual care | %time spent problem solving | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded a comprehensive heart failure assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded a diet assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded medication knowledge assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded medication adherence assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded medication side-effects assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that instructed patients about heart failure symptom, shortness of breath | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that instructed patients about heart failure symptom, fluid weight gain | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that instructed patients about heart failure symptom, fatigue | −
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that instructed patients about global heart failure symptoms | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about self weighing | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about managing fluid weight gain | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about low salt diet | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about medication management | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions about methods to improve adherence | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about self contacting an MD | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations to treat heart failure patients (basic intervention) vs. nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about education material | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded a comprehensive heart failure assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded a diet assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded medication knowledge assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded medication adherence assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that recorded medication side-effects assessment | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that instructed patients about heart failure symptom, shortness of breath | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that instructed patients about heart failure symptom, fluid weight gain | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that instructed patients about heart failure symptom, fatigue | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimate of percent of nurses that instructed patients about global heart failure symptoms | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about self weighing | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about managing fluid weight gain | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about low salt diet | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about medication management | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions about methods to improve adherence | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about self contacting an MD | +
Murtaugh, 2005^31^ | Communication via email | Nurses who received email recommendations and additional resources to treat heart failure (augmented intervention) vs. Nurses treating heart failure patients that provide usual care | Estimates of percent of nurses that recorded instructions to patients about education material | +
Noel, 2004^43^ | Electronic medical records, telemonitoring systems | Intervention patients received home telehealth units that used standard phone lines to communicate with the hospital and integrated into hospital electronic health records vs. usual home health care services plus nurse case management. | Bed-days-of-care | +
Ross, 2004^44^ | Communication via email, IT-guided self-management, electronic medical records, PHR | Participants in the intervention group were given a user identification and password to SPPARO to access electronic hospital records vs. patients in the control group continued to receive standard care in the practice | General adherence Medical Outcomes Study compliance score | +
Scherr, 2009^45^ | Telemonitoring | Participants in the intervention group received pharmacological treatment with telemedical surveillance | Re-hospitalization | +
Scherr, 2009^45^ | Telemonitoring | Participants in the intervention group received pharmacological treatment with telemedical surveillance | Length of stay | +
Scherr, 2009^45^ | Telemonitoring | Participants in the intervention group received pharmacological treatment with telemedical surveillance | Dosage management | +
Subramanian, 2004^36^ | Clinical decision aids | Physicians’ care suggestions generated with electronic medical record data and symptom data from patient questionnaires within 2 weeks of scheduled outpatient visits (intervention group) vs. physicians whose suggestions were generated with EMR data alone (control group). | Number of all clinical decisions | +
Subramanian, 2004^36^ | Clinical decision aids | | Mean all-cause hospitalizations | −
Subramanian, 2004^36^ | Clinical decision aids | | Mean admissions for heart failure | +
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions, approved by a panel of local cardiologists and general internists, were displayed to physicians and pharmacists as they cared for enrolled patients vs. control group where suggestions were withheld | Mean number of all hospitalizations | +
Tierney, 2003^37^ | IT-guided disease management | | Mean number of heart disease specific hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | Printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in Pharmacist Intervention Recording System. Vs. control group where suggestions were withheld | Mean number of all hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | Printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in Pharmacist Intervention Recording System. Vs. control group where suggestions were withheld | Mean number of heart disease specific hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions, approved by a panel of local cardiologists and general internists, were displayed to physicians and pharmacists as they cared for enrolled patients and a printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in Pharmacist Intervention Recording System vs. control group where suggestions were withheld | Mean number of all hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | | Mean number of heart disease specific hospitalizations | 0
Wakefield, 2008^42^ | Telemedicine | Videophone followup vs. usual care. Usual care subjects contacted their primary care nurse case manager by telephone if needed. Intervention subjects contacted their assigned study nurse via videophone if needed after discharge. The intervention nurses reinforced discharge plans, had full access to patient records and employed strategies to improve subjects’ adherence to prescribed treatment plans. | Percent readmitted to hospital | +

ACE: Angiotensin-Converting Enzyme, DARTS: Decision Analysis in Routine Treatment, E-mail: Electronic Mail, EMR: Electronic Medical Record, HF: heart failure, KCCQ: Kansas City Cardiomyopathy Questionnaire, MOS: Medical Outcomes Study, NHS: National Health Service, SPPARO: System Providing Access to Records Online

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

ACE: Angiotensin-converting enzyme, BMI: Body Mass Index, BP: blood pressure, HF: heart failure, KCCQ: Kansas City Cardiomyopathy Questionnaire, MOS: Medical Outcomes Study, NHS: National Health Service, SPPARO: System Providing Access to Records Online, USD: United States dollars

Table 9b Overall grade of the quality of evidence in heart disease studies addressing health care process outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | Moderate
* | Mean Jadad score^†^ | −0.43
2 | Number of studies | 14
3 | Did the studies have important inconsistency? | No
4 | Were the studies sparse? | No
5 | Overall grade of evidence | Moderate

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Table 10a Summary of the impact of health IT applications on process outcomes for patients with cancer

Study, Year | Health IT Application | Interventions Compared | Outcomes Measure | Positive Impact
Jones, 1999^46^ | IT-guided disease management, education via IT, patient portals | Personal computer based information vs. booklet information | Doctors assessment — patients above average in knowledge | +
Jones, 1999^46^ | IT-guided disease management, education via IT, patient portals | General computer information vs. booklet information | Doctors assessment- patients above average in knowledge | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Presence of pain assessed by nurse | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Medication assessment by nurse | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Mood assessment by nurse | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Educational materials delivered by nurse | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Probability of hospitalization | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Probability of emergency department use | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Home care-related costs | −
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Overall costs | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Inadequate pain management | +
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Presence of pain assessed by nurse | +
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Medication assessment by nurse | +
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Mood assessment by nurse | +
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Educational materials delivered by nurse | +
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Inadequate pain management | +
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Probability of hospitalization | +
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Probability of emergency department use | +
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Home care-related costs | −
McDonald, 2005^48^ | Communication via email | Email reminder + provider prompts +patient education + clinical nurse specialist outreach vs. usual care | Overall costs | +
Nguyen, 2000^49^ | Clinical decision aids | Cancer screening reminder system, including both manual and computerized reminders vs. usual care | Checkups | +
Nguyen, 2000^49^ | Clinical decision aids | Cancer screening reminder system, including both manual and computerized reminders vs. usual care | Smoking cessation counseling | +
Nguyen, 2000^49^ | Clinical decision aids | Cancer screening reminder system, including both manual and computerized reminders vs. usual care | Pap testing | +
Nguyen, 2000^49^ | Clinical decision aids | Cancer screening reminder system, including both manual and computerized reminders vs. usual care | Pelvic exams | +
Nguyen, 2000^49^ | Clinical decision aids | Cancer screening reminder system, including both manual and computerized reminders vs. usual care | Clinical breast exams | −
Nguyen, 2000^49^ | Clinical decision aids | Cancer screening reminder system, including both manual and computerized reminders vs. usual care | Mammography | +
Nguyen, 2000^49^ | Clinical decision aids | Cancer screening reminder system, including both manual and computerized reminders vs. usual care | Hepatitis B serologies | +
Nguyen, 2000^49^ | Clinical decision aids | Cancer screening reminder system, including both manual and computerized reminders vs. usual care | Hepatitis B immunizations | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Congruence between patient-reported symptoms and those addressed in consult visit | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Importance-weighted congruence between patient reported symptoms and those addressed in consult visit | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–10) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–15) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–20) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–25) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–30) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–40) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–50) | +

E-mail: Electronic Mail, IT: Information Technology, mHealth: Mobile Health

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

mHealth: mobile health

Table 10b Overall grade of the quality of evidence in cancer studies addressing health care process outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.75
2 | Number of studies | 4
3 | Did the studies have important inconsistency? | No
4 | Were the studies sparse? | Yes
4 | Overall grade of evidence | Moderate

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Table 11a Summary of the impact of health IT applications on process outcomes for patients with hypertension

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact
Fretheim, 2006^50^ | Clinical decision aids, IT-guided disease management | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | Thiazides prescription | +
Fretheim, 2006^50^ | Clinical decision aids, IT-guided disease management | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | CV risk assessment done | +
Fretheim, 2006^50^ | Clinical decision aids, IT-guided disease management | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | Treatment goal achieved | −
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services vs. usual care | Electronic messaging and subsequent responses | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services vs. usual care | Telephone encounters | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services and pharmacist care vs. usual care | Electronic messaging and subsequent responses | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services and pharmacist care vs. usual care | Telephone encounters | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services vs. usual care | Primary care visits | 0
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services vs. usual care | Primary care visits | 0
Hetlevik, 1998^51^ | Clinical decision aids | CDSS vs. usual care | Fractions of patients without registration of blood pressure | −
Hetlevik, 1998^51^ | Clinical decision aids | CDSS vs. usual care | Fractions of patients without registration of serum cholesterol | −
Hetlevik, 1998^51^ | Clinical decision aids | CDSS vs. usual care | Fractions of patients without registration of cigarettes | +
Hetlevik, 1998^51^ | Clinical decision aids | CDSS vs. usual care | Fractions of patients without registration of cardio vascular inheritance | −
Hetlevik, 1998^51^ | Clinical decision aids | CDSS vs. usual care | Fractions of patients without registration of BMI | +
Hetlevik, 1998^51^ | Clinical decision aids | CDSS vs. usual care | Fractions of patients without registration of risk score | +
Hicks, 2008^55^ | Clinical decision aids | Computerized support vs. usual care | Prescribing Joint National Committee adherent drug class | — no data
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit only practices vs. patients who received no feedback | All patients with no recorded blood pressure | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit only practices vs. patients who received no feedback | All patients with no recorded blood pressure | +
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Patients receiving audit plus strategic practices (patient-specific list ranking patients with risk of death from stroke) vs. patients receiving no feedback | Final proportion with controlled blood pressure in hypertensive patients | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Patients receiving audit plus strategic practices (patient-specific list ranking patients with risk of death from stroke) vs. patients receiving no feedback | All patients with no recorded blood pressure | +
Montgomery, 2000^53^ | Clinical decision aids | Risk chart alone vs. usual care | Number of patients with 0–1 classes of drugs prescribed | 0
Montgomery, 2000^53^ | Clinical decision aids | Risk chart alone vs. usual care | Number of patients with 2 classes of drugs prescribed | +
Montgomery, 2000^53^ | Clinical decision aids | Risk chart alone vs. usual care | Number of patients with >=3 classes of drugs prescribed | +
Montgomery, 2000^53^ | Clinical decision aids | CDSS plus risk chart vs. usual care | Number of patients with 0–1 classes of drugs prescribed | −
Montgomery, 2000^53^ | Clinical decision aids | CDSS plus risk chart vs. usual care | Number of patients with 3 classes of drugs prescribed | −
Montgomery, 2000^53^ | Clinical decision aids | CDSS plus risk chart vs. usual care | Number of patients with >=3 classes of drugs prescribed | −
Parati, 2009^57^ | Computer-assisted self-care, telemedicine, telemonitoring systems | Teletransmitted home blood pressure vs. usual care | Frequency of treatment changes | +
Parati, 2009^57^ | Computer-assisted self-care, telemedicine, telemonitoring systems | Teletransmitted home blood pressure vs. usual care | Health care costs | +
Parati, 2009^57^ | Computer-assisted self-care, telemedicine, telemonitoring systems | Teletransmitted home blood pressure vs. patients that received usual care | Frequency of treatment changes | +
Parati, 2009^57^ | Computer-assisted self-care, telemedicine, telemonitoring systems | Teletransmitted home blood pressure vs. patients that received usual care | Health care costs | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message and alert vs. provider who received only the email message. | Drug added | −
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message and alert vs. provider who received only the email message. | Both increased dose and drug added | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message, alert and patient education vs. provider who received only the email message | Drug added | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message, alert and patient education vs. provider who received only the email message | Both increased dose and drug added | −
Santamore, 2008^85^ | Telemedicine | Blood pressure measurements transmitted through an Internet based telemedicine system vs. not through a telemedicine system | Percent error for similarity between telemedicine recorded systolic blood pressure and recorded systolic blood pressure | Insufficient data
Santamore, 2008^85^ | Telemedicine | Blood pressure measurements transmitted through an Internet based telemedicine system vs. not through a telemedicine system | Percent error for similarity between telemedicine recorded diastolic blood pressure and recorded diastolic blood pressure | Insufficient data
Santamore, 2008^85^ | Telemedicine | Blood pressure measurements transmitted through an Internet based telemedicine system vs. not through a telemedicine system | Blood pressure monitoring | +

BMI: Body Mass Index, CDSS: Clinical Decision Support System, CV: Cardiovascular, E-mail: Electronic Mail, IT: Information Technology

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 11b Overall grade of the quality of evidence in hypertension studies addressing health care process outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.71
2 | Number of studies | 9
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | No
5 | Overall grade of evidence | Moderate

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

### Specific Findings

#### Health Care Process Outcomes in Studies Addressing Diabetes Mellitus

We identified 11 studies that evaluated the impact of health IT on process outcomes in patients with diabetes mellitus (Table 8a; Appendix G, Evidence Tables 1–4). Most showed a positive impact of health IT on process outcomes, and many of these effects were statistically significant. The study quality was high, but the quality scores were variable. The primary reasons for lower-quality scores were issues with studies not being double-blinded or not describing loss to followup. The overall grade of the strength of evidence in these studies was moderate (Table 8b; Appendix G, Evidence Tables 1–4).

In a large randomized study described by Filippi in 2003,^20^ 150 general practitioners in Italy had access to an electronic reminder system integrated into their usual clinical practice software. A control group of 150 general practitioners did not have access to the electronic reminder system. The reminder system prompted the general practitioners in the intervention group to consider prescribing an antiplatelet medication when they opened the medical records for diabetic patients 30 years old or older. The study used an intention-to-treat approach, and included the selected general practitioners whether or not they chose to activate the system. After 7 months, patients not at high risk for cardiovascular disease who were treated by general practitioners in the intervention group were 1.99 (95% confidence interval [CI] 1.79 to 2.22) times more likely to have been prescribed an antiplatelet drug than were similar patients whose physicians were in the control group (Table 8a; Appendix G, Evidence Table 4).

A study published by Hetlevik in 2000^21^ described a computerized decision support system accessible from the record system that 24 physicians in Norway used for 18 months. This system contained diagnostic and therapeutic modules that guided doctors in the diagnosis and management of patients with diabetes, hypertension, and hypercholesterolemia (although the article only discussed patients with diabetes). Physicians only used the system for 14 percent of the eligible patients, and while it did result in significantly increased notations about patients’ smoking status and cardiac risk scores, the rates of increase in notations about patients’ glycated hemoglobin (HbA1c), cholesterol, and cardiovascular risk inheritance were not statistically significant (Table 8a; Appendix G, Evidence Table 4).

Sequist (2005)22 described a 7-month trial where the intervention group used a patient data-specific electronic reminder system embedded in electronic medical records. The control group received usual care. A composite score (based on adherence to five measures of diabetes care) increased after implementation of the IT intervention; however, this increased score was attributable only to an increased hazard ratio of 1.41 (95% CI 1.15 to 1.72) for performing an annual cholesterol exam. Hazard ratios did not significantly increase in the intervention group for performance of a biennial HbA1c test or annual dilated eye exam, use of an angiotensin-converting enzyme inhibitor in hypertensive patients, or use of a statin in patients with a low-density lipoprotein (LDL) cholesterol ≥ 130 mg/dL (Table 8a; Appendix G, Evidence Table 4).

Thomas (2007)23 studied the effects of quarterly feedback and patient-specific reminders from a computerized diabetes registry integrated with a clinical information system used by 78 internal medicine residents. Residents in the control group did not receive any computerized reminders. Patients cared for by physicians in the intervention group were more likely to have an HbA1c measurement within 6 months (61.5% vs. 48.1%, p=0.01), or an LDL cholesterol measurement within 12 months (75.8% vs. 64.1%, p=0.02) (Table 8a; Appendix G, Evidence Table 4).

A 2008 study by Persell and colleagues,24 provided all physicians with a reminder to prescribe aspirin when they opened the electronic records for diabetic patients greater than 40 years of age who were not on aspirin. The study sent an additional email recommending aspirin prescription to the physicians of only 130 intervention patients; if deemed appropriate by the physician, patients received a letter and a phone call from a nurse advising aspirin use. Aspirin use did not significantly increase in the intervention group (46% vs. 39%, p=0.20) (Table 8a; Appendix G, Evidence Table 4).

A 3-year study, described by Ziemer (2006),25 randomized 345 internal medicine residents to be controls or to receive patient-specific computerized recommendations and/or biweekly feedback on care performance for patients in the Grady Medical Clinic. Care for patients with elevated glucose levels increased to the greatest extent in the first year, and most significantly in the two groups receiving performance feedback, as opposed to the group receiving computerized recommendations alone (Table 8a; Appendix G, Evidence Table 4).

A cellular phone-based diabetes-management system described by Quinn (2008)26 coached patients about glucose monitoring and diabetes control and provided feedback about blood glucose levels to physicians for 15 patients over 3 months. Patients using the system were more likely than patients in the control group to have their diabetes medications intensified (84.6% vs. 23.3%, p=0.002) and more likely to have medication errors identified (53.4% vs. 0%, p=0.002). Providers for these patients were also more likely to receive patients’ glucose readings (100% vs. 7.7%, p<0.001) (Table 8a; Appendix G, Evidence Table 4).

A “virtual consultation” was provided by an endocrinologist for 358 diabetic patients via telemedicine and email in a 2008 study by Smith and colleagues.27 The control group received no “virtual consultation.” In the 12-month followup period, aspirin use increased (odds ratio [OR] 1.99, 95% CI 1.31 to 3.02), and more patients were noted to be not smoking or to have been advised to quit smoking (OR 1.80, 95% CI 1.04 to 3.13). However, there were no significant differences in the odds of being prescribed an angiotensin-converting enzyme inhibitor, angiotensin receptor blocker, or statin, or in the frequency of office visits, referrals for endocrine consultation, or visits and calls with the diabetes educator (Table 8a; Appendix G, Evidence Table 4).

Gomez (2002)28 described an intervention using a telemedicine system facilitating communication between patients and their care providers. They conducted a 6-month crossover pilot study with 10 type 1 patients with diabetes. During the telemedicine period, providers performed more therapeutic medication changes (2.9 vs. 0.2) (Table 8a; Appendix G, Evidence Table 4).

In the Diabetes Priority Program described by Glasgow (2000);29 that enrolled 417 patients, the intervention group used a computerized touch screen assessment and action planning procedure prior to two diabetes-related visits, at 6 and 12 months. Their physicians were given a printout describing the patients’ self-management goals and needs assessments. Patients in the intervention group reported having received more “lab procedures” (blood pressure evaluation, dilated eye exam, foot exam, microalbumin or HbA1c testing) during the study (4.29 procedures vs. 4.01, p=0.001). They also reported completion of more patient-centered activities (goal-setting, medical nutrition treatment, self-monitoring blood glucose, meeting patient satisfaction items): 3.74 vs. 3.31, p<0.001 (Table 8a; Appendix G, Evidence Table 4).

A study described by Ralston (2009)30 randomized 39 patients to receive Web-based care management for 22 months, including electronic access to medical records, secure electronic messaging with providers, and feedback on blood glucose readings. The control group received usual care. No significant difference was found between intervention and control groups in the number of primary care or specialty physician visits or the number of days spent hospitalized (Table 8a; Appendix G, Evidence Table 4).

#### Health Care Process Outcomes in Studies Addressing Heart Disease

Fifteen studies evaluated the impact of health IT on process outcomes in patients with heart disease other than hypertension (Table 9a; Appendix G, Evidence Tables 1–3 and 5). Most showed a positive impact of health IT on process outcomes, and many of these results were statistically significant. Study quality was moderate. The primary reasons for lower quality scores were issues with studies not being double-blinded or not describing loss to followup. The overall grade of the strength of evidence in these studies was moderate (Table 9b; Appendix G, Evidence Tables 1–3 and 5).

An article by Murtaugh (2005)31 reported on a study randomizing home health nurses for patients with heart failure to either usual care (n=122), a one-time email reminder highlighting heart failure recommendations (n=114), or an augmented intervention of email plus additional prompts, educational material, and outreach by a nurse specialist (n=118). For the basic email intervention, significantly more nurses recorded a comprehensive heart failure assessment and assessment of medication adherence and also documented instruction about shortness of breathe as a symptom. They were also more likely to document instructing patients to weigh themselves, consume a low-salt diet, and use methods to improve adherence with recommended therapy. For the augmented intervention, significantly more nurses recorded a comprehensive heart failure and diet assessment and assessed medication side effects. They were significantly more likely than usual care nurses to instruct patients about the symptom of fluid weight gain and to give global instruction about signs and symptoms. They also were more likely to document instructing patients to weigh themselves, to consume a low salt diet, to contact a physician for certain circumstances, and to provide educational material. Other findings also favored the basic and augmented interventions, but these differences were not significant (Table 9a; Appendix G, Evidence Table 5).

Feldman (2005)32 studied the effects of an email to the homecare nurses for 628 outpatients with heart failure; the email highlighted heart failure recommendations, with or without additional educational materials. Home care-related and overall costs per patient were higher for patients in the intervention groups than for a group not receiving email about heart failure recommendations, but this difference was only significant for patients whose nurses received the additional materials (Table 9a; Appendix G, Evidence Table 5).

In Kaner (2007),33 verbal and non-verbal behaviors were compared for providers using paper-based guidelines versus a computer-based decision aid to discuss the use of warfarin with 29 patients who had atrial fibrillation. Consultation times were significantly greater for providers using the computer-based tool, and these providers spent significantly less time seeking information from patients and more time pausing, nodding, and gazing at the tool (Table 9a; Appendix G, Evidence Table 5).

Kucher (2005)34 reported on the effects of a computer program designed to identify patients who were at risk for deep venous thrombosis and not on prophylaxis. The providers for 1,255 of these patients were randomly assigned to receive or not receive a computerized alert about patient risk. Significantly more intervention patients received mechanical (10.0 vs. 1.5%, p<0.001) or pharmacologic (23.6 vs. 13.0%, p<0.001) prophylaxis (Table 9a; Appendix G, Evidence Table 5).

A study by Lowensteyn in 1998^35^ randomized 253 providers for 958 patients to either receive early post-visit, patient-specific, computerized coronary risk profiles or standard notification. Intervention patients were significantly more likely to return for followup (1.23 vs. 0.77, p<0.05) (Table 9a; Appendix G, Evidence Table 5).

Subramanian’s 2004 study36 randomized physicians to either receive patient-specific care suggestions based on electronic medical record data and patient symptom reports, or care suggestions based only on electronic medical record data, for a total of 720 patients. There were no significant differences in physician adherence to care suggestions at 12 months between the two groups. The intervention patients had more all-cause hospitalizations at 6 and 12 months; however, there were no significant differences between the two groups in terms of congestive heart failure and congestive heart failure-related hospitalizations (Table 9a; Appendix G, Evidence Table 5).

Tierney’s 2003^37^ study randomized physicians and pharmacists caring for 706 outpatients with heart failure and/or ischemic heart disease to receive or not receive evidence-based care suggestions. No significant differences were found between intervention and control groups in the number of patients with care that was compliant with recommendations, hospitalizations for any cause, or heart disease-specific hospitalizations (Table 9a; Appendix G, Evidence Table 5).

The randomized, prospective study by Bailey (2007)38 used computerized alerts identifying inpatients with troponin levels greater than 1.4ng/ml within the first 24 hours of hospitalization; pharmacists were notified via email and then conducted academic detailing with the physicians caring for 365 intervention patients. As compared to standard care, the intervention patients were significantly more likely to be discharged on angiotensin-converting enzyme inhibitors and statin drugs (p<0.01); they were also more likely to be discharged on beta blockers, but this finding was not significant (Table 9a; Appendix G, Evidence Table 5).

A study described by Murray (1999)39 randomized 28 pharmacists at a hospital-based outpatient pharmacy to receive or not receive telehealth for heart failure, ischemic heart disease, reactive airways disease, and hypertension. Pharmacists in the intervention group spent significantly less time filling prescriptions, and significantly more time advising or informing patients or problem solving (Table 9a; Appendix G, Evidence Table 5).

Research described in the article by Jerant (2001)40 compared usual care for 12 recently hospitalized patients with heart failure to that of 13 patients receiving video-based, home telehealth and 12 receiving telephone care. As compared to the usual care group, the mean heart failure-related readmission charges were 86 percent lower in the telehealth group and 84 percent lower in the phone group, but these differences were not significant. Both intervention groups had significantly fewer heart failure-related emergency department visits than did those receiving usual care (Table 9a; Appendix G, Evidence Table 5).

A randomized study by McCrossan (2007),41 compared videoconferencing, teleconferencing, and usual care in 66 children at home with a new diagnosis of congenital heart disease. Parents of children receiving videoconferencing had more calls and longer calls than those with telephone care, but neither of these findings was significant. The rates at which particular concerns were raised were similar between the two groups, but more videoconferences resulted in an assessment that no action was needed or that the consultant should be informed, whereas phone conferences resulted in more referrals to the family doctor, emergency department, or inpatient cardiology ward; this last finding was statistically significant (Table 9a; Appendix G, Evidence Table 5).

A study by Wakefield (2008)42 compared videophone, telephone, and usual care in 148 patients after hospitalization for heart failure. The time to readmission was significantly longer in the intervention group, but the readmission rate itself was not significantly different, and hospital days and urgent care clinic use were not significantly affected (Table 9a; Appendix G, Evidence Table 5).

Another study examining telehealth, Noel (2004),43 randomized 104 patients with complex heart failure, chronic lung disease, and/or diabetes to receive either usual care or home telehealth for 6–12 months; the intervention patients also had at-home vital-sign monitoring. Telehealth patients had a significant decrease at 6 months in bed days of care (p<0.0001) and urgent clinic/emergency room visits (p=0.023) (Table 9a; Appendix G, Evidence Table 5).

Ross (2004)44 described the effects of giving 54 of 107 outpatients with heart failure a combination of online access to their medical records, an educational guide, and a messaging system with clinic staff. Intervention patients had significantly higher compliance scores (p=0.01) (Table 9a; Appendix G, Evidence Table 5).

Scherr (2009)45 described the effects of a telemonitoring system on heart disease patients in a randomized sample of 120 patients. Process outcomes of interest included re-hospitalization, system availability, system transmissions, length of stay, and dosage management. Fifty-four patients were randomized to the intervention. Intervention patients who were hospitalized had a shorter length of stay (p=0.04) than the control group (Table 9a; Appendix G, Evidence Table 5).

#### Health Care Process Outcomes in Studies Addressing Cancer

We identified four studies that evaluated the impact of health IT on process outcomes in patients with cancer; each showed almost exclusively positive effects, and a sizable number of these effects were statistically significant (Table 10a; Appendix G, Evidence Tables 1–3 and 6). Study quality was high, but the scores were variable. The primary reasons for lower-quality scores were issues regarding loss to followup. The overall grade of the strength of evidence in studies of health care process outcomes addressing cancer was moderate (Table 10b; Appendix G, Evidence Table 6).

A study by Jones (1999)46 offered 169 patients a personalized “consultation” about their condition using a touch screen computer, 167 patients general computer-based information about cancer, and another 180 access to booklets about various types of cancer. More patients who received personalized computer information indicated that they would prefer the computer to a 10-minute consultation with a physician and that they had used printed materials generated by the program at home. Physicians assessed more patients to be above average in knowledge in the group given general computerized information (35%) than in the group given a personalized consultation (25%) or booklets (20%) (p=0.01) (Table 10a; Appendix G, Evidence Table 6).

A study by Ruland (2003)47 examined the effects of the computerized patient support system CHOICES: Creating better Health Outcomes by Improving Communication about Patients’ Experiences with 27 of 52 patients with various cancer diagnoses. The study showed improved congruence between patient-reported symptoms and those addressed in a consult visit (Table 10a; Appendix G, Evidence Table 6).

McDonald (2005)48 studied documentation by home care nurses caring for cancer patients with pain. Intervention nurses received either a patient-specific, one-time email (121 subjects) or an email plus supplemental education material and specialist nurse outreach (97 subjects) when eligible patients were enrolled in home care. The control group received usual care. While the basic and augmented interventions had positive effects on nurse documentation of the presence of pain, medication assessment, mood assessment, and the provision of instruction about medication management and education materials, none of these differences were significant. Nurses in the basic intervention group had a slightly lower probability of documenting bowel function (89.0%) than did control nurses (94.7%), (p=0.02). Cost differences between the three groups were not statistically significant (Table 10a; Appendix G, Evidence Table 6).

A study by Nguyen and colleagues in 2000^49^ randomized 20 Vietnamese physicians to receive computerized or manual cancer screening reminders and educational materials, or no intervention. The duration of the intervention was 3 years. The study saw positive effects on rates of routine checkup performance, clinical breast exams, mammography, hepatitis B testing, and hepatitis B immunization; however, the study saw statistically significant improvement only for performance of smoking cessation counseling (p=0.02), Pap testing (p=0.004), and pelvic examinations (p=0.01) (Table 10a; Appendix G, Evidence Table 6).

#### Health Care Process Outcomes in Studies Addressing Other Targeted Care Focus Areas

After diabetes, heart disease, and cancer, the next most commonly targeted care focus areas were hypertension, asthma, mental health, and smoking cessation (Table 5).

##### Hypertension

Nine studies evaluated the impact of health IT on process outcomes in patients with hypertension. Study quality was high, and quality scores were consistent across studies (Table 11a; Appendix G, Evidence Table 7). The overall grade of the strength of evidence in studies of health care process outcomes addressing hypertension was high (Table 11b; Appendix G, Evidence Table 7). Eight of those studies that we deemed significant are outlined below.

Freitheim (2006)50 randomized 146 general practices to an intervention or control group for the care of patients with preexisting or newly treated hypertension or hypercholesterolemia. Intervention physicians received educational visits from pharmacists and patient-specific computerized reminders linked to the medical record system. Thiazide prescriptions increased significantly for the intervention patients; however, there was no difference in the percentage of patients who had cardiac risk assessments performed or whose treatment goals were achieved (Table 11a; Appendix G, Evidence Table 7).

A study described in Hetlevik (1998)51 randomized physicians for 2,239 patients with hypertension to either use or not use a diagnostic and therapeutic decision support system. The study revealed no significant difference in the percentage that had registered blood pressure or cholesterol levels between the intervention and control groups during 12 months of followup. Similarly, there was no difference between the percentages that had recorded smoking status, cardiovascular inheritance, or body mass index (BMI) at 18 months (Table 11a; Appendix G, Evidence Table 7).

A study by Roumie (2006)52 randomized the providers for 1,341 Tennessee veterans with hypertension on a single agent to receive either an email with Joint National Commission version 7 guidelines, the email plus patient-specific computerized alerts, or the email, alerts, and patient education. No significant differences were found between the percentages of patients in each group that had a dose increase, a drug added, or any change in antihypertensive medication (Table 11a; Appendix G, Evidence Table 7).

Montgomery (2000)53 reported on a study that randomized 614 hypertensive patients to receive either usual care, a cardiac risk chart, or integrated patient-specific decision support and a cardiac risk chart. The primary outcomes were cardiac risk reduction and blood pressure control. Only the patients who received just the cardiac risk chart had significantly more cardiovascular drugs prescribed. The chart-only group was twice as likely to be prescribed two classes of cardiovascular drugs and more than three times as likely to be prescribed three or more classes of drugs than were the other groups (Table 11a; Appendix G, Evidence Table 7).

A study described by Mitchell (2004)54 randomized 52 practices with 265,572 patients in Scotland to receive provider feedback based on general electronic medical record audits, or to receive patient-specific (“strategic”) feedback or neither. The greatest increase in the number of patients with blood pressure recorded was in the general audit group (Table 11a; Appendix G, Evidence Table 7).

Hicks and colleagues (2008)55 conducted a study that randomized the providers for 2,027 adult patients with hypertension to receive either 18 months of computerized patient-specific decision support recommendations or usual care. Intervention providers had significantly increased rates of Joint National Committee guideline-adherent prescribing, although the rates remained extremely low (7% vs. 5%, p<0.001) (Table 11a; Appendix G, Evidence Table 7).

Green (2008)56 randomized 778 patients with uncontrolled hypertension and Internet access to receive either: usual care; home blood pressure monitoring and secure patient Web training; or home blood pressure monitoring, secure Web training, and pharmacist management via Web communications. The primary outcome was blood pressure control; however, the number of medications taken by the two intervention groups was significantly greater than that for individuals receiving usual care, and those in the pharmacist group also had significantly higher aspirin use. The number of primary care visits did not differ among the three groups (Table 11a; Appendix G, Evidence Table 7).

A study described by Parati (2009)57 randomized 329 patients with hypertension to receive either usual care or home blood pressure telemonitoring. The intervention patients required significantly fewer treatment changes than did the patients receiving usual care (Table 11a; Appendix G, Evidence Table 7).

##### Asthma

Six studies evaluated the use of health IT in asthma care (Appendix G, Evidence Tables 1–3). Eccles (2002)58 examined the effects of providing caregivers with computerized guidelines for the management of asthma; there was no significant effect on the odds of assessing lung function, assessing inhaler technique, checking compliance, recording smoking status, or providing asthma education. There was also no difference in the prescription rates of certain asthma medications (Appendix G, Evidence Table 3).

Shiffman (2000)59 studied the use of a handheld device in practitioners’ offices that provided structured encounter documentation and offered recommendations for care. Documentation regarding peak expiratory flow rate (PEFR), oxygen saturation measurements, and nebulization treatments was significantly increased during the intervention period.

Taylor (2008)60 found that an electronic decision support tool for patients with an asthma flare in an emergency department resulted in significantly higher rates of documentation in seven out of 10 variables (Appendix G, Evidence Table 3).

Chan (2003)61 examined the effect of an Internet-based home-telehealth education, peak flow, and video-assessment system on patient symptoms and adherence in a 10-patient pediatric study. Inhaler technique improved significantly for those children in the intervention group (Appendix G, Evidence Table 3).

Kattan (2006)62 used phone calls to children’s caretakers to generate computerized letters to their providers about the children’s symptoms, health service use, and medication use, along with treatment recommendations. Significantly more children in the intervention group kept their scheduled appointments and had their asthma medications appropriately stepped up (Appendix G, Evidence Table 3).

Finally, a study by Krishna (2003)63 focused on using the Internet to educate children about their asthma and resulted in significant improvements in a process outcome—visits to the emergency department (Appendix G, Evidence Table 3).

##### Mental Health

Three eligible studies targeted the use of health IT in treatment of mental health conditions (see Appendix G, Evidence Tables 1–3). Two used computerized decision support to improve screening, diagnosis, and/or treatment for psychiatric conditions, Cannon (2000)64 and Rollman (2002)65. However, only Cannon64 found significant improvements in screening rates for mood disorders, and complete documentation of diagnostic criteria. One used electronic surrogates for psychiatric care, Marks (2004)66. This study found a significant decrease in clinician time when randomized patients received computerized self-exposure therapy for their phobia or panic disorder, without any decline in symptom improvement or treatment satisfaction (Appendix G, Evidence Table 3).

##### Smoking Cessation

Three studies evaluated the use of smoking cessation addressing health care process outcomes; each used electronic medical record-embedded decision support to improve smoking care by outpatient providers (see Appendix G, Evidence Tables 1–3).

Linder (2009)67 is a large (132,630-patient) study that found significant improvement in documentation of smoking status and rates of contact with a cessation counselor but no difference in the likelihood of being prescribed smoking cessation medication.

Wolfenden (2005)68 found that intervention patients were more likely to report receiving brief smoking advice by nurses and anesthesiologists and to report being prescribed postoperative nicotine replacement therapy at a preoperative clinic (Appendix G, Evidence Table 3).

Bentz (2007),69 found that electronic health record-documented rates of advising, assessing, and assisting smokers increased significantly in intervention clinics (Appendix G, Evidence Table 3).

There were one or two studies addressing health care process outcomes that focuseed on a number of other conditions (Table 5 and Appendix G, Evidence Table 3).

### How Does the Impact on Process Outcomes Vary by Type of Health IT Application?

Table 12 summarizes how health care process outcomes vary according to the type of health IT application described in Chapter 2. The analysis demonstrated that, among all reviewed health IT applications that address components of PCC, telehealth applications and care management tools were most frequently cited as having a positive impact on at least one health care process outcome. Although there were fewer studies examining the other three types of health IT, these other types of health IT applications had at least one statistically significant positive outcome in the majority of studies.

Table 12 The impact on health care process outcomes by type of health IT application

Health IT Type | Number of Studies | Studies With at Least 1 Outcome Having a Positive Impact, n (%) | Studies With at Least 1 Outcome Having a Statistically Significant Positive Impact, n (%)
Care management tools | 22 | 20 (91) | 16 (73)
Telehealth | 28 | 25 (89) | 16 (57)
PHR/patient portals | 12 | 11 (92) | 9 (75)
Secure electronic messaging | 9 | 8(89) | 6 (67)
Shared decisionmaking | 2 | 2(100) | 2(100)

IT: Information Technology, PHR: Personal Health Record

## Key Question 1b Are health IT applications that address one or more components of PCC effective in improving clinical outcomes for patients, and how do these improvements vary by type of health IT application?

### General Study Characteristics

We identified 92 articles evaluating how health IT applications that address PCC affect clinical outcomes. The most commonly targeted clinical conditions were heart disease, diabetes, asthma, obesity, mental health, chronic obstructive pulmonary disease and cancer (Table 13). The health IT applications most commonly employed were clinical decision aids, IT-guided disease-management, telemonitoring systems, IT-guided self-management, and social networking/peer-to-peer sites (Table 14). The PCC components most commonly addressed were patient engagement in their care, quality improvement, quality and safety, and integrated care (Table 15). The study results suggested clinical outcomes generally improve with health IT applications that address one or more components of PCC.

Table 13 Studies addressing the effect of health IT applications on clinical outcomes in specific target conditions, target populations, and care focus areas

Target Care Focus Area | N (Specific Reference)
Diabetes mellitus | 21^21^ 23 26–30 43 198–209 247
Heart disease | 16^34–37^ 40 42–45 52 53 76 119 212 213 248
Cancer | 4 47 48 215 216
Hypertension | 8^50^ 54–57 144 217 218
Asthma | 9^60^ 62 63 220 221 59 137 183 222
Obesity | 7^230–236^
Mental health | 6^224–227^ 228 229
Medications and adverse drug events | 5^100^ 241–244
COPD and chronic lung disease | 4^88^ 89 180 249
Acute respiratory distress syndrome | 149 250
Spinal cord injury | 2^118^ 240
Chronic conditions/health problems | 4^96^ 237 239 251
Hyperlipidemia | 1^104^
Infectious disease | 1^105^
Endocrinology/Bone metabolism | 1^108^
Dental disease | 1^245^
Obstetrics and gynecology | 1^246^
Physical therapy | 1^252^
Polypharmacy | 1^150^

COPD: Chronic Obstructive Pulmonary Disease, IT: Information Technology

Table 14 Studies addressing the effect of health IT applications on clinical outcomes

Type of Health IT Application | N (Specific References)
Care Management Tools
Clinical decision aids | 23^21^ 23 27 29 34 36 50 55 58–60 100 104 105 111 112 119 218 220 221 223 226 244
IT-guided disease management | 19^26^ 50 56 119 247 29 37 54 58 59 89 108 202 203 227 228 96 225 231
IT-guided self-management | 14^198^ 199 204 253 63 202 222 225 228 232 233 235 238 254 229
Computer-assisted self-care | 11^23^ 57 207 228 89 213 225 230 231 234 245
Electronic medical records | 10^30^ 60 112 247 255 43 54 104 108 220
Computerized provider order entry | 3^241–243^
Disease registry | 1 23
Electronic prescribing | 1 243
Telehealth
Telemonitoring systems | 18^30^ 40 43 45 56 57 61 204–206 208 212 217 222 228 240 241 256
Personal Health Record and Patient Portal Related Applications
Education via information technology | 6^30^ 34 56 235 245 46 63
mHealth | 7^26^ 206 244 256 59 61 47
Interactive lifestyle counseling | 6^199^ 224 234 235 230 232
Personal health records | 4 206 237 247 256
Secure Electronic Messaging
Social networking/peer-to-peer sites | 15^28^ 57 62 88 117 118 201 207 208 248 257 200 203 225 240.
Communication via e-mail | 10^27^ 30 32 56 247 48 104 217 235 236
Information exchange | 5^159^ 166 210 83 219

E-mail: Electronic Mail, IT: Information Technology, mHealth: Mobile Health

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 15 Studies addressing the effect of health IT applications on clinical outcomes, broken down by specific components of PCC

Component of PCC | N (Specific References)
Coordination and Integration of Care
Quality improvement | 39^21^ 57 59 62 63 70 72 74 77 80 89 108 112 117 141 161 183 199–201 205 208 212 222 223 227 230 234–236 239 240 242 243 248 249 253 258–260
Quality and safety | 22^27^ 45 46 88 89 96 201–203 217 224 229 230 232 233 240 244–247 254 257 258
Integrated care | 17^30^ 48 55 59 100 108 202 203 207 208 212 217 223 224 231 234 244 253 261
Prevention and health promotion | 9^56^ 105 117 199 206 207 236 255 262 231
Routine patient feedback to the practice | 6^40^ 46 47 63 111 221 227
Transition and continuity of care | 5^119^ 235 236 240 253
Whole-Person Orientation
Alleviation of fear and anxiety | 8^26^ 30 50 55 57 58 225 228
Respecting patients values, preferences and needs | 5^23^ 243 247 47 225
Emotional component | 3^47^ 228 237
Exploring the disease and illness condition | 2^111^ 228
Physical comfort | 1^117^
Enhanced Clinician-Patient Relationship
Patient engagement in their care | 37^76^ 83 84 86 130 135 140 146 150 153–155 159 167 173 180 189 191 210 211 214 219 251 252 263–276
Patient empowerment | 14^23^ 29 40 50 55 56 58–60 112 204 225 229 255
Finding common ground | 1 23
Clinical Information Systems
Publicly available information on practices | 1 26
Practice-based learning | 1 242
Socio-Cultural Competence
Community outreach | 3 28 212 245
Family and friend involvement in care | 2^59^ 119

IT: Information Technology, PCC: Patient-Centered Care

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

### Specific Findings

#### Clinical Outcomes in Studies Addressing Diabetes Mellitus

Twenty-one studies examined the impact of health IT use on clinical outcomes related to diabetes mellitus (Table 16a; Appendix G, Evidence Tables 8–11). The study quality was high, but the study quality scores were somewhat variable. The primary reasons for lower-quality scores were issues with studies not being double-blinded or not describing loss to followup. The overall grade of the strength of evidence in studies of clinical outcomes addressing diabetes mellitus was moderate (Table 16b; Appendix G, Evidence Tables 8–11).

Table 16a Summary of the impact of health IT applications on clinical outcomes for patients with diabetes mellitus

Study, Year | Health IT Application | Intervention Compared | Outcome Measures | Positive Impact^*^
Benhamou, 2007^205^ | Telemonitoring systems | Weekly medical support through SMS based upon weekly review of glucose values vs. patients downloading SMBG values on a weekly basis without receiving SMS | Glycemia (mg/dL) | 0
Benhamou, 2007^205^ | Telemonitoring systems | Weekly medical support through SMS based upon weekly review of glucose values vs. patients downloading SMBG values on a weekly basis without receiving SMS | HbA1c | 0
Cadario, 2007^206^ | mHealth, PHR, telemonitoring systems | Glucobeeb, a Web-based tool to support the diabetes care vs. patients who did not use Glucobeeb | Median HbA1c percentage | +
Cadario, 2007^206^ | mHealth, PHR, telemonitoring systems | Glucobeeb, a Web-based tool to support the diabetes care vs. patients who did not use Glucobeeb | Median HbA1c percentage | +
Farmer, 2005^207^ | Computer-assisted self-care, telemedicine | Clinical advice from a diabetes specialty nurses in response to real-time blood glucose readings vs. patients who received minimal feedback from nurses | Mean HbA1c level | +
Farmer, 2005^207^ | Computer-assisted self-care, telemedicine | Clinical advice from a diabetes specialty nurses in response to real-time blood glucose readings vs. patients who received minimal feedback from nurses | Proportion of transmitted blood glucose tests in the hypoglycemic range | +
Farmer, 2005^207^ | Computer-assisted self-care, telemedicine | Clinical advice from a diabetes specialty nurses in response to real-time blood glucose readings vs. patients who received minimal feedback from nurses | Proportion of participants achieving an HbA1c reduction of >=0.7 % and an HbA1c ≤ 8.0 % at 9 months | +
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | Telephone followup vs. the basic intervention condition received by all participants involving a meeting with a health counselor at a central location and having specific dietary goals set with the aid of a multimedia touch screen computer | HbA1c | −
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Total cholesterol | +
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Weight | 0
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Lipid ratio: total/HDL | +
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Diabetes intrusiveness | −
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | Community resources vs. the basic intervention condition received by all participants involving a meeting with a health counselor at a central location and having specific dietary goals set with the aid of a multimedia touch screen computer | HbA1c | 0
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Total cholesterol | +
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Weight | −
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Lipid ratio: total/HDL | +
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Diabetes intrusiveness | −
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | Telephone followup support and community resources vs. the basic intervention condition receiving by all participants involved a meeting with a health counselor at a central location and having specific dietary goals set with the aid of a multimedia touch screen computer | HbA1c | −
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Total cholesterol | +
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Weight | −
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Lipid ratio: total/HDL | +
Glasgow, 2000^199^ | IT-guided self-management, interactive lifestyle counseling | | Diabetes intrusiveness | −
Glasgow, 2005^29^ | Clinical decision aids, IT-guided disease management | Touch screen treatment components, physician goal setting. care manager meetings and followup phone calls vs. a touch screen computer assessment that focused on general health risks but did not address the Provider Recognition Program measures | HbA1c | −
Glasgow, 2005^29^ | Clinical decision aids, IT-guided disease management | | Ratio of total cholesterol to HDL cholesterol | −
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management | Tailored self-management vs. computer-aided enhanced usual care | Hba1c (%) | +
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management | Tailored self-management vs. computer-aided enhanced usual care | Total cholesterol/HDL cholesterol | 0
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management | Tailored self-management vs. computer-aided enhanced usual care | Total cholesterol | +
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management | Tailored self-management vs. computer-aided enhanced usual care | HDL cholesterol | +
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management | Tailored self-management vs. computer-aided enhanced usual care | Weight | +
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management | Tailored self-management vs. computer-aided enhanced usual care | Patient Health Questionaire-9 total score | 0
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management | Tailored self-management vs. computer-aided enhanced usual care | Diabetes Distress Scale | +
Gomez, 2002^28^ | Telemedicine | Usual care vs. a telemonitoring system designed to make the patients’ self-monitring data available to caregivers | Median HbA1c Level | +
Grant, 2008^247^ | Communication via email, IT-guided disease management, electronic medical records, information exchange, PHR | Web-based PHR that imported clinical and medications data, provided patient- tailored decision support, and enabled the patient to author a “Diabetes Care Plan” for electronic submission to their physician prior to upcoming appointments vs. PHR that updated and submitted family history and health maintenance information | Diabetes treatement regimine adjustments | +
Grant, 2008^247^ | Communication via email, IT-guided disease management, electronic medical records, information exchange, PHR | | Followup visits | +
Grant, 2008^247^ | Communication via email, IT-guided disease management, electronic medical records, information exchange, PHR | | HbA1c levels | 0
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Body mass index | −
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Systolic blood pressure | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Diastolic blood pressure | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | HbA1c | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Fasting glucose | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Cholesterol | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | HDL | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | LDL | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Triglyceride | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Creatinine | −
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | Average HbA1c in registered patients | +
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | Systolic blood pressure in registered patients | +
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | Diastolic blood pressure in registered patients | +
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | Serum cholesterol in registered patients | +
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | BMI in registered patients | −
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | Coronary heart disease risk score (female) | −
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | Coronary heart disease risk score (male) | −
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | Percentage of registered patients who are smokers | NR
Hetlevik, 2000^21^ | Clinical decision aids | CDSS vs. pre-existing routines for treatment for physicians of diabetes mellitus patients | Percentage of registered patients with CV inheritance | NR
Homko, 2007^203^ | IT-guided disease management, telemedicine | Internet exchange of blood glucose and other health data to care providers and advice to patients vs. blood glucose and other health data recorded in a logbook, which was reviewed by the medical team at prenatal visit | Percent of patients requiring diabetes therapy (Diet) | +
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Percent of patients requiring diabetes therapy (Glyburide) | +
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Percent of patients requiring diabetes therapy (Insulin) | −
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Fasting blood sugar | −
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Hba1c at delivery | +
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Maternal mean blood glucose | −
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Cesarean delivery | 0
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Premature rupture of membranes | +
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Placental abruption | −
Homko, 2007^203^ | IT-guided disease management, telemedicine | | Pre-eclampsia/gestational hypertension | −
Laffel, 2007^204^ | IT-guided self-management, telemonitoring systems | Integrated glucose meters and electronic logbooks (electronic group) vs. paper log books (control group) | Mean decrease in HbA1c | +
Montori, 2004^208^ | Telemedicine, telemonitoring systems | Telehealth (glucometer transmission with feedback) vs. glucometer transmission without feedback | Mean HbA1c Level | +
Montori, 2004^208^ | Telemedicine, telemonitoring systems | Telehealth (glucometer transmission with feedback) vs. glucometer transmission without feedback | Proportion of patients with HbA1c with HbA1c ≤0.7% after 6 months | +
Noel, 2004^43^ | Telemedicine | Home telehealth that used standard phone lines to communicate with the hospital and integrate with hospital electronic health record system vs. usual home health care services and nurse case management | Bed-days-of-care | +
Noel, 2004^43^ | Telemedicine | | Urgent clinic/emergency room visits | +
Noel, 2004^43^ | Telemedicine | | HbA1c | +
Noel, 2004^43^ | Telemedicine | | Cognitive status | +
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | Depression Score | +
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | Anxiety Score | −
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | Self-efficacy Score | +
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | Days in bed because of illness | +
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | Days cut down on activities because of illness | +
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | Diabetes-specific HRQL- summary scale | 0
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | General HRQL- physical functioning | +
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | General HRQL- role limitations (physical) | +
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | General HRQL- social functioning | +
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | General HRQL- bodily pain | −
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | General HRQL- role limitations (mental) | −
Piette, 2000^201^ | Telemedicine | Biweekly ATDM calls with telephone followup vs. usual care | General HRQL- general health perceptions | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Well-Doc, a cell phone-based software designed by endocrinologists and clinical diabetes educators vs. glucometers, testing strips and lancets | HbA1c level | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Well-Doc, a cell phone-based software designed by endocrinologists and clinical diabetes educators vs. glucometers, testing strips and lancets | New diagnosis depression | +
Ralston, 2009^30^ | Communication via email, education via IT, electronic medical records, telemonitoring systems | Web-based care management vs. usual care | Mean HbA1c | +
Ralston, 2009^30^ | Communication via email, education via IT, electronic medical records, telemonitoring systems | Web-based care management vs. usual care | Glycohemoglobin <7 % | +
Shea, 2007^209^ | Telemedicine | Home telemedicine unit vs. no home telemedicine unit | Mean HbA1c Level | +
Shea, 2007^209^ | Telemedicine | Home telemedicine unit vs. no home telemedicine unit | HbA1c in subgroup with HbA1c >7 % at baseline | +
Smith, 2008^27^ | Clinical decision aids, communication via email | Virtual consultation vs. no virtual consultation | HbA1c (%), median | 0
Smith, 2008^27^ | Clinical decision aids, communication via email | Virtual consultation vs. no virtual consultation | Systolic blood pressure | −
Smith, 2008^27^ | Clinical decision aids, communication via email | Virtual consultation vs. no virtual consultation | Diastolic blood pressure | 0
Smith, 2008^27^ | Clinical decision aids, communication via email | Virtual consultation vs. no virtual consultation | LDL | +
Smith, 2008^27^ | Clinical decision aids, communication via email | Virtual consultation vs. no virtual consultation | UKPDS 10-y risk | +
Smith, 2008^27^ | Clinical decision aids, communication via email | Virtual consultation vs. no virtual consultation | Minnesota community aggregate optimal diabetes score | +
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | Mean HbA1c | +
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | Mean LDL cholesterol | −
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | Mean systolic blood pressure | −
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | Mean diastolic blood pressure | +
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | HbA1c <7.0 % | +
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | Mean LDL <100 mg/dL | +
Thomas, 2007^23^ | Clinical decision aids, computer-assisted self-care, disease registry | Computerized diabetes registry vs. control group (usual clinic education) | Blood pressure <130/85 mmHg | 0
Yoon, 2008^200^ | Telemedicine | Access to a Web site through cellular phones or wired connections transmitting blood glucose levels weekly through telecare and receiving feedback and suggestions from providers vs. Usual care that did not use cellular phones for treatment | Mean HbA1c level | +

ATDM: Automated Telephone Disease Management, BMI: Body Mass Index, CDSS: Clinical Decision Support System, CV: Cardiovascular, E-mail: Electronic Mail, HbA1c: Glycated Hemoglobin, HDL: High-Density Lipoprotein, IT: Information Technology, LDL: Low-Density Lipoprotein, mHealth: Mobile Health, PHR: Personal Health Record, QOL: Quality of Life, SMBG: Self-Monitoring of Blood Glucose, SMS: Short Message Service, UKPDS: United Kingdom Prospective Diabetes Study

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 16b Overall grade of the quality of evidence in diabetes mellitus studies addressing clinical outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.82
2 | Number of studies | 22
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | No
5 | Overall grade of evidence | Moderate

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

These studies assessed several different clinical outcomes. All of them assessed glycemic control by measuring HbA1c. The other outcomes the studies assessed were blood pressure,21 23 198 lipids,23 198–200 quality of life (QOL), 29 199 201 BMI or weight,21 198 199 202 depression, 26 29 201 202 anxiety,201 fat/fruit and vegetable intake,199 202 coronary risk,21 sick days,201 and pregnancy outcomes (Appendix G, Evidence Table 11).203

Several of the studies did not find a statistically significant difference in outcomes between the intervention and control groups.29 23 27 28 204 205 The studies that detected at least one statistically significant difference in an outcome between the intervention and control groups are summarized below.

In a study by Glasgow (2000),199 one group received a telephone followup call, a second group had access to a multimedia computer to set specific dietary goals and could meet with a health counselor, and a final group received all three interventions. The clinical outcomes measured were HbA1c, serum lipids, weight, and QOL. Both groups that had access to the computer and also met with a counselor had a more favorable total/high-density lipoprotein (HDL) lipid ratio than the group that just received a telephone followup call (Table 16a; Appendix G, Evidence Table 11).

One study by Hetlevik (2000)21 examined how using a computer-based, clinical decision support system in the care of patients with diabetes might compare with standard protocols. The clinical outcomes studied were HbA1c, systolic and diastolic BP, cholesterol, BMI, coronary risk, and the percentage of patients who were smokers and had cardiovascular inheritance. The intervention had no impact on serum cholesterol (difference =0). However, it had a favorable impact on BMI (difference +0.3; 95% CI −0.8 to 1.4), and the percentage of patients who were smokers (difference +3.0; CI −4.0 to 10.0). It had a small negative impact on HbA1c (−0.1%; CI −0.4 to 0.1%) and on systolic (−1.2 mm Hg; CI −4.4 to 2.0 mm Hg) and diastolic blood pressure (−2.3 mm Hg; CI −3.8 to −0.8 mm Hg) (Table 16a; Appendix G, Evidence Table 11).

A study by Piette (2000)201 examined how a biweekly automated telephone disease management system with phone followup might impact depression, anxiety, and a number of health-related QOL parameters.201 The intervention had a positive effect on depression scores (13.7 vs. 17.6, p=0.023), self-efficacy (4.5 vs. 4.2, p=0.006), and days in bed because of illness (0.5 vs. 1.0, p=0.026) when compared to standard care (Table 16a; Appendix G, Evidence Table 11).

Quinn (2008)26 showed that a cell phone-based software application had a favorable impact on HbA1c when compared with standard care. The mean absolute decrease in HbA1c for intervention patients was 2.03 percent, as compared to 0.68 percent for the control group (p<0.02) (Table 16a; Appendix G, Evidence Table 11).

Cadario (2007)206 found that Glucobeeb, a Web-based tool, had a favorable impact on HbA1c when compared with usual protocols in diabetes care (−0.7% at 3 months and −0.7% at 6 months, p=0.03) (Table 16a; Appendix G, Evidence Table 11).

Farmer in 2005^207^ examined how special diabetes nurses, providing clinical advice in response to real-time glucose readings, might affect three clinical outcomes—mean HbA1c, a patient achieving a specific HbA1c level, and the proportion of transmitted glucose tests in the hypoglycemia range. Farmer found a significant difference in the proportion of transmitted blood glucose tests in the hypoglycemic range between the intervention group and the control group that received usual care (5.3% vs. 3.5%, p<0.0001) (Table 16a; Appendix G, Evidence Table 11).

The Glasgow (2006)202 study compared tailored self-management with computer-aided enhanced usual care, assessing HbA1c, lipids, Patient Health Questionnaire-9, diabetes distress scale, and weight. Tailored self-management had a positive impact on weight when compared with the other group (−0.68 kg, p=0.0007) (Table 16a; Appendix G, Evidence Table 11).

Harno (2006)198 reported favorable results when studying an e-health application with a diabetes management system and a home care link. When compared with standard care, the intervention had a positive impact on post-intervention diastolic blood pressure (79 vs. 82 mm Hg, p<0.05), HbA1c (7.32 vs. 7.83%, p<0.05), fasting glucose (8.88 vs. 1.87 mmol/l, p<0.001), total cholesterol (4.74 vs. 5.03 mmol/l, p<0.05), LDL (2.52 vs. 2.76 mmol/l, p<0.05), and triglycerides (1.44 vs. 1.67 mmol/l, p<0.05) (Table 16a; Appendix G, Evidence Table 11).

Homko (2007)203 used the Internet to send blood glucose and other health data directly to the health care providers of pregnant women and then send feedback to the women. The study assessed the percentage of patients requiring therapy (diet, glyburide, or insulin), fasting blood glucose, HbA1c at delivery, mean blood glucose, and pregnancy outcomes. Compared with usual care, the Internet intervention had a positive impact only on the percentage of patients receiving insulin (31% vs. 4%, p<0.05) (Table 16a; Appendix G, Evidence Table 11).

A study by Montori (2004)208 used telehealth to send glucometer readings. The intervention had a positive impact on mean HbA1c levels at 6 months when compared with usual care (8.2 vs. 7.8%, p=0.03) (Table 16a; Appendix G, Evidence Table 11).

Yoon (2008)200 compared using a Web site, to transmit glucose readings and provide feedback, with usual care. There was a significant change in HbA1c in the intervention group, with a mean absolute percentage change of −1.32 percent at 12 months versus 0.81 percent in the control group (p<0.05) (Table 16a; Appendix G, Evidence Table 11).

Shea (2007)209 showed that when compared with normal care, using a home telemedicine unit for the management of diabetes had a positive impact on mean HbA1c at one year (difference: 0.18%, p=0.006), systolic and diastolic blood pressures (difference: 3.4 mm Hg, p=0.001, and 1.9 mm Hg, p<0.001, respectively), and LDL cholesterol (difference: 9.5 mg/dL, p<0.001) (Table 16a; Appendix G, Evidence Table 11).

A study by Noel (2004)43 assessed the impact of using telehealth services on HbA1c in patients with diabetes. At 6 months, subjects in the intervention group showed a decrease in HbA1c levels (mean = 7.30%, p<0.001), as compared with an increase in HbA1c levels in the control group (mean = 7.83percent, p=0.002) (Table 16a; Appendix G, Evidence Table 11).

Ralston (2009)167 assessed the impact of a Web-based care management system on persons with diabetes mellitus versus usual care. The Web-based program included access to medical records and secure e-mail with the provider, feedback on blood glucose readings and education. The outcome measure of HbA1c declined by 0.7 percent (95% CI 0.2–1.3) in the intervention group.

Grant (2008)210 assessed whether a ptient-held record where participants could update their medical status would impact the number of followup visits recorded and whether the personal healt record would increase the rate of medication changes. Followup visits increase significantly from 15 to 53% (p> 0.001) and a significant number of participants in the intervention arm had their treatment regimens adjusted (Table 16a; Appendix G, Evidence Table 11).

Benhamou (2007)211 examined patiens with poorly controlled HbA1c. The intervention involved participants receiving short message service messages advising them based on the previous submitted levels compared to usual care. There were no significant differences between the usual care group and the intervention groups in respect to reduction in HbA1c levels or glucose levels (Table 16a; Appendix G, Evidence Table 11).

#### Clinical Outcomes in Studies Addressing Heart Disease

Sixteen studies evaluated the impact of health IT on clinical outcomes related to heart disease (Table 17a; Appendix G, Evidence Tables 8–10 and 12). Specific conditions evaluated were heart failure, anticoagulation and thrombosis, and cardiovascular risk. Overall, the study quality was high, but the scores were somewhat variable. The primary reason for lower-quality scores was loss to followup. The overall grade of the strength of evidence was moderate (Table 17b; Appendix G, Evidence Table 12). Below is a summary of studies that had statistically significant findings on direct clinical outcome measures.35

Table 17a Summary of the impact of health IT applications on clinical outcomes for patients with heart disease

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact^*^
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | KCCQ summary score adjusted^†^ (higher score = better outcome) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | KCCQ physical limitation domain score adjusted (higher score = better outcome) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | KCCQ symptom domain score (higher score = better outcome) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Depression adjusted score (higher score = presence of depression) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | EuroQoL health-related QOL adjusted score (higher score = better outcome) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Percent with KCCQ QOL domain score >=50 | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | Percent with KCCQ social limitation domain score >= 50 | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations (basic intervention) vs. heart failure patients receiving usual care | KCCQ percent w/self efficacy domain score >=50 | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations and additional resources (augmented intervention) vs. heart failure patients receiving usual care | KCCQ summary score Adjusted score (higher score = better outcome) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations and additional resources (augmented intervention) vs. heart failure patients receiving usual care | KCCQ physical limitation domain score Adjusted score (higher score = better outcome) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations and additional resources (augmented intervention) vs. heart failure patients receiving usual care | KCCQ symptom domain score (higher score = better outcome) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations and additional resources (augmented intervention) vs. heart failure patients receiving usual care | Depression Adjusted score (higher score = presence of depression) | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations and additional resources (augmented intervention) vs. heart failure patients receiving usual care | EuroQoL health-related QOL Adjusted score (higher score = better outcome) | −
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations and additional resources (augmented intervention) vs. heart failure patients receiving usual care | KCCQ percent w/QOL domain score >=50 | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations and additional resources (augmented intervention) vs. heart failure patients receiving usual care | KCCQ percent w/social limitation domain score >= 50 | +
Feldman, 2005^32^ | Communication via email | Heart failure patients whose nurses received email recommendations and additional resources (augmented intervention) vs. heart failure patients receiving usual care | KCCQ percent w/self efficacy domain score >=50 | +
Jerant, 2001 40 | Telemonitoring systems | Nurse phone calls with nurse vs. usual care | Median health care utilization | +
Jerant, 2001 40 | Telemonitoring systems | Home telemonitoring videoconferencing vs. usual care | Median health care utilization | +
Jerant, 2003 248 | Telemedicine | Telemedicine vs. usual care | Emotional subscale on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003 248 | Telemedicine | Telemedicine vs. usual care | Physical subscale on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003 248 | Telemedicine | Telemedicine vs. usual care | Total score on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003 248 | Telemedicine | Telemedicine vs. usual care | Short Form-36 mental component score | −
Jerant, 2003 248 | Telemedicine | Telemedicine vs. usual care | Short Form-36 physical component score | +
Jerant, 2003 248 | Telemedicine | Telephone vs. usual care | Emotional subscale on Minnesota Living With Heart Failure Questionnaire: mean | 0
Jerant, 2003 248 | Telemedicine | Telephone vs. usual care | Physical subscale on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003 248 | Telemedicine | Telephone vs. usual care | Total score on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003 248 | Telemedicine | Telephone vs. usual care | Short Form-36 mental component score | +
Jerant, 2003 248 | Telemedicine | Telephone vs. usual care | Short Form-36 physical component score | +
Kucher, 2005^34^ | Clinical decision aids | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | Death at 30 days | −
Kucher, 2005^34^ | Clinical decision aids | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | Death at 90 days | −
Kucher, 2005^34^ | Clinical decision aids | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | Major hemorrhage at 30 days | 0
Kucher, 2005^34^ | Clinical decision aids | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | Minor hemorrhage at 30 days | +
Kucher, 2005^34^ | Clinical decision aids | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | Mechanical prophylaxis | +
Kucher, 2005^34^ | Clinical decision aids | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | Pharmacologic prophylaxis | +
Kucher, 2005^34^ | Clinical decision aids | Computerized alert to physician about patient’s risk of deep vein thrombosis vs. no computerized alert | Deep vein thrombosis of the arms at 90 days | +
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | Total-C | −
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | HDL | −
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | LDL | −
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | Total-C/HDL ratio | −
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | Systolic blood pressure | −
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | Diastolic blood pressure | −
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | Body mass index | −
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | 8-year coronary risk | −
Lowensteyn, 1998^35^ | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | CV age | −
Montgomery, 2000^53^ | Clinical decision aids | CDSS and risk chart vs. usual care | Mean 5-year CV risk | +
Montgomery, 2000^53^ | Clinical decision aids | CV risk chart vs. usual care (chart only) | Mean 5-year CV risk | 0
Noel, 2004^43^ | Electronic medical records, telemonitoring systems | Home telemonitoring that used standard phone lines to communicate with the hospital and integrate into hospital electronic health records vs. usual home health care services and nurse case management. | Bed-days-of-care | +
Noel, 2004^43^ | Electronic medical records, telemonitoring systems | Home telemonitoring that used standard phone lines to communicate with the hospital and integrate into hospital electronic health records vs. usual home health care services and nurse case management. | Urgent clinic/emergency room visits | +
Noel, 2004^43^ | Electronic medical records, telemonitoring systems | Home telemonitoring that used standard phone lines to communicate with the hospital and integrate into hospital electronic health records vs. usual home health care services and nurse case management. | Hba1c | +
Noel, 2004^43^ | Electronic medical records, telemonitoring systems | Home telemonitoring that used standard phone lines to communicate with the hospital and integrate into hospital electronic health records vs. usual home health care services and nurse case management. | Cognitive status | +
Noel, 2004^43^ | Electronic medical records, telemonitoring systems | Home telemonitoring that used standard phone lines to communicate with the hospital and integrate into hospital electronic health records vs. usual home health care services and nurse case management. | Bed-days-of-care | +
Noel, 2004^43^ | Electronic medical records, telemonitoring systems | Home telemonitoring that used standard phone lines to communicate with the hospital and integrate into hospital electronic health records vs. usual home health care services and nurse case management. | HbA1c | +
Noel, 2004^43^ | Electronic medical records, telemonitoring systems | Home telemonitoring that used standard phone lines to communicate with the hospital and integrate into hospital electronic health records vs. usual home health care services and nurse case management. | Cognitive status | +
Poller, 2008^212^ | Telemonitoring systems | PARMA-5 computer-assisted dosage program vs. manual dosage | Incidence of clinical events | +
Poller, 2008^212^ | Telemonitoring systems | PARMA-5 computer-assisted dosage program vs. manual dosage | Minor bleeds | +
Poller, 2008^212^ | Telemonitoring systems | PARMA-5 computer-assisted dosage program vs. manual dosage | Major bleeds | +
Poller, 2008^212^ | Telemonitoring systems | PARMA-5 computer-assisted dosage program vs. manual dosage | Thrombotic events | +
Poller, 2008^212^ | Telemonitoring systems | PARMA-5 computer-assisted dosage program vs. manual dosage | Deaths | +
Poller, 2008^212^ | Telemonitoring systems | PARMA-5 computer-assisted dosage program vs. manual dosage | Total Events in DVT/PE group | −
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Time for which International Normalized Ratio was in range | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Incidence of clinical events adjudicated | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Minor bleeds | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Major bleeds | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Thrombotic events | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Deaths | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Total events in DVT/PE group | −
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Time for which International Normalized Ratio (INR) was in range | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Incidence of clinical events adjudicated | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Minor bleeds | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Major bleeds | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Thrombotic events | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Deaths | +
Poller, 2008^119^ | Clinical decision aids, IT-guided disease management | Computer-assisted oral anticoagulant dosage vs. medical staff dosage | Total events in DVT/PE group | −
Ross, 2004^44^ | Electronic medical record | SPPARO to access electronic hospital records vs. standard care | KCCQ self-efficacy score | −
Ross, 2004^44^ | Electronic medical record | SPPARO to access electronic hospital records vs. standard care | Symptom stability | +
Ross, 2004^44^ | Electronic medical record | SPPARO to access electronic hospital records vs. standard care | QOL | +
Ross, 2004^44^ | Electronic medical record | SPPARO to access electronic hospital records vs. standard care | Functional status | +
Ross, 2004^44^ | Electronic medical record | SPPARO to access electronic hospital records vs. standard care | Clinical summary | +
Ross, 2004^44^ | Electronic medical record | SPPARO to access electronic hospital records vs. standard care | Physical limitations | −
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message and alert vs. only email | Systolic blood pressure | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message and alert vs. only email | Systolic blood pressure ≤140 mmHg | −
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message and alert vs. only email | Dose increased | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message and alert vs. only email | Drug added | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message and alert vs. only email | Both increased dose and drug added | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message, alert and patient education vs. only email | Systolic blood pressure | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message, alert and patient education vs. only email | Systolic blood pressure ≤140 mm Hg | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message, alert and patient education vs. only email | Dose increased | −
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message, alert and patient education vs. only email | Drug added | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider who received email message, alert and patient education vs. only email | Both increased dose and drug added | +
Subramanian, 2004^36^ | Clinical decision aids | Physicians care suggestions generated with electronic medical record data and symptom data from patient questionnaires within 2 weeks of scheduled outpatient visits (intervention group) vs. physicians whose suggestions were generated with EMR data alone (control group). | Short Form-36: Physical Component Scale | −
Subramanian, 2004^36^ | Clinical decision aids | | Short Form-36: Mental Component Scale | +
Scherr, 2009^45^ | Telemonitoring | Participants in the intervention group received pharmacological treatment with telemedical surveillance | Event free survival | +
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions, approved by a panel of local cardiologists and general internists, were displayed to physicians and pharmacists as they cared for enrolled patients vs. control group where suggestions were withheld | Mental health Short-Form 36 subscale score | 0
Tierney, 2003^37^ | IT-guided disease management | | Overall health status (Chronic heart disease questionnaire score) | 0
Tierney, 2003^37^ | IT-guided disease management | | Dyspnea (Chronic heart disease questionnaire score) | +
Tierney, 2003^37^ | IT-guided disease management | | Fatigue (Chronic heart disease questionnaire score) | 0
Tierney, 2003^37^ | IT-guided disease management | | Emotion (Chronic heart disease questionnaire score) | −
Tierney, 2003^37^ | IT-guided disease management | Printed note (rather than bottle labels) instructing the pharmacist to view the care suggestions in an electronic database of those suggestions vs. control group where suggestions were withheld | Mental health Short-Form 36 subscale score | +
Tierney, 2003^37^ | IT-guided disease management | Printed note (rather than bottle labels) instructing the pharmacist to view the care suggestions in an electronic database of those suggestions vs. control group where suggestions were withheld | Overall health status (Chronic heart disease questionnaire score) | 0
Tierney, 2003^37^ | IT-guided disease management | Printed note (rather than bottle labels) instructing the pharmacist to view the care suggestions in an electronic database of those suggestions vs. control group where suggestions were withheld | Dyspnea (Chronic heart disease questionnaire score) | +
Tierney, 2003^37^ | IT-guided disease management | Printed note (rather than bottle labels) instructing the pharmacist to view the care suggestions in an electronic database of those suggestions vs. control group where suggestions were withheld | Fatigue (Chronic heart disease questionnaire score) | −
Tierney, 2003^37^ | IT-guided disease management | Printed note (rather than bottle labels) instructing the pharmacist to view the care suggestions in an electronic database of those suggestions vs. control group where suggestions were withheld | Emotion (Chronic heart disease questionnaire score) | +
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions, approved by a panel of local cardiologists and general internists, were displayed to physicians and pharmacists as they cared for enrolled patients and a printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in an electronic database of those suggestion vs. control group where suggestions were withheld | Mental health Short-Form 36 subscale score | +
Tierney, 2003^37^ | IT-guided disease management | | Overall health status (Chronic heart disease questionnaire score) | −
Tierney, 2003^37^ | IT-guided disease management | | Dyspnea (Chronic heart disease questionnaire score) | +
Tierney, 2003^37^ | IT-guided disease management | | Fatigue (Chronic heart disease questionnaire score) | 0
Tierney, 2003^37^ | IT-guided disease management | | Emotion (Chronic heart disease questionnaire score) | 0
Verheijden, 2004^213^ | Computer-assisted self-care | Web-based nutrition counseling and social support vs. usual care | Mean perceived social support | 0
Verheijden, 2004^213^ | Computer-assisted self-care | Web-based nutrition counseling and social support vs. usual care | Mean BMI | +
Verheijden, 2004^213^ | Computer-assisted self-care | Web-based nutrition counseling and social support vs. usual care | Mean systolic blood pressure | −
Verheijden, 2004^213^ | Computer-assisted self-care | Web-based nutrition counseling and social support vs. usual care | Mean diastolic blood pressure | −
Verheijden, 2004^213^ | Computer-assisted self-care | Web-based nutrition counseling and social support vs. usual care | Mean total cholesterol | −
Wakefield, 2008^42^ | IT-guided disease management, interactive lifestyle counseling | Usual care subjects contacted their primary care nurse case manager by telephone if needed. Intervention subjects contacted their assigned study nurse via videophone if needed after discharge. Intervention nurses reinforced discharge plans, had full access to patient records and employed strategies to improve adherence with treatment plans. | Minnesota Living with Heart Failure (higher score= worse QOL) | −
Wakefield, 2008^42^ | IT-guided disease management, interactive lifestyle counseling | | Mortality | +

BMI: Body Mass Index, CDSS: Clinical Decision Support System, CV: Cardiovascular, DVT: deep vein thrombosis, E-mail: Electronic Mail, EMR: Electronic Medical Record, HbA1c: Glycated Hemoglobin, HDL: high-density lipoprotein, IT: Information Technology, KCCQ: Kansas City Cardiomyopathy Questionnaire, LDL: low-density lipoprotein, PE: Pulmonary Embolism, QOL: quality of life, SPPARO: System Providing Access to Records Online

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

† Adjusted for patient, nurse, and location characteristics.

Table 17b Overall grade of the quality of evidence in heart disease studies addressing clinical outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.27
2 | Number of studies | 15
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | No
5 | Overall grade of evidence | Moderate

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

A study by Feldman (2005)32 examined how a basic intervention involving recommendations sent by email to nurses caring for the patients, and an augmented intervention involving recommendations and additional resources sent by email to nurses caring for the patients might compare to usual care in patients with heart failure. The study assessed the clinical outcomes physical limitation, symptom domains, QOL, social limitation, self-efficacy, and depression. Results show additional interventions had a positive impact when compared with usual care, specifically in the summary score for the Kansas City Cardiomyopathy Questionnaire (46.5 vs. 40.4, p=0.013 and 45.6 vs. 40.4, p=0.048; basic and augmented interventions, respectively) and the EuroQoL health-related QOL score (score: 48.9 vs. 39, p=0.003; basic intervention vs. usual care) (Table 17a; Appendix G, Evidence Table 12).

Noel (2004)43 assessed the impact of using telehealth services on the cognitive status of patients with heart failure. Results for cognitive level showed a statistically significant difference in the intervention group when compared with a control group receiving usual home health care services (p<0.001) (Table 17a; Appendix G, Evidence Table 12).

Subramanian (2004)36 compared an intervention in which physicians received care suggestions from an electronic medical record and symptom data from questionnaires with an intervention that provided symptom data from questionnaires alone. The study examined the impact on the physical and mental components of the Short-Form 36 Health Status Questionnaire. Patients in the control group had greater improvement in the physical component scale of the questionnaire at 12 months (1.3 vs. −0.6, p=0.03) (Appendix G, Evidence Tables 8, 9, and 12).

Ross (2004)44 studied the effect of System Providing Access to Records Online and telemonitoring versus usual care on the self-efficacy domain of the Kansas City Cardiomyopathy Questionnaire in patients with heart failure. At 12 months, the symptom stability score for the intervention group was superior to that for the control group (63 vs. 46; difference: +17; CI 4 to 29, p<0.01) (Table 17a; Appendix G, Evidence Table 12).

Kucher (2005)34 used a computer program linked to a patient database to alert physicians about patients at risk of deep vein thrombosis and suggest measures to prevent it. The comparison group received no alert. The clinical outcomes considered were death, hemorrhage, and the presence of mechanical or pharmacological prophylaxis for deep vein thrombosis. More patients in the intervention group received mechanical (10.0% vs. 1.5%, p<0.001) or pharmacologic prophylaxis (23.6% vs. 13.0%, p<0.001). The computer alert reduced the risk of deep vein thrombosis or pulmonary embolism at 90 days by 41 percent (heart rate, 0.59; 95% CI 0.43 to 0.81; p=0.001) (Table 17a; Appendix G, Evidence Table 12).

Poller (2008)119 used two different computer-assisted dosage programs to determine the correct anticoagulation dosage. The study evaluated the length of time during which the International Normalized Ratio was in the therapeutic range, and the incidence of clinical events, bleeds, thrombotic events, deaths, and total events. Computer assistance made a positive impact on time in the therapeutic range (time in targeted International Normalized Ratio range): 1.2%, 95% CI 0.7 to 1.8). In the patients with established deep vein thrombosis and/or pulmonary embolism, the incidence of clinical events was lower with computer-assisted dosage (incidence rate ratio=0.67; 95% CI 0.52 to 0.85; p=0.001) (Table 17a; Appendix G, Evidence Table 12).

A second study by the same authors212 compared the PARMA-5 computer-assisted dosage program with manual dosing. The study examined anticoagulation-related outcomes, including the incidence of clinical events, minor and major bleeds, thrombotic events, total events, and the proportion of time patients were maintained within the locally decided target anticoagulation range. This study found an overall non-significant reduction in total events, but in the subgroup of patients with deep vein thrombosis/pulmonary embolism, the intervention resulted in a reduction in number of total events (incidence rate ratio= 0.69; 95% CI 0.53 to 0.89, p=0.005) (Table 17a; Appendix G, Evidence Table 12).

A study by Lowensteyn (1998)35 assessed how providing a coronary risk profile to the physician might impact lipids, blood pressure, BMI, smoking, coronary risk, and cardiovascular age. The study favored the intervention group over a comparison group that did not receive the risk profile, with differences at 3 months of followup in total cholesterol (difference: −0.238 mmol/l, p=0.05), LDL (difference: −0.226 mmol/l, p=0.05), total cholesterol/HDL ratio (difference: −0.287 mmol/l, p=0.005), 8-year coronary risk percentage (difference: −1.426, p<0.01) and cardiovascular age (difference: −0.571, p<0.01) (Table 17a; Appendix G, Evidence Table 12).

Scherr (2009)45 described the effects of a telemonitoring system on heart disease patients in a randomized sample of 120 patients. Fifty-four patients were randomized to the intervention. Clinical outcomes of interest included cardiovascular mortality. The intervention showed a 15 percent reduction in the risk of death (p=0.04) (Table 17a; Appendix G, Evidence Table 12).

Jerant (2001)73 addressed molbility and health care utilization/readmission in a population receiving home telecare equipment. Health care readmission charges were lower in the intervention group atients receiving the intervention plus usual care were more likely to have a reduced cardiovascular risk than those receiving the intervention plus chart alone.

Montgomery (2000)144 examined clinical decision support systems and their impact on mean 5-year CV risk. P

Five other studies showed that health IT that addressed PCC had either no significant impact or a negative impact on clinical outcomes. 37 42 52 213 214 (Appendix G, Evidence Tables 8, 9, and 12).

#### Clinical Outcomes in Studies Addressing Cancer

Four studies examined the effects of health IT that addressed PCC on clinical outcomes for patients with cancer (Table 18a; Appendix G, Evidence Tables 8–10 and 13). The study quality was high, but the quality scores were variable. The primary reasons for lower-quality scores were studies not being double-blinded or not describing loss to followup. The overall grade of the strength of evidence in these studies was low (Table 18b; Appendix G, Evidence Table 13).48 46 47 215 216

Table 18a Summary of the impact of health IT applications on clinical outcomes for patients with cancer

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact^*^
Maslin, 1998^215^ | Interactive lifestyle counseling | Interactive video disk system vs. usual care | Mental health score on Short-Form 36 questionnaire | 0
Maslin, 1998^215^ | Interactive lifestyle counseling | Interactive video disk system vs. usual care | Anxiety score on the Hospital Anxiety and Depression Scale | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Pain at its worst (range: 0–10) | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Pain on average (range: 0–10) | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Pain interference scale (range: 0–10) | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Best QOL | −
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Severe pain | −
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Severe insomnia | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. usual care | Severe constipation | −
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. email reminder, provider prompts, patient education and clinical nurse specialist outreach vs. usual care | Pain at its worst (range: 0–10) | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. email reminder, provider prompts, patient education and clinical nurse specialist outreach vs. usual care | Pain on average (range: 0–10) | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. email reminder, provider prompts, patient education and clinical nurse specialist outreach vs. usual care | Pain interference scale (range: 0–10) | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. email reminder, provider prompts, patient education and clinical nurse specialist outreach vs. usual care | Best QOL | −
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. email reminder, provider prompts, patient education and clinical nurse specialist outreach vs. usual care | Severe pain | −
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. email reminder, provider prompts, patient education and clinical nurse specialist outreach vs. usual care | Severe insomnia | +
McDonald, 2005^48^ | Communication via email | Patient-specific, one-time email reminder with pain-specific recommendations vs. email reminder, provider prompts, patient education and clinical nurse specialist outreach vs. usual care | Severe constipation | −
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for care of cancer symptoms vs. usual care | Number of reported symptoms (0–10) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for care of cancer symptoms vs. usual care | Number of reported symptoms (0–15) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for care of cancer symptoms vs. usual care | Number of reported symptoms (0–20) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for care of cancer symptoms vs. usual care | Number of reported symptoms (0–25) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for care of cancer symptoms vs. usual care | Number of reported symptoms (0–30) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for care of cancer symptoms vs. usual care | Number of reported symptoms (0–40) | 0
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for care of cancer symptoms vs. usual care | Number of reported symptoms (0–50) | +
Taenzer, 2000^216^ | IT-guided self-management | Lung cancer patients whose physicians and nurses received quality of life training and patients completed the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Physical functioning | −
Taenzer, 2000^216^ | IT-guided self-management | | Role functioning | −
Taenzer, 2000^216^ | IT-guided self-management | | Emotional functioning | −
Taenzer, 2000^216^ | IT-guided self-management | | Cognitive functioning | −
Taenzer, 2000^216^ | IT-guided self-management | | Social functioning | −
Taenzer, 2000^216^ | IT-guided self-management | | Global functioning | −
Taenzer, 2000^216^ | IT-guided self-management | | Number of functional scales indicating compromised function | −
Taenzer, 2000^216^ | IT-guided self-management | | Fatigue | −
Taenzer, 2000^216^ | IT-guided self-management | | Nausea and vomiting | +
Taenzer, 2000^216^ | IT-guided self-management | | Pain | −
Taenzer, 2000^216^ | IT-guided self-management | | Dyspnea | −
Taenzer, 2000^216^ | IT-guided self-management | | Sleep disturbance | −
Taenzer, 2000^216^ | IT-guided self-management | | Appetite | +
Taenzer, 2000^216^ | IT-guided self-management | | Constipation | −
Taenzer, 2000^216^ | IT-guided self-management | | Diarrhea | +
Taenzer, 2000^216^ | IT-guided self-management | | Financial difficulties | +
Taenzer, 2000^216^ | IT-guided self-management | | Number of symptom scales indicating compromised functioning | −
Taenzer, 2000^216^ | IT-guided self-management | | Number of functional and symptom scales indicating compromised function | −
Taenzer, 2000^216^ | IT-guided self-management | | Total number of items endorsed | +

E-mail: Electronic Mail, EORTC-QLQ: European Organization for Research and Treatment of Cancer QOL Questionnaire, IT: Information Technology, mHealth: Mobile Health, QOL: Quality of Life

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

EORTC-QLQ: European Organization for Research and Treatment of Cancer QOL Questionnaire

Table 18b Overall grade of the quality of evidence in cancer studies addressing clinical outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.25
2 | Number of studies | 4
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | Yes
5 | Overall grade of evidence | Low

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

McDonald (2005)48 compared three groups: a control group that received usual care and two interventions groups, one that received a patient-specific, one-time email reminder with pain-specific recommendations (the basic intervention) and another that received an email reminder, provider prompts, patient education, and clinical nurse outreach. The study measured impact in terms of pain levels, QOL, insomnia, and constipation. The basic intervention had a positive impact on average pain level difference (pain interface scale: −1.5, p=0.03) and on the nursing assessment of bowel movements (−5.7, p=0.02) (Table 18a; Appendix G, Evidence Table 13).48

Maslin (1998)215 studied how the use of an interactive videodisk system might affect the mental health and anxiety of cancer patients. There was a fall in the anxiety score on the Hospital Anxiety and Depression scale in both intervention and usual care groups at 9 months (p<0.001). The study did not report a difference in actual score between the intervention and usual care groups (Table 18a; Appendix G, Evidence Table 13).

A study of lung cancer patients by Taenzer in 2000^216^ assessed physical, emotional, cognitive, role, social, and global functioning, as well as symptoms such as fatigue, nausea and vomiting, pain, dyspnea, sleep disturbance, appetite, constipation, diarrhea, financial difficulties and a number of scales showing compromised function. The groups included patients who completed a computerized version of the European Organization for Research and Treatment of Cancer QLQ-C30 instrument versus patients who completed a paper version of the same instrument. The patients in the intervention arm reported more QOL issues with regard to physical functioning (60.0 vs. 76.9, p<0.05) and role functioning (55.6 vs. 84.6, p<0.01) and more dyspnea (51.9 vs. 34.6, p<0.05) (Table 18a; Appendix G, Evidence Table 13).

Ruland (2003)47 assessed the usefulness and feasibility of the computer application CHOICES (Creating better Health Outcomes by Improving Communication about Patients’ Experiences) in evaluating symptoms in cancer patients. Patients using this application had significantly higher scores on symptom reporting than did the control group (group differences in congruence controlled for number of reported symptoms: 7.63 vs. 2.83, p<0.05 for total symptoms) (Table 18a; Appendix G, Evidence Table 13).

#### Clinical Outcomes in Studies Addressing Other Disease Categories

In addition to the main disease categories of diabetes, heart disease, and cancer, health IT applications have been used for a number of other diseases and conditions. Below we provide a brief description of the outcomes according to disease category. We provide additional details in the accompanying evidence tables (Appendix G, Evidence Tables 8–10).

##### Hypertension

Eight studies examined clinical outcomes associated with the use of health IT applications related to PCC for patients with hypertension (Table 19a; Appendix G, Evidence Tables 8–10 and 14).50 54–57 144 217 218 The study quality was high, and the quality scores were somewhat variable. The primary reasons for lower-quality scores were studies not being double-blinded or not describing loss to followup. The overall grade of the strength of evidence in studies of clinical outcomes addressing hypertension was high (Table 19b; Appendix G, Evidence Table 14). Below is a summary of those studies that were most significant.

Table 19a Summary of the impact of health IT applications on clinical outcomes for patients with hypertension

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact^*^
Bosworth, 2009^218^ | Clinical decision aids | Patient behavioral intervention group vs. control group (hypertension reminder) whose providers did not receive decision support | Estimated mean systolic blood pressure | −
Bosworth, 2009^218^ | Clinical decision aids | Patient behavioral intervention group vs. control group (hypertension reminder) whose providers did not receive decision support | Estimated percent in blood pressure control | +
Bosworth, 2009^218^ | Clinical decision aids | Combined patient and provider intervention vs. control group (hypertension reminder) whose providers did not receive decision support | Estimated percent in blood pressure control | 0
Bosworth, 2009^218^ | Clinical decision aids | Provider decision support system group vs. control group (hypertension reminder) | Estimated mean systolic blood pressure | +
Bosworth, 2009^218^ | Clinical decision aids | Provider decision support system group vs. control group (hypertension reminder) | Estimated percent in blood pressure control | −
Fretheim, 2006^50^ | Clinical decision aids, IT-guided disease management | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | CV risk among patients started on treatment | +
Fretheim, 2006^50^ | Clinical decision aids, IT-guided disease management | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | †Patients with CV risk above 20% | +
Fretheim, 2006^50^ | Clinical decision aids, IT-guided disease management | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | Treatment goal achieved among diabetes patients | −
Fretheim, 2006^50^ | Clinical decision aids, IT-guided disease management | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | Treatment goal for hypertension achieved | +
Fretheim, 2006^50^ | Clinical decision aids, IT-guided disease management | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | Treatment goal for cholesterol achieved | −
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Web-based blood pressure monitoring and Web training vs. usual care | Adjusted change in systolic blood pressure at 12 months | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Web-based blood pressure monitoring and Web training vs. usual care | Percent with controlled blood pressure at 12 months | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Web-based blood pressure monitoring and Web training and Web-based pharmacist care vs. usual care | Adjusted change in systolic blood pressure at 12 months | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Web-based blood pressure monitoring and Web training and Web-based pharmacist care vs. usual care | Percent with controlled blood pressure at 12 months | +
Hicks, 2008^55^ | Clinical decision aids | Computerized support vs. usual care | Blood pressure control | +
Hicks, 2008^55^ | Clinical decision aids | Computerized support vs. usual care | Mean systolic blood pressure at outcome visit | −
Hicks, 2008^55^ | Clinical decision aids | Computerized support vs. usual care | Mean diastolic blood pressure at outcome visit | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Day time ambulatory blood pressure monitoring systolic blood pressure | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Day time ambulatory blood pressure monitoring diastolic blood pressure | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Night time ambulatory blood pressure monitoring systolic blood pressure | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Night time ambulatory v monitoring diastolic blood pressure | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Day time ambulatory blood pressure monitoring systolic blood pressure (age >=60) | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Day time ambulatory blood pressure monitoring diastolic blood pressure (age >=60) | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Change in Day Time ambulatory blood pressure monitoring systolic blood pressure (age >=60) | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Change in Day time ambulatory blood pressure monitoring diastolic blood pressure (age >=60) | +
Madsen, 2008^217^ | Communication via email, information exchange, telemonitoring systems | Telemonitoring of blood pressure vs. conventional monitoring of blood pressure | Percent achieved Target blood pressure | +
Montgomery, 2000^144^ | IT-guided decision support | Chart alone vs patients who received decision support | At risk for cardiovascular event at 12 months. | 0
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit only practices vs. patients who received no feedback | Final systolic blood pressure | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit only practices vs. patients who received no feedback | Final systolic blood pressure | +
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit only practices vs. patients who received no feedback | Final proportion with controlled blood pressure in hypertensive patients | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit only practices vs. patients who received no feedback | All patients with blood pressure <160/90 mmHg | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit only practices vs. patients who received no feedback | All patients with BP>=160/90 mmHg | +
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit only practices vs. patients who received no feedback | All patients with no recorded blood pressure | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit and strategic practices vs. patients who received no feedback | Final proportion with controlled blood pressure in hypertensive patients | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit and strategic practices vs. patients who received no feedback | All patients with blood pressure <160/90 | +
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit and strategic practices vs. patients who received no feedback | All patients with blood pressure >=160/90 | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit and strategic practices vs. patients who received no feedback | All patients with no recorded blood pressure | +
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit and strategic practices vs. patients who received no feedback | Blood pressure control (%) | −
Mitchell, 2004^54^ | IT-guided disease management, electronic medical records | Audit and strategic practices vs. patients who received no feedback | Blood pressure control (%) | −
Parati, 2009^57^ | Computer-assisted self-care, telemonitoring systems | Telemonitoring home blood pressure vs. usual care | QOL at end of study per QOL assessment in hypertension patients questionnaire | +
Parati, 2009^57^ | Computer-assisted self-care, telemonitoring systems | Telemonitoring home blood pressure vs. usual care | Percent with daytime blood pressure normalization | +
Parati, 2009^57^ | Computer-assisted self-care, telemonitoring systems | Telemonitoring home blood pressure vs. patients that received usual care | QOL at end of study per QOL assessment in hypertension patients questionnaire | +
Parati, 2009^57^ | Computer-assisted self-care, telemonitoring systems | Telemonitoring home blood pressure vs. patients that received usual care | Percent with daytime blood pressure normalization | +

CV: Cardiovascular, E-mail: Electronic Mail, IT: Information Technology, QOL: quality of life

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

† as defined by SmartHeart (Phizer)

Table 19b Overall grade of the quality of evidence in hypertension studies addressing clinical outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.71
2 | Number of studies | 7
3 | Did the studies have important inconsistency? | No
4 | Were the studies sparse? | No
5 | Overall grade of evidence | High

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Green (2008) 159 assessed the impact on blood pressure of two interventions, a Web-based home monitoring system with Web training, and a Web-based home monitoring system with Web training and Web-based pharmacist care. Results showed that adding Web-based pharmacist care significantly increased the percentage of patients with controlled blood pressure (56%; 95% CI 49 to 62) when compared with usual care (p<0.01) or Web-based home monitoring system with Web training alone (p<0.01). Patients who had baseline systolic blood pressures of 160 mm Hg or higher and who received a Web-based home monitoring system, Web training and a Web-based pharmacist care had a greater net reduction in systolic (13.2 mm Hg; 95% CI −19.2 to −7.1, p<0.001) and diastolic blood pressure (−4.6mm Hg; 95% CI −8.0 to −1.2, p<0.01) and improved blood pressure control (relative risk [RR] 3.32; 95% CI 1.86 to 5.94, p<0.001) when compared with usual care (Table 19a; Appendix G, Evidence Table 14).

Hicks (2008)153 assessed the impact of computerized decision support versus usual care on blood pressure control.55 After 18 months of followup, there was a significant difference in mean diastolic blood pressure between the intervention and control groups and no significant difference in systolic blood pressure (77 vs. 78 mm Hg, p>0.05; 137 vs. 138, p=0.67) (Table 19a; Appendix G, Evidence Table 14).

Montgomery (2000)144 compared the effect on cardiovascular risk and blood pressure of two interventions, a risk chart alone and a risk chart plus a computer-based, clinical-decision, support system.53 In the risk chart-alone group, patients had lower systolic blood pressure than did those in the usual care group at 12 months (difference: 4.6 mm Hg; 95% CI 0.8 to 8.4, p=0.02). Also, a greater proportion of patients in the computer-based, clinical decision support system group were at no higher risk than usual care or chart only groups of having a cardiovascular event at 12 (adjusted OR 2.3, 95% CI 1.1 to 4.8; p=0.02) (Table 19a; Appendix G, Evidence Table 14).

Parati (2009) 173 assessed how telehealth delivery of home blood pressure affected QOL and the percentage of patients with daytime blood pressure normalization. The percentage of daytime blood pressure normalization was higher in the intervention group than in the control group (62 vs. 50%, p<0.05)57 (Table 19a; Appendix G, Evidence Table 14).

Madsen (2006)219 evaluated the impact of telemonitoring versus conventional monitoring on blood pressure, change in blood pressure, and achievement of blood pressure targets. Results showed telehealth made a positive impact on the percentage of patients achieving their blood pressure target (62% vs. 50%, p<0.05), and resulted in fewer treatment changes (9 vs. 14%, p<0.05)217 (Table 19a; Appendix G, Evidence Table 14).

Mitchell (2004)161 evaluated the impact on blood pressure control of an audit versus an audit plus strategic practices. Results showed the audit plus strategic practices arm had a much higher proportion of patients with controlled blood pressure than did the usual care group (adjusted relative risk 1.72; 95% CI 1.06 to 2.79, p=0.028) (Table 19a; Appendix G, Evidence Table 14).

##### Pulmonary Disease

Nine studies examined the impact of health IT on clinical outcomes for asthma.59 60 62 63 137 183 220–222 These studies assessed the daily dose of inhaled corticosteroids,63 symptom days and activity limitations,62 QOL and health status,220 asthma symptoms,221 peak flow measurements,59 222 oxygen saturation and nebulizer use,59 and nighttime and daytime symptoms (Appendix G, Evidence Tables 8–10).63 222

Three studies examined the impact of health IT on clinical outcomes for chronic obstructive pulmonary disease.88 89 220 These studies assessed mortality,88 QOL,220 dyspnea with activities of daily living, ability to exercise, fatigue, and emotional and physical health (Appendix G, Evidence Tables 8–10).89

Two studies assessed the impact of health IT on clinical outcomes for acute respiratory distress syndrome, including the management of mechanical ventilation, barotrauma, morbidity, oxygen requirement, and survival (Appendix G, Evidence Table 10).111 223

One study assessed the impact of health IT on clinical outcomes for chronic lung disease, focusing on QOL and functional level (Appendix G, Evidence Tables 8–10).43

One study assessed the use of health IT on clinical outcomes related to PCC for sleep apnea, including the use of continuous positive airway pressure and functional status (Appendix G, Evidence Tables 8–10).117

##### Mental Health

Six studies examined the impact of health IT on clinical outcomes for mental health.224–229 Two studies evaluated depression using a screening survey instrument.224 225 One study screened for anxiety.225 One study assessed subjective QOL in schizophrenia and psychotic disorders.229 One study assessed discomfort and work/social adjustment in obsessive-compulsive disorder.228 One study assessed various quality of life parameters and unmet needs (Appendix G, Evidence Tables 8–10).227

##### Obesity

Seven studies examined the impact of health IT on clinical outcomes for obesity.230–236 All seven studies assessed weight loss using a combination of weight, BMI, waist circumference, or body fat percentage. Two studies assessed physical activity.233 236 Three studies assessed dietary intake (Appendix G, Evidence Tables 8–10).233–235

##### Chronic Conditions/Health Problems

Four studies96 237–239 examined the impact of health IT on chronic health problems or chronic pain. For example, one study assessed the impact of having a chronic health condition on blood pressure.237 A second study assessed symptoms of dyspnea, health distress, self-reported global health, and also whether patients exercised and practiced stress management.96 A third study focused on back pain and assessed pain and life control, ability to decrease pain, and associated mental health parameters (Appendix G, Evidence Tables 8–10).238

##### Spinal Cord Injuries

Two studies examined the impact of health IT on outcomes for neurologic conditions, specifically spinal cord injuries, assessing function and QOL interventions118 as well as depression and well-being (Appendix G, Evidence Tables 8–10).240

##### Medication Safety and Adverse Events

Five studies evaluated the use of health IT applications for improving PCC in the areas of patient safety, medication safety and reconciliation, or potential adverse drug events.100 241–244 Three were considered significant. One of these focused on medication safety for pregnant women243 and another on potentially inappropriate prescriptions and therapeutic duplication by the physician and iatrogenic drug interactions.100 One study assessed polypharmacy and falls in a rural elderly population (Appendix G, Evidence Tables 8–10).112

##### Infectious Diseases

One study assessed the use of health IT to improve PCC involving antibiotic management and prophylaxis, with a focus on in-hospital mortality (Appendix G, Evidence Tables 8–10).105

##### Endocrinology/Bone Metabolism

One study evaluated the use of health IT to improve PCC for osteoporosis, focusing on bone mineral density evaluation, osteoporosis medication, and total calcium intake (Appendix G, Evidence Tables 8–10).108

##### Dental Disease

One study evaluated the use of health IT to improve PCC for periodontal disease management, focusing on gingival inflammation, plaque accumulation, and oral hygiene (Appendix G, Evidence Tables 8–10). 245

##### Obstetrics and Gynecology

One study evaluated the use of health IT to improve patient-centered decisionmaking regarding the mode of delivery in pregnant women with a previous Caesarian section (Appendix G, Evidence Tables 8–10).246

### How Does the Impact on Clinical Outcomes Vary by Type of Health IT Application?

Table 20 summarizes how clinical outcomes varied according to the type of health IT application (Chapter 2). Our analysis showed that among the studies we included in our review, the types of health IT applicationsmost frequently cited as having a positive impact on at least one clinical outcome were telehealth applications and care management tools. Personal health recordsand patient portals, and secure electronic messaging were studied less frequently, but they also had a statistically significant improvement in at least one clinical outcome in the majority of studies. None of the studies reporting on clinical outcomes involved the remaining type of health IT, shared decisionmaking.

Table 20 The impact on clinical outcomes by type of health IT application

Health IT Type | Number of Studies | Studies With at Least 1 Outcome Having a Positive Impact, n (%) | Studies With at Least 1 Outcome Having a Statistically Significant Positive Impact, n (%)
Care management tools | 22 | 20 (91) | 13 (59)
Telehealth | 37 | 36 (97) | 21 (57)
PHR/patient portals | 14 | 14 (100) | 9 (64)
Secure electronic messaging | 10 | 9 (90) | 6 (60)

IT: Information Technology, PHR: Personal Health Record

## Key Question 1c Are health IT applications that address one or more components of PCC effective in improving intermediate outcomes for patients, and how do these improvements vary by type of health IT application?

### General Study Characteristics

We identified 87 articles evaluating how health IT applications that address PCC affect intermediate outcomes (Appendix G, Evidence Tables 15–17). These articles predominantly targeted diabetes mellitus, heart disease, obesity, cancer, hypertension, and alcohol abuse (Table 21). They predominantly employed telemonitoring, clinical decision aids, and IT-guided self-management as the types of health IT applications (Table 22). The most frequently included components of PCC were related to coordination and integration of care, and enhanced clinician-patient relationship (Table 23). They most commonly addressed the intermediate outcomes of patient knowledge or behaviors and patient satisfaction (Tables 24–27). The study results suggested that intermediate outcomes generally improve with health IT interventions having one or more components of PCC.

Table 21 Studies addressing the effect of health IT applications on intermediate outcomes in specific target conditions, target populations, and care focus areas in studies^*^

Target care focus area | N (Specific Reference)
Diabetes | 13^26–28^ 198 202–204 209 211 277 278 288 210 197
Heart disease | 6^32^ 35–37 248 289
Cancer | 6^47^ 215 216 256 281 282
Hypertension | 6^52^ 56 57 85 218 259
Obesity | 7^231–234^ 236 254 290
Alcohol abuse | 5^87^ 237 248 291 292
Asthma | 2^61^ 222
Mental health | 3^66^ 226 229
Smoking cessation | 4^157^ 293–295
Menopause/hormone replacement therapy | 4^107^ 296–298
Pregnancy | 2^90^ 246
Adolescent behavior | 1^299^
Congestive heart failure | 1^300^
Chronic back pain | 1^238^
Chronic condition/health problem | 1^96^
Chronic pain | 1^301^
Chronic obstructive pulmonary disease | 1^89^
Fertility (in vitro fertilization) | 1^302^
Mechanical ventilation management in acute respiratory distress syndrome | 1^223^
Osteoporosis | 1^108^
Acute myocardial infarction | 1^303^
Periodontal disease management | 1^245^
Eating disorder | 1^304^
Recurrent headache | 1^115^
Safety knowledge | 1^305^
Sickle cell anemia | 1^306^
Substance abuse | 1^307^
Wound care | 2^121^ 308
Other or not specified | 11^122^ 132 309–317

IT: Information Technology

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 22 Studies addressing the effect of health IT applications on intermediate outcomes^*^

Type of Health Information Technology Application | N (Specific Reference)
Care Management Tools
Clinical decision aids | 16^27^ 33 36 53 60 90 215 216 218 220 223 226 282 297–299 301 318–320
IT-guided self-management | 16^63^ 66 85 198 199 202 204 222 229 232 233 238 254 259 288 292 294 304 321
IT-guided disease management | 14^26^ 37 56 89 96 108 202 203 216 231 278 288 301 303 322
Computer-assisted self-care | 12^57^ 66 89 115 231 234 245 277 288 307 322–324
Electronic medical records | 4^60^ 108 302 325 326
Care coordination tools | 1^327^
Telehealth
Telemonitoring systems | 18^28^ 57 121 183 203 209 248 266 270 289 306 323 328–335
Personal Health Record and Patient Portal Related Applications
Education via information technology | 9^52^ 56 63 85 209 245 281 296 304 305 336
Interactive lifestyle counseling | 7^199^ 232 234 290 293–295 307 337
mHealth | 6^26^ 47 61 256 288 327
Patient portals | 3^85^ 209 318 325
PHR | 3 237 256 302
Secure Electronic Messaging
Communication via e-mail | 8^27^ 32 52 56 85 236 323 325
Information exchange | 6^26^ 35 52 56 85 107
Social networking/peer-to-peer sites | 1 338
Shared Decisionmaking
Shared decisionmaking tools | 6^33^ 47 107 215 246 296 297 339

E-mail: Electronic Mail, IT: Information Technology, mHealth: Mobile Health, PHR: Personal Health Record

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 23 Studies addressing the effect of health IT applications on intermediate outcomes, broken down by specific components of PCC^*^

Component of PCC | N (Specific References)
Coordination and Integration of Care
Quality and safety | 25^27^ 87 89 90 96 107 121 202 203 215 232 233 245 246 254 281 282 290 294 296 299 301 305 318 320 322
Quality improvement | 21^57^ 61 63 89 108 199 216 220 222 234 236 248 278 282 291 297 301 303 304 320 332 334 336 338
Prevention and health promotion | 20^28^ 36 53 56 199 216 223 226 231 236 277 280 292 295 297 302 319 325 326 335 336 338
Integrated care | 25^27^ 87 89 90 96 107 121 202 203 215 232 233 245 246 254 281 282 290 294 296 299 301 305 318 320 322
Routine patient feedback to practice | 21^57^ 61 63 89 108 199 216 220 222 234 236 248 278 282 291 297 301 303 304 320 332 334 336 338
Transition and continuity | 20^28^ 36 53 56 199 216 223 226 231 236 277 280 292 295 297 302 319 325 326 335 336 338
Whole-Person Orientation
Respecting patients’ values, preferences and needs | 6^47^ 52 66 121 226 277 339
Alleviation of fear and anxiety | 2^26^ 57 321
Emotional support | 2 47 237 321
Physical comfort | 2^220^ 300
Exploring the disease and illness condition | 2 121 335
Enhanced clinician-patient relationship
Patient engagement in care | 38^32^ 33 35–37 47 53 56 57 60 61 63 66 85 107 115 198 199 204 218 220 226 229 231 236 238 248 256 259 277 280 291 292 295 300 302 305–307 323 324 335 339 340
Patient empowerment | 7^33^ 37 56 60 204 209 229 256 277 292
Clinical Information Systems
Practice-based learning | 3^89^ 282 338
Publicly available information on practices | 1^26^
Socio-Cultural Competence
Community outreach | 4 28 245 307 326

IT: Information Technology

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 24a Summary of the impact of health IT applications on intermediate outcomes for patients with diabetes mellitus

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact^*^
Benhamou, 2007^205^ | Telemonitoring systems | Patients receiving support through SMS based upon weekly review of glucose values vs. patients downloading SMBG values on a weekly basis without receiving SMS | Adherence of patients in (number of capillary blood glucose values transmitted) performing SMBG | +
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management, | Tailored self-management vs. computer-aided enhanced usual care | Fruit and vegetable screener (NCI All Day screener (unit not specified)) | +
Glasgow, 2006^202^ | IT-guided disease management, IT-guided self-management, | Tailored self-management vs. computer-aided enhanced usual care | Daily fat intake-block fat screener | −
Gomez, 2008 28 | Telemedicine | DIABTel telemedicine system vs. usual care | Glycemic control improvement | +
Gomez, 2008 28 | Telemedicine | DIABTel telemedicine system vs. usual care | Facilitating treatment changes | +
Gomez, 2008 28 | Telemedicine | DIABTel telemedicine system vs. usual care
Gomez, 2008 28 | Telemedicine | DIABTel telemedicine system vs. usual care | Help on diabetes education | +
Grant, 2008^247^ | Communication via email, IT-guided disease management, electronic medical records, information exchange, PHR | Web-based PHR that imported clinical and medications data, provided patient-tailored decision support, and enabled the patient to author a “Diabetes Care Plan” for electronic submission to their physician prior to upcoming appointments vs. PHR to update and submit family history and health maintenance information | Proportion of followup visits with diabetes mellitus–related medication changes among patients who submitted PHR journals to their physician’s electronic medical record | +
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Average number of physician and nurse visits | 0
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Average number of physician and nurse telephone calls | 0
Harno, 2006^198^ | IT-guided self-management | E-health application with a diabetes management system and a home care link vs. usual care that did not involve e-health | Average number of physician and nurse home care links | 0
Homko, 2007^203^ | IT-guided disease management, telemedicine | Women send blood glucose and other health data directly to their care providers via the Internet and received information from their health care provider vs. women in the control group were asked to record their information in a logbook, which was reviewed by the medical team at prenatal visit | Feelings of diabetes psychosocial self-efficacy | +
Laffel, 2007^204^ | IT-guided self-management, telemonitoring systems | Integrated glucose meters and electronic logbooks (electronic group) vs. paper log books (control group) | Self-monitoring blood glucose frequency >4 times per day | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Cell phone-based software, Well-Doc, vs. One Touch Ultra™ BG meters, blood glucose testing strips and lancets | Diet diabetes self-care | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Cell phone-based software, Well-Doc, vs. One Touch Ultra™ BG meters, blood glucose testing strips and lancets | Medications diabetes self-care | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Cell phone-based software, Well-Doc, vs. One Touch Ultra™ BG meters, blood glucose testing strips and lancets | Exercise diabetes self-care | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Cell phone-based software, Well-Doc, vs. One Touch Ultra™ BG meters, blood glucose testing strips and lancets | Improved knowledge of food (self-reported) | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Cell phone-based software, Well-Doc, vs. One Touch Ultra™ BG meters, blood glucose testing strips and lancets | Patient self-management skills improved | +
Quinn, 2008^26^ | IT-guided disease management, information exchange, mHealth | Cell phone-based software, Well-Doc, vs. One Touch Ultra™ BG meters, blood glucose testing strips and lancets | Patient confidence | +
Sequist, 2005^22^ | Care coordination tools | Evidence-based electronic physician reminders within the electronic medical record vs. usual care | Performance of recommended action for diabetes | +
Sequist, 2005^22^ | Care coordination tools | Evidence-based electronic physician reminders within the electronic medical record vs. usual care | Performance of recommended action for coronary artery disease | +
Sevick, 2008^288^ | IT-guided self-management | PDA based IT-guided self-management vs. usual care | Patient engagement in care | 0
Smith, 2008^27^ | Clinical decisionmaking aids, communication via email | Virtual consultation vs. no virtual consultation | Estimated 10-year coronary artery disease risk | +
Smith, 2008^27^ | Clinical decisionmaking aids, communication via email | Virtual consultation vs. no virtual consultation | Minnesota community aggregate optimal diabetes score | +
Tjam, 2006 278 | IT-guided disease management | Internet program vs. diabetes | Mean difference in patient satisfaction at 3 months | +
Tjam, 2006 278 | IT-guided disease management | Internet program vs. diabetes | Mean difference in patient satisfaction at 6 months | +
Williams, 2007^277^ | Computer-assisted self-care | Computer-assisted diabetes care intervention vs. usual care (did not set self-management goals, meet with a care manager, or receive followup phone calls) | Baseline to 12 month change in perceived competence | +

E-health: Electronic Health, IT: Information Technology, NCI: National Cancer Institute, SMBG: self-monitoring of blood glucose, SMS: short message service, PDA: personal digital assistant, PHR: personal health records

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 24b Overall grade of the quality of evidence in diabetes mellitus studies addressing intermediate outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.36
2 | Number of studies | 13
3 | Did the studies have important inconsistency? | No
4 | Were the studies sparse? | No
5 | Overall grade of evidence | High

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Table 25a Summary of the impact of health IT applications on intermediate outcomes for patients with heart disease

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact^*^
Dansky, 2008^289^ | Telemonitoring | Telemonitoring and usual care vs. control | Physical activity | 0
Dansky, 2008^289^ | Telemonitoring | Telemonitoring and usual care vs. control | Diet | 0
Dansky, 2008^289^ | Telemonitoring | Telemonitoring plus video and usual care vs control | Physical activity | 0
Dansky, 2008^289^ | Telemonitoring | Telemonitoring plus video and usual care vs control | Diet | 0
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient skips medicine | −
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient is sure about when to take heart failure medicine | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient recognition of own heart failure medicines
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient does not recognize any of own heart failure medicines | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient recognizes up to half of own heart failure medicines | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient recognizes more than half of own heart failure medicines | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient salts food | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient’s weighing behavior
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient has no scale | −
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient weighs self but not daily | −
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses vs. usual care | Patient weighs self daily | −
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient skips medicine | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient is sure about when to take heart failure medicine | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient recognition of own heart failure medicines
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient does not recognize any of own heart failure medicines | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient recognizes up to half of own heart failure medicines | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient recognizes more than half of own heart failure medicines | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient salts food | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient’s weighing behavior
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient has no scale | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient weighs self but not daily | +
Feldman, 2005^32^ | Communication via email | Email recommendations to nurses and additional resources (augmented intervention) vs. usual care | Patient weighs self daily | +
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Emotional sub scale on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Physical sub scale on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Total score on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Short Form-36 mental component score | −
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Short Form-36 physical component score | +
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Medication Use: ACE inhibitor | 0
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Medication use: beta blocker | 0
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Medication use: calcium channel | +
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Digoxin | −
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Diuretic loop | −
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Diuretic, k+-sparing | −
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Nitrate - long action | −
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Medication compliance, self-report >75% dose taken | +
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | Medication compliance, self-report ≤75% dose taken | +
Jerant, 2003^248^ | Telemedicine | Telemedicine vs. usual care | CSQ (Satisfaction) score | +
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Emotional sub scale on Minnesota Living With Heart Failure Questionnaire: mean | 0
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Physical sub scale on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Total score on Minnesota Living With Heart Failure Questionnaire: mean | −
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Short Form-36 mental component score | +
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Short Form-36 physical component score | +
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Medication use: ACE inhibitor | +
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Medication use: beta blocker | +
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Medication use: calcium channel | −
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Digoxin | −
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Diuretic loop | +
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Diuretic, k+-sparing | −
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Nitrate - long action | −
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Medication compliance, self-report >75% dose taken | −
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | Medication compliance, self-report ≤75% dose taken | −
Jerant, 2003^248^ | Telemedicine | Telephone vs. usual care | CSQ (Satisfaction) score | −
Lowensteyn, 1998 35 | Information exchange | Coronary risk profile to physician vs. no profile risk to physician | Ratio of high risk / low risk patients returning for followup | +
Subramanian, 2004^36^ | Clinical decision aids | Care suggestions generated with electronic medical record data and symptom ded from questionnaires mailed to patients within two weeks of scheduled outpatient visits vs. care suggestions generated with electronic medical record data alone | Patient satisfaction with most recent primary care visit (Change enrollment to 12 months) | +
Subramanian, 2004^36^ | Clinical decision aids | | Mean all-cause hospitalizations | +
Subramanian, 2004^36^ | Clinical decision aids | | Mean admissions for heart failure | +
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions displayed to physicians and pharmacists as they cared for enrolled patients vs. control group where suggestions were withheld | Mean number of all emergency department visits | −
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions displayed to physicians and pharmacists as they cared for enrolled patients vs. control group where suggestions were withheld | Mean number of heart disease specific emergency department visits | 0
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions displayed to physicians and pharmacists as they cared for enrolled patients vs. control group where suggestions were withheld | Mean number of all hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions displayed to physicians and pharmacists as they cared for enrolled patients vs. control group where suggestions were withheld | Mean number of heart disease specific hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | Printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in PIRS vs. control group where suggestions were withheld | Mean number of all emergency department visits | −
Tierney, 2003^37^ | IT-guided disease management | Printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in PIRS vs. control group where suggestions were withheld | Mean number of heart disease specific emergency department visits | 0
Tierney, 2003^37^ | IT-guided disease management | Printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in PIRS vs. control group where suggestions were withheld | Mean number of all hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | Printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in PIRS vs. control group where suggestions were withheld | Mean number of heart disease specific hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | Evidence-based cardiac care suggestions displayed to physicians and pharmacists as they cared for enrolled patients and a printed a note (rather than bottle labels) instructing the pharmacist to view the care suggestions in PIRS vs. Control group where suggestions were withheld | Mean number of all emergency department visits | −
Tierney, 2003^37^ | IT-guided disease management | | Mean number of heart disease specific emergency department visits | +
Tierney, 2003^37^ | IT-guided disease management | | Mean number of all hospitalizations | 0
Tierney, 2003^37^ | IT-guided disease management | | Mean number of heart disease specific hospitalizations | 0

ACE: Angiotensin-Converting Enzyme, CSQ: Client Satisfaction Questionnaire, DARTS: Decision Analysis in Routine Treatment, E-mail: Electronic Mail, IT: Information Technology, E-MAILPIRS: Pharmacist Intervention Recording System

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 25b Overall grade of the quality of evidence in heart disease studies addressing intermediate outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | Moderate
* | Mean Jadad score^†^ | −0.75
2 | Number of studies | 8
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | No
5 | Overall grade of evidence | Low

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Table 26a Summary of the impact of health IT applications on intermediate outcomes for patients with cancer

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact^*^
Frosch, 2008^282^ | Clinical decision aids | Traditional didactic decision aid providing information about PSA screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Total knowledge score / imputed data | +
Frosch, 2008^282^ | Clinical decision aids | Traditional didactic decision aid providing information about PSA screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Total knowledge score / complete cases only | +
Frosch, 2008^282^ | Clinical decision aids | Traditional didactic decision aid providing information about PSA screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | PSA screening - pretest choice | −
Frosch, 2008^282^ | Clinical decision aids | Traditional didactic decision aid providing information about PSA screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | PSA screening - reduction | +
Frosch, 2008^282^ | Clinical decision aids | Traditional didactic decision aid providing information about PSA screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Watchful waiting at pretest | −
Frosch, 2008^282^ | Clinical decision aids | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Total knowledge score / imputed data | +
Frosch, 2008^282^ | Clinical decision aids | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Total knowledge score / complete cases only | +
Frosch, 2008^282^ | Clinical decision aids | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | PSA screening - pretest choice | +
Frosch, 2008^282^ | Clinical decision aids | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | PSA screening - reduction | +
Frosch, 2008^282^ | Clinical decision aids | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Watchful waiting at pretest | −
Frosch, 2008^282^ | Clinical decision aids | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Total knowledge score / imputed data | +
Frosch, 2008^282^ | Clinical decision aids | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Total knowledge score / complete cases only | +
Frosch, 2008^282^ | Clinical decision aids | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | PSA screening - pretest choice | +
Frosch, 2008^282^ | Clinical decision aids | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | PSA screening - reduction | +
Frosch, 2008^282^ | Clinical decision aids | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition). | Watchful waiting at pretest | +
Glazebrook, 2006^281^ | Education via IT | Skinsafe multimedia intervention (for melanoma knowledge protective skin behaviors) vs. no intervention (control condition) | Melanoma knowledge score (0–12) | +
Glazebrook, 2006^281^ | Education via IT | Skinsafe multimedia intervention (for melanoma knowledge protective skin behaviors) vs. no intervention (control condition) | Skin protective behavior score (0–12) | +
Glazebrook, 2006^281^ | Education via IT | Skinsafe multimedia intervention (for melanoma knowledge protective skin behaviors) vs. no intervention (control condition) | Number of participants checking moles | −
Maslin, 1998^215^ | Clinical decision aids, shared decisionmaking tools | Intervention — interactive video disk system + usual care from multidisciplinary team vs. usual care from multidisciplinary team | Viewing IVD had impact on surgical choice | 0
Maslin, 1998^215^ | Clinical decision aids, shared decisionmaking tools | Intervention — interactive video disk system + usual care from multidisciplinary team vs. usual care from multidisciplinary team | Viewing IVD had impact on adjuvant therapy choice | 0
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for SDM for cancer symptoms care vs. usual care | Congruence between patient reported symptoms and those addressed in consult visit | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Used computerized system for SDM for cancer symptoms care vs. usual care | Importance-weighted congruence between patient reported symptoms and those addressed in consult visit | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Lung cancer patients whose physicians and nurses received QOL training and patients completed the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Actions taken / patient | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Lung cancer patients whose physicians and nurses received QOL training and patients completed the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Percentage of categories identified that were acted upon by the patient | +
Gaertner,2004 256 | mHealth, PHR, telemonitoring systems | Electronic pain diary vs. paper diary | Patient satisfaction | +
Gaertner,2004 256 | mHealth, PHR, telemonitoring systems | Electronic pain diary vs. paper diary | Patient preference for electronic diary | +
Gaertner,2004 256 | mHealth, PHR, telemonitoring systems | Electronic pain diary vs. paper diary | Health care support | +

EORTC-QLQ: European Organization for Research and Treatment of Cancer QOL Questionnaire

IT: Information Technology, IVD: interactive video disk, mHealth: Mobile Health, PHR: Personal Health Record, PSA: prostate specific antigen, QOL: Quality of Life

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 26b Overall grade of the quality of evidence in cancer studies addressing intermediate outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.67
2 | Number of studies | 6
3 | Did the studies have important inconsistency? | No
4 | Were the studies sparse? | No
5 | Overall grade of evidence | High

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Table 27a Summary of the impact of health IT applications on intermediate outcomes for patients with hypertension

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact^*^
Bosworth, 2009^218^ | Clinical decision aids | Patient behavioral intervention group vs. control group (hypertension reminder) whose providers did not receive decision support system | Estimated percent in blood pressure control | +
Bosworth, 2009^218^ | Clinical decision aids | Provider decision support system group vs. control group (hypertension reminder) whose providers did not receive decision support system | Estimated percent in blood pressure control | −
Bosworth, 2009^218^ | Clinical decision aids | Combined patient and provider intervention vs. control group (hypertension reminder) whose providers did not receive decision support system | Estimated percent in blood pressure control | 0
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services vs. usual care | Mean increase in patient-initiated threads | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services vs. usual care | Primary care visits | 0
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services vs. usual care | Telephone encounters | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services and pharmacist care vs. usual care | Mean increase in patient-initiated threads | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services and pharmacist care vs. usual care | Telephone encounters | +
Green, 2008^56^ | Communication via email, IT-guided disease management, education via IT, information exchange, telemonitoring systems | Blood pressure monitoring and patient Web services and pharmacist care vs. usual care | Primary care visits | 0
Parati, 2009^57^ | Computer-assisted self-care, telemedicine, telemonitoring systems | Teletransmitted home blood pressure vs. usual care | QOL at end of study per QOL assessment in hypertension patients questionnaire | +
Parati, 2009^57^ | Computer-assisted self-care, telemedicine, telemonitoring systems | Teletransmitted home blood pressure vs. usual care | Percent with daytime blood pressure normalization | +
Parati, 2009^57^ | Computer-assisted self-care, telemedicine, telemonitoring systems | Teletransmitted home blood pressure vs. usual care | Frequency of treatment changes | +
Rinfret, 2009^341^ | IT-guided self-management, telemonitoring systems | Participants in the intervention group were given a digital blood pressure monitor, log book, and access to an IT-supported, telephone-linked management system. | Medication adherence | +
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider education and alert vs. provider education | Medication adherence | 0
Roumie, 2006^52^ | Communication via email, education via IT, information exchange | Provider education, alert and patient education vs. provider education | Medication adherence | −
Santamore, 2008^85^ | Communication via email, IT-guided self-management, education via IT, patient portals, telemonitoring systems | Blood pressure measurements transmitted through a Internet based telemedicine system vs. no telemedicine system | Blood pressure monitoring | +

CDSS: Clinical Decision Support Systems, E-mail: Electronic Mail, IT: Information Technology, JNC: Joint National Committee on Prevention Detection Evaluation and Treatment of High Blood Pressure, QOL: Quality of Life

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 27b Overall grade of the quality of evidence in hypertension studies addressing intermediate outcomes

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.33
2 | Number of studies | 6
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | No
5 | Overall grade of evidence | Moderate

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

### Specific Findings

#### Intermediate Outcomes in Studies Addressing Diabetes Mellitus

Thirteen studies examined the impact of health IT applications addressing components of PCC on intermediate outcomes for patients with diabetes mellitus (Table 24a; Appendix G, Evidence Tables 15–18). The studies examined a wide variety of intermediate outcomes. The quality of these studies was high, but there was a great deal of variability in quality scores. A number of studies were randomized, double-blinded, and addressed loss to followup, but others did not address blinding and/or loss to followup. The overall grade of the strength of evidence in studies of intermediate outcomes addressing diabetes mellitus was high (Table 24b; Appendix G, Evidence Tables 15–18).

Grant (2008)247 randomized 11 primary care practices and 244 patients. Intervention practices had access to a diabetes-specific PHR that imported clinical and medications data, provided patient-tailored decision support, and enabled the patient to author a “Diabetes Care Plan” for electronic submission to his or her physician prior to upcoming appointments. Control practices received a PHR for patients to update and submit family history and health maintenance information. Half of the patients in the intervention arm (51%) who completed a Diabetes Care Plan indicated that they wished to improve their blood glucose control, 32 percent their blood pressure control, and 28 percent their control of LDL. Intervention patients who completed the Diabetes Care Plan (n=82) were more likely than the patients from the control group who submitted family history and health maintenance information (n=41) to have a medication initiation or dosage adjustment for hyperglycemia (29% vs. 15%; p=0.10), hypertension (13% vs. 0%; p=0.02), or hyperlipidemia (11% vs. 0%; p=0.03) during the subsequent episode of care (Table 24a; Appendix G, Evidence Table 18).

Smith (2008),27 in a study of primary care physicians in Rochester, Minnesota, compared no intervention with a telemedicine intervention that delivered specialty advice and evidence-based messages regarding medication management for cardiovascular risk. After each encounter in the telemedicine intervention, endocrinologists reviewed an abstract from the medical record and provided management recommendations and advice to the physician via email. Control physicians received email with periodic generic recommendations about cardiovascular risk reduction in diabetes. Outcome measures included diabetes care process outcomes, clinical outcomes, and the intermediate outcome of patient costs. As compared with the control, the intervention did not improve metabolic outcomes or reduce estimated coronary artery disease risk (adjusted mean difference, −1%, 95% CI −19 to 17). The mean total 1-year-cost savings was significantly greater for the intervention group ($2,311, 95% CI $266 to $4,667) (Table 24a; Appendix G, Evidence Table 18).

Quinn (2008)26 assessed the impact on HbA1c of a cellular phone-based diabetes-management-software system combined with Web-based data analytics and therapy optimization tools. Thirty patients with type 2 diabetes were recruited from three community practices for a 3-month study and randomized to the intervention, which consisted of cell phone-based software providing real-time feedback on patients’ blood glucose levels and sending computer-generated logbooks with treatment suggestions to patients’ health care providers. As compared with controls, the patients undergoing the intervention reported increased engagement in care and were more likely to control their diabetes based on knowledge of food choices (91% vs. 50%), confidence (100% vs. 75%), and the provider receiving regular blood sugars (100% vs. 36%) (Table 24a; Appendix G, Evidence Table 18).

Laffel (2007)204 examined glycemic control and persistence of glycemic improvements during long-term observational followup in two similar groups of adult and pediatric insulin-using patients (n=205) with HbA1c greater than or equal to 8.0 percent. The intervention group used integrated glucose meters and electronic logbooks and the control group used conventional meters and paper logbooks. Logbook data and HbA1c were monitored every 4 weeks for 16 weeks. The average daily documented self-monitored blood glucose frequency was significantly greater in the intervention group, with 48 percent of the electronic group versus 30 percent of the control group monitoring four or more times daily (p=0.03) (Table 24a; Appendix G, Evidence Table 18).

Harno (2006)198 randomized 175 patients with type 1 and 2 diabetes in primary care practices and medical center outpatient departments into a study group (n=101) or usual care (n=74). The study group had access to a health IT intervention consisting of an e-health application with a diabetes management system and a home care link; the care team was able to send text messages to patients in the study group. Usual care did not involve e-health. The outcome (HbA1c) was significantly lower in the study group than in the control group, but there was no significant difference in behaviors measured in terms of contacts with physicians and nurses (Table 24a; Appendix G, Evidence Table 18).

Gomez (2002)28 presented the results of a 6-month crossover pilot study of the use of a telemedicine system in 10 patients with type 1 diabetes. The system included a patient unit used by patients in their day-to-day activities and a medical workstation used by physicians and nurses at hospitals. This study represented a preliminary report; however, data were presented on patients’ evaluation of the system’s utility. Of the 60 patients, the following numbers of patients reported good utility (four or five on a five-point scale) in various domains: seven in glycemic control improvement, seven in help on diabetes education, eight in general use in diabetes care, and six in providing other advantages (not defined in article) over a traditional (face-to-face) system (Table 24a; Appendix G, Evidence Table 18).

Williams (2007),277 in a trial of 866 adult type 2 diabetes patients in heterogeneous primary care settings in Colorado, assessed whether a patient-centered, computer-assisted diabetes care intervention would increase perceived support for autonomy and perceived competence. The computer-assisted intervention increased patients’ perception of autonomy support relative to a control (p=0.05) (Appendix G, Evidence Table 18).

Benhamou (2007)205 enrolled 30 patients with poorly controlled diabetes (HbA1c: 7.5 to 10%) in a two-center, open-label, randomized 12-month two-period crossover study. Fifteen patients were randomly assigned to receive weekly medical support through short message service based upon weekly review of glucose values, while 15 patients continued to download self-monitored blood glucose values on a weekly basis without receiving short message service. After 6 months, patients crossed over to the alternate sequence for 6 additional months. Visits at the clinic were maintained every 3 months. The study measured the intermediate outcome adherence of patients in performing self-monitored blood glucose. The intervention had no effect on this outcome (Table 24a; Appendix G, Evidence Table 18).

Glasgow (2006)202 compared a computer-aided self-management intervention with computer-aided enhanced usual care in 335 primary care patients with type 2 diabetes from fee-for-service and health maintenance organizations. In addition to computer-assisted self-management assessment and feedback, the intervention consisted of tailored goal-setting, barrier identification, and problem-solving, followed by health counselor interaction and telephone followup. The study measured changes in health knowledge and behavior. Although the authors observed a trend favoring the intervention, the effect was not statistically significant (Table 24a; Appendix G, Evidence Table 18).

Homko (2007)203 randomized women with gestational diabetes mellitus (n=57) either to an Internet group (n=32), which had access to a Web site established for documentation of glucose values and communication between the patient and the health care team (i.e., IT-guided self-management and disease management), or to a control group (n=25). The study measured the maternal feelings of diabetes self-efficacy at study entry and before delivery. Women in the Internet group demonstrated significantly more feelings of self-efficacy at the study’s end: mean score on a five-point scale, 4.0 (0.5) in the control group versus 4.4 (0.5) in the Internet group (p=0.053) (Table 24a; Appendix G, Evidence Table 18).

Tjam (2006)278 randomized patients with type 2 diabetes in Ontario, Canada to an Internet disease management program (n=37) or to an in-person program using a Diabetes Management Center (n=20). The authors staggered enrollment at 3, 6, and 12 months. In addition to the clinical endpoints of HbA1c, HDL, LDL, and blood glucose levels, the study reported on patient satisfaction with care. The Internet group demonstrated improvement in patient satisfaction levels at 3 and 6 months, whereas the control group did not. In the Internet group, the mean difference in satisfaction at 3 months when compared to baseline was 0.383 (0.3) on a 4-point scale (p=0.0150); the mean difference in satisfaction at 6 months when compared to baseline was 0.58 (0.38), p=0.014 (Table 24a; Appendix G, Evidence Table 18).

Sequist (2005)22 showed that computer-aided disease management in the form of clinical reminders to physicians within their electronic medical record improved quality-of-care by increasing the completion of recommended actions for diabetes (Table 24a; Appendix G, Evidence Table 18).

Sevick (2008)279 reported that PDA-based IT-guided self-management did not have a significant effect on patient engagement in care, when compared with usual care. We included this study in the evidence on Key Question 1c because the study seemed to be assessing patient engagement in care as a form of health behavior.

#### Intermediate Outcomes in Studies Addressing Heart Disease

Six studies examined the impact of health IT applications addressing components of PCC on intermediate outcomes for patients with heart disease (Table 25a; Appendix G, Evidence Tables 15–17 and 19). Improved patient satisfaction was the most common intermediate outcome in these studies. The quality of these studies was moderate—nearly all of the studies were lacking information on loss to followup and about half were not double-blinded. The overall grade of the strength of evidence in the studies of intermediate outcomes addressing heart disease was low (Table 25b, Appendix G, Evidence Tables 15–17 and 19).

In a study by Feldman (2005)32 nurses treated patients randomly assigned to usual care or one of two intervention groups. The basic intervention was an email to the nurse highlighting six heart failure-specific clinical recommendations that would aid in ongoing care and discharge planning, in addition to counseling the patient in self-care management techniques. The augmented intervention supplemented the initial nurse reminder with additional clinician and patient resources. Clinicians conducted patient interviews conducted 45 days after admission to measure self-management behaviors and heart failure-specific outcomes. The basic intervention yielded a higher QOL score than did usual care (p≤0.05). In addition, the interventions had a positive impact on medication knowledge, diet, and weight monitoring. The basic intervention was more cost-effective than the augmented intervention in improving clinical outcomes (Table 25a; Appendix G, Evidence Table 19).

Subramanian (2004)36 studied primary care physicians at two Veterans Affairs Medical Centers who were treating heart failure patients. Intervention physicians were assigned to receive care suggestions generated with electronic medical record data and symptom data obtained from questionnaires mailed to patients within 2 weeks of scheduled outpatient visits. The control group received suggestions generated with electronic medical record data alone. The authors assessed physician adherence to heart failure guidelines, as well as patients’ New York Heart Association class, QOL and satisfaction with care, at 6 and 12 months after enrollment. At 12 months, intervention patients were more satisfied with their physicians (p<0.02) and primary care visit (p<0.02) (Table 25a; Appendix G, Evidence Table 19).

Tierney (2003)37 assessed the effects of computer-based cardiac-care suggestions on the care provided by primary care physicians and pharmacists. The care suggestions for chronic heart failure fell into five major categories according to the most recent clinical guidelines for cardiac care. One of the major categories included suggestions on improving intermediate outcomes in patients such as encouraging regular exercise, smoking cessation, and weight reduction. However, care suggestions generated by the electronic medical record system did not improve intermediate outcomes in heart failure and ischemic heart disease patients. Patient knowledge and attitudes toward guidelines after the intervention remained unchanged (Table 25a; Appendix G, Evidence Table 19).

Lowensteyn (1998)35 determined the feasibility of using patient-specific, multifactorial computerized risk profiles as a clinical decision aid to support primary prevention of coronary heart disease. Study participants were 253 community physicians randomized into profile and control groups, and 958 of their patients. Profile group physicians received coronary risk profiles of their patients within 10 working days after the baseline patient assessment, so as to obtain early feedback. The control group received profiles only if the patient was clinically re-evaluated during a 3-month followup. The intermediate outcome specified was the ratio of high-risk to low-risk patients (as determined by a Framingham-based multivariate regression model of risk) who returned for a followup visit. This ratio was significantly higher (p<0.05) in the profile group than in the control group (Table 25a; Appendix G, Evidence Table 19).

Jerant (2003)248 compared three post-hospitalization nursing-care models for the reduction of rehospitalizations for heart failure within 180 days of hospital discharge. Clinicians visited the subjects at baseline and at 60 days. The patients received one of three care modalities in the interim: video-based home telehealth, telephone calls, and usual care. The study randomized 37 eligible subjects—13 to the home telehealth group and 12 each to the telephone and usual care groups. Patient self-care adherence, adherence to medications, health status, and satisfaction did not differ among the three groups. However, the authors designed the study only to detect a difference between the groups in readmission charges (the primary outcome) and not for the intermediate outcomes (Table 25a; Appendix G, Evidence Table 19).

Dansky (2008)280 conducted a randomized field study of 284 patients with heart failure to determine the effects of telemonitoring (either one-way or two-way monitoring) on medication use and physical activity. With regard to intermediate outcomes, there was greater reduction in physical activity among patients using telemonitoring than among control patients (p<0.001) (Table 25a; Appendix G, Evidence Table 19).

#### Intermediate Outcomes in Studies Addressing Cancer

Six studies examined the impact of health IT applications addressing components of PCC applications on intermediate outcomes for patients with cancer (Table 26a; Appendix G, Evidence Tables 15–17 and 20). The studies examined a variety of intermediate outcomes. The quality of the studies was high, with little variation across studies. Quality scores were lowered mainly because the studies did not describe loss to followup. The overall grade of the strength of evidence in studies of intermediate outcomes addressing cancer was high (Table 26b; Appendix G, Evidence Tables 15–17 and 20).

Gaertner (2004)256 conducted a randomized crossover trial in which 24 patients suffering from chronic cancer and noncancer pain completed the electronic and paper versions of a pain diary. After 4 weeks, patient satisfaction was higher for the electronic version. Fifteen users said that the electronic version better supported their health care, as compared to four users for the paper version (p=0.012). Twenty said that they would like to use the electronic version again, as compared with four for the paper version (p<0.001) (Table 26a; Appendix G, Evidence Table 20).

Taenzer (2000)216 randomized 53 patients at a lung cancer outpatient clinic in Alberta, Canada to assess whether the use of a computerized version of a 30-item QOL questionnaire before a clinic appointment would improve patient care (compared to a paper version). In the intervention group, clinicians addressed more of the questionnaire’s QOL issues during the clinic appointment than in the control group (6.4 +/− 4.1 items in the experimental group vs. 2.5 +/− 2.9 items in the control group, p<0.01). However, patients in both groups reported being equally satisfied with the treatment (Table 26a; Appendix G, Evidence Table 20).

Maslin (1998)215 pilot-tested an interactive video disk system using a shared decisionmaking program for women with early breast cancer. The study’s aim was to determine the acceptability of the system as a means of providing information about the risks and benefits of treatment choices. Ninety-two percent of patients using the video disk said they would recommend it, which we considered an indication of satisfaction with the intervention (Table 26a; Appendix G, Evidence Table 20).

Glazebrook (2006)281 evaluated the impact of an interactive multimedia intervention on patients’ knowledge about melanoma and on their skin-protective behaviors. Doctors and nurses in five family practices prescribed the intervention to patients with high-risk skin characteristics. Two hundred fifty-nine patients received the intervention, and 330 patients were matched controls. At the 6-month followup, the intervention group had higher knowledge scores than the control group (3.71 vs. 3.03, p ≤0.001), reported more protective skin behaviors (5.36 vs. 5.06, p=0.007), and were more likely to report mole checking (OR 1.67, 95% CI 1.04 to 2.70, p=0.035) (Table 26a; Appendix G, Evidence Table 20).

Ruland (2003)47 evaluated how a computerized system might better align a cancer patient’s self-reported symptoms and preferences to those addressed in the clinician-patient consultation, and thus improve patient satisfaction. Cancer patients scheduled for an outpatient visit used a tablet computer to report their symptoms and preferences prior to their consultation. The study authors processed, printed, and provided the information to the patient and clinician in the intervention group (n=27), but not the control group (n=25). The intervention had no effect on the main intermediate outcome (patient satisfaction) (Table 26a; Appendix G, Evidence Table 20).

Frosch (2008)282 evaluated the effects of patient decision support Web sites on decision quality for men considering prostate cancer screening. Six hundred eleven men older than 50 years were randomly assigned to one of four Internet interventions: a traditional didactic decision aid providing information about prostate-specific antigen screening options; a chronic disease trajectory model for prostate cancer, followed by a time-trade-off exercise; both the didactic decision aid and the chronic disease trajectory model; or links to credible public Web sites about prostate cancer (control group). The outcome measures were prostate-specific antigen test choice, prostate cancer treatment preferences, knowledge and concern about prostate cancer, and decisional conflict. Participants assigned to view public Web sites were less likely to review information (116 participants [76.8%] reviewed) than those assigned to intervention groups (399 [86.7%] reviewed; p=0.004). Greater reductions in prostate-specific antigen screening from pretest to post-test were observed among participants assigned to the traditional decision aid (−9.1%) or chronic disease trajectory model (−8.7%) than to the combination (−5.3%) or control (−3.3%) groups (p=0.047). Preferences for watchful waiting increased significantly in all four groups (baseline, 219 [35.8%]; followup, 303 [66.2%]; p=0.001). Knowledge scores were lowest for those assigned to public Web sites (mean [standard deviation] score, 7.49 [0.19] of questions correct) and highest for the traditional decision aid (8.65 [0.18] of questions correct; p=0.005). The authors concluded that public Web sites about prostate cancer provided less effective decision support than the specially designed Internet decision aids (Table 26a; Appendix G, Evidence Table 20).

#### Intermediate Outcomes in Studies Addressing Other Diseases and Conditions

##### Hypertension

Six studies examined the impact of health IT applications addressing components of PCC on intermediate outcomes for patients with hypertension (Table 27a; Appendix G, Evidence Tables 15–17 and 21). Overall, the quality of these studies was high, but there was variation across studies in quality, based on a lack of both blinding and a description of loss to followup. The overall grade of the strength of evidence in studies of intermediate outcomes addressing hypertension was high (Table 27b; Appendix G, Evidence Tables 15–17 and 21).

Bosworth (2009)218 conducted a cluster-randomized trial with two-year followup among patients with hypertension enrolled from a Veterans Affairs Medical Center primary care clinic. Primary care providers in the intervention group (n=17) received computer-generated, guideline-concordant medical therapy reminders; control providers (n=15) received a reminder at each visit. Patients received usual care or a bimonthly tailored nurse-delivered behavioral telephone intervention to improve hypertension treatment (Table 21). The primary outcome was the proportion of patients who achieved a blood pressure less than 140/90 mm Hg (less than 130/85 for diabetic patients) over the 24-month intervention. There were no significant differences in the amount of change in blood pressure control in the three intervention groups as compared with the hypertension reminder control group. The only intermediate outcome considered in the study was provider interaction with the provider decision support intervention. For the visits in which this was displayed, providers interacted with the intervention 57 percent of the time (528 of 929 visits) (Table 27a; Appendix G, Evidence Table 21).

In Parati (2009),57 12 general practitioners screened 391 consecutive hypertensive patients; the study randomized 329 of these patients to either usual care based on office blood pressure (group A, n=113) or to integrated care on the basis of telemonitored home blood pressure (group B, n=216). The authors performed 24-hour ambulatory blood pressure monitoring at baseline and after 6 months; thereafter, they monitored treatment using either office or home blood pressure values. The intermediate endpoints were a need for treatment changes during followup and health care costs. There were less frequent treatment changes in group B than in group A (9 vs. 14%, p<0.05). Differences in the cost of patient management between the groups were not statistically significant (Table 27a; Appendix G, Evidence Table 21).

Green (2008)56 randomized 778 participants with uncontrolled essential hypertension and Internet access to: usual care (control); home blood pressure monitoring and secure patient Web site training (intervention); or home blood pressure monitoring, secure patient Web site training, and pharmacist care management delivered through Web communication (augmented intervention). Intermediate outcomes included the mean number of antihypertensive medication classes filled. At baseline, patients took a mean of 1.6 antihypertensive medication classes. At 12 months, the mean (standard deviation) number of antihypertensive medication classes filled in the intervention group, 1.94 (0.91), was significantly higher than the 1.69 (0.91) in the control group (p<0.01). The augmented intervention group had an increase in the mean (standard deviation) number of antihypertensive medication classes to 2.16 (0.93), which was significantly greater than that for both the control group (p<0.001) and the intervention group. Physical activity, BMI, and satisfaction with the health plan did not differ among the three groups. Thus, the intervention improved participation in care, as represented by prescription filling, but it had no effect on any other intermediate outcomes (Table 27a; Appendix G, Evidence Table 21).

Roumie (2006)52 randomly assigned 182 providers caring for 1,341 hypertensive patients to one of three interventions: receiving a Web link to the Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (control); receiving the Web link and a computer alert notifying them of the patient’s blood pressure (intervention); or receiving the Web link, a computer alert, and a letter educating the patient about ways to control his or her blood pressure (augmented intervention). Intermediate outcomes were closely related to the process measures reported in the section on Key Question 1a. The study did not show improvement in patient education in the third group as compared with other groups. There were no differences in medication adherence score among the three study groups (Table 27a; Appendix G, Evidence Table 21).

Rinfret (2009)259 studied the impact of IT-guided self-management on adherence to medication use in 223 primary care patients. At the end of the study there was a trend toward improved drug adherence in the intervention subjects as measured using pharmacy data (Table 27a; Appendix G, Evidence Table 21).

Santamore (2008)85 developed an Internet-based telemedicine system to improve control of hypertension and other modifiable risk factors. To minimize cost, the subjects used home monitors for blood pressure measurements and entered these values into the telemedicine system. The study randomized subjects (n=464) with 10 percent or greater 10-year risk of cardiovascular disease and with treatable risk factors into two groups, a control group and a telemedicine group. Each subject received a home sphygmomanometer with memory. The telemedicine group recorded and entered blood pressure at least weekly. During office visits, the blood pressure meters were downloaded, and recorded blood pressure was compared with blood pressure values transmitted via telemedicine. Results showed relatively little difference between telemedicine blood pressure values and meter recorded values downloaded during office visits (Table 27a; Appendix G, Evidence Table 21).

##### Obesity

Seven studies examined the impact of health IT applications addressing components of PCC on intermediate outcomes for patients with obesity. Of these studies, the most common intermediate outcome was patient engagement in care and QOL and safety.268 274 283–287 Napolitano (2003)236 showed that communication via a Web site improved prevention and health-promotion activities, in this case, physical activity. Rothert (2006)254 showed that IT-guided self-management (using a specially designed Web site) was found to be easy to use and understood by patients who used it for weight management (Appendix G, Evidence Tables 15–17).

##### Asthma

Two studies examined the impact of health IT applications addressing components of PCC on intermediate outcomes for patients with asthma. Chan (2003)61 found no influence of a clinical decision support on quality or patient engagement of care. Jan (2007)222 showed that telemonitoring and IT-guided self-management improved the quality of asthma care (Appendix G, Evidence Tables 15–17).

### How Does the Impact on Intermediate Outcomes Vary by Type Of Health IT Application?

Table 28 summarizes the impact of health IT applications addressing components of PCC on intermediate outcomes. We summarized the results in this table based on the five major health IT types described in Chapter 2. The analysis of the summary table demonstrated that, among all reviewed health IT applications, telehealth was most frequently cited as affecting intermediate outcomes. However, less than half of the telehealth applications had a statistically significant positive effect on at least one intermediate outcome. In contrast, for three of the health IT types that had fewer studies of intermediate outcomes (PHR/patient portals, secure electronic messaging, and shared decisionmaking tools), the majority of studies reported a statistically significant positive effect on at least one intermediate outcome. This observation makes it difficult to formulate any strong conclusion about how the impact on intermediate outcomes varies by type of health IT application.

Table 28 The impact on intermediate outcomes by type of health IT application

Health IT Type | Number of Studies | Studies With at Least 1 Outcome Having a Positive Impact, n (%) | Studies With at Least 1 Outcome Having a Statistically Significant Positive Impact, n (%)
Care management tools | 9 | 8 (89) | 4 (44)
Telehealth | 21 | 19(90) | 8 (38)
PHR/patient portals | 8 | 7 (88) | 6 (75)
Secure electronic messaging | 8 | 7 (88) | 6 (75)
Shared decisionmaking | 3 | 2 (67) | 2 (67)

IT: Information Technology, PHR: Personal Health Record

## Key Question 1d Are health IT applications that address one or more components of PCC effective in improving responsiveness to the needs and preferences of individual patients, and how do these improvements vary by type of health IT application?

### General Study Characteristics

A total of 14 articles applied to this key question. The studies most commonly targeted cancer (Table 29). They most often employed the clinical decision aids, IT-guided disease management, and telemedicine as the health IT applications (Table 30). The studies most commonly addressed the PCC components related to quality and safety, quality improvement, and patient engagement in care (Table 31). The results suggested that responsiveness to the needs, preferences, and values of individual patients generally improve with health IT interventions having one or more components of PCC, but the available data are too limited to draw firm conclusions for any targeted clinical focus area other than cancer.

Table 29 Studies addressing the effect of health IT applications on responsiveness to patient needs, preferences, and values in specific target conditions, target populations, and care focus areas^*^

Target Care Focus Area | N (Specific Reference)
Cancer (breast) | 3^47^ 216 282
Asthma /chronic obstructive pulmonary disease | 1 220
COPD | 1 89
Menopause/hormone replacement therapy | 2 107 296
Mental health (depression and anxiety) | 1^342^
Obesity | 2^254^ 343
Osteoporosis | 1^108^
Pregnancy | 1^90^
Smoking | 1^293^
Wounds | 1^333^

COPD = chronic obstructive pulmonary disease, IT = information technology, PCC = patient-cnetered care

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 30 Studies addressing the effect of health IT applications on responsiveness to patient needs, preferences, and values^*^

Health IT Application | N (Specific Reference)
Care Management Tools
Clinical decision support | 4^142^ 249 344 345
IT-guided disease management | 3^158^ 162 345
IT-guided self-management | 2 158 283
Electronic medical records | 2 162 249
Electronic prescribing | 1 346
Telehelath
Telemedicine | 1^308^
Personal Health Record and Patient Portal Related Applications
Education via information technology | 1 347
Interactive lifestyle counseling | 1 348
mHealth | 2 189 343
Secure Electronic Messaging
Information exchange | 1 192
Shared Decisionmaking
Shared decisionmaking tools | 3 189 192 347

IT: Information Technology, PHR: Personal Health Record

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 31 Studies addressing the effect of health IT applications on responsiveness to a patient’s needs, preferences, and values, broken down by specific components of PCC^*^

Component of PCC | N (Specific References)
Coordination and Integration of Care
Quality and safety | 7 344 158 192 346 283 142 347
Quality improvement | 5^344^ 158 345 162 249
Integrated care | 3^346^ 162 348
Routine patient feedback to practice | 3 189 249 308
Prevention and health promotion | 1 345
Transition and continuity | 1 308
Whole-Person Orientation
Respecting patients’ values, preferences, and needs | 1^189^
Emotional support | 1 189
Physical comfort | 1 249
Enhanced Clinician-Patient Relationship
Patient engagement in care | 4 189 192 249 343
Clinical Information Systems
Practice-based learning | 2 344 158

IT: Information Technology

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

### Specific Findings

#### Improving the Responsiveness to Needs, Values, and Preferences of Patients in Studies Addressing Cancer

Three studies addressed the impact of health IT on the needs, values, or preferences of patients with cancer (Table 32a; Appendix G, Evidence Tables 22–25). The overall quality of these studies was high, with little variability across studies. The overall grade of the strength of evidence in these studies was low (Table 32b; Appendix G, Evidence Tables 22–25).

Table 32a Summary of the impact of health IT applications on responsiveness to a patient’s needs, preferences, and values for patients with cancer

Study, Year | Health IT Application | Intervention Compared | Outcomes Measure | Positive Impact^*^
Frosch, 2008^282^ | Clinical decision aids | Traditional didactic decision aid providing information about PSA screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources | PSA screening - pretest choice | +
Frosch, 2008^282^ | Clinical decision aids | Traditional didactic decision aid providing information about PSA screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources | PSA screening - reduction | +
Frosch, 2008^282^ | Clinical decision aids | Traditional didactic decision aid providing information about PSA screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources | Watchful waiting at pretest | −
Frosch, 2008^282^ | Clinical decision aids | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources | PSA screening - pretest choice | +
Frosch, 2008^282^ | Clinical decision aids | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources | PSA screening - reduction | +
Frosch, 2008^282^ | Clinical decision aids | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources | Watchful waiting at pretest | −
Frosch, 2008^282^ | Clinical decision aids | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | PSA screening - pretest choice | +
Frosch, 2008^282^ | Clinical decision aids | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | PSA screening - reduction | +
Frosch, 2008^282^ | Clinical decision aids | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | Watchful waiting at pretest | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | congruence between patient reported symptoms and those addressed in consult visit | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Importance-weighted congruence between patient reported symptoms and those addressed in consult visit | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–10) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–15) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–20) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–25) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–30) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–40) | +
Ruland, 2003^47^ | mHealth, shared decisionmaking tools | Computerized system for shared decisionmaking for cancer symptoms care vs. usual care | Number of reported symptoms (0–50) | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Actions taken / patient | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Percentage of categories identified that were acted upon | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Physical functioning (higher indicate better function) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Role functioning (higher indicate better function) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Emotional functioning (higher indicate better function) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Cognitive functioning (higher indicate better function) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Social functioning (higher indicate better function) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Global functioning (higher indicate better function) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Number of functional scales indicating compromised function (mean) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Fatigue (higher scores indicate more symptomatology-mean) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Nausea and vomiting (higher scores indicate more symptomatology-mean) | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Pain (higher scores indicate more symptomatology-mean) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Dyspnea (higher scores indicate more symptomatology-mean) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Sleep disturbance (higher scores indicate more symptomatology) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Appetite (higher scores indicate more symptomatology) | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Constipation (higher scores indicate more symptomatology) | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Diarrhea (higher scores indicate more symptomatology) | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Financial difficulties (higher scores indicate more symptomatology) | +
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Number of symptom scales indicating compromised functioning | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Number of functional and symptom scales indicating compromised function | −
Taenzer, 2000^216^ | Clinical decision aids, IT-guided disease management | Clinician receive QOL training and patients complete the computerized EORTC QLQ-C30 vs. patients completed a paper-and pencil version of the EORTC QLQ-C30 only | Total number of items endorsed | +

IT: Information Technology, mHealth: Mobile Health, PSA: Prostate Specific Antigen

EORTC-QLQ: European Organization for Research and Treatment of Cancer Quality of Life Questionnaire, IT: Information Technology, PSA: Prostate specific antigen, QOL: Quality of Life

* “+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 32b Overall grade of the quality of evidence in cancer studies addressing responsiveness to the needs and preferences of individual patients

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.57
2 | Number of studies | 3
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | Yes
5 | Overall grade of evidence | Low

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Taenzer (2000)216 evaluated the impact of providing patient-specific computerized QOL information to clinic staff before an appointment in a lung cancer outpatient clinic. The authors found that a computerized screening tool was effective in increasing detection of QOL problems during the clinic appointment and resulted in a trend toward more concerns being charted. The tool also marginally increased the level of action taken with regard to these concerns. Patients reported being equally and highly satisfied with the treatment in both groups (Table 32a; Appendix G, Evidence Table 25).

Ruland (2003)47 conducted an RCT with Norwegian cancer patients that evaluated the feasibility and impact of a computerized decision support system (intervention group) on the congruence between patients’ reported symptoms and preferences, and those addressed in the patient consultation. The computerized system provided intervention clinicians with information regarding patients’ reported symptoms and preferences prior to consultation. Results indicated that were no significant group differences in patient satisfaction as measured by the “Patient Satisfaction with Decision Making” questionnaire (p=0.45) between the intervention group and the control group that did not use the computerized decision support system. However, clinicians in the intervention group addressed significantly more of patients’ reported symptoms during patient consultations. Given a mean of approximately 15 symptoms, an average of approximately 51 percent was addressed in the experimental group, versus only 19 percent in the control group. These group differences persisted when patients’ symptoms were weighted according to patients’ importance ratings. Despite its small sample size, this pilot study demonstrated significant initial effects of this intervention (Table 32a; Appendix G, Evidence Table 25).

Frosch (2008)282 conducted an RCT to evaluate the effects of patient decision support Web sites on decision quality for men considering prostate cancer screening. This study revealed that the Web site was more effective at impacting decision quality and prostate cancer knowledge. The intervention also led to reductions in requests for prostate-specific antigen testing. Preferences for watchful waiting increased significantly in all four groups (baseline, 219 [35.8%]; followup, 303 [66.2%]; p<0.001) (Table 32a; Appendix G, Evidence Table 25).

### How Does the Responsiveness to Patient Needs, Preferences, and Values Vary by Type of Health IT Application?

Table 33 summarizes the impact of health IT applications addressing components of PCC on responsiveness to patient needs, preferences, and values. The results in this table were summarized based on the five major health IT types described in Chapter 2. There were an insufficient number of studies to address the question of whether responsiveness to patient needs, preferences, and values vary by type of health IT application.

Table 33 The impact on responsiveness to patient needs, preferences, and values by type of health IT application

Health IT Type | Number of Studies | Studies With at Least 1 Outcome With a Positive Impact, n (%) | Studies With at Least 1 Outcome With a Statistically Significant Positive Impact, n (%)
Care Management | 9 | 4 (44) | 2 (22)
Telehealth | 7 | 6 (86) | 3 (43)
PHR/patient portals | 4 | 3 (75) | 2 (50)
Secure electronic messaging | 1 | 1 (100) | 1 (100)

IT: Information Technology, PHR: Personal Health Record

## Key Question 1e Are health IT applications that address one or more components of PCC effective in improving shared decisionmaking between patients, their families, and providers; patient-clinician communication; and access to medical information; and how do these improvements vary by type of health IT application?

### General Study Characteristics

We identified 25 articles evaluating how health IT applications affect: shared decisionmaking between patients, their families, and providers; patient-clinician communication; and access to medical information. The articles predominantly targeted cancer, heart disease, and hormone replacement therapy for perimenopausal and postmenopausal care (Table 34). The articles most commonly employed clinical decision aids, shared decisionmaking tools, and education via IT as the health IT applications (Table 35). They predominantly addressed the PCC components related to quality and safety, patient engagement in care, and quality improvement (Table 36). They most commonly studied the outcomes of health care choices after exposure to health IT interventions, satisfaction with decisions, decisional conflict, and communication with providers. The studies provided moderate strength of evidence that health IT interventions having one or more components of PCC can help to improve shared decisionmaking with patients, their families, and providers, or help to improve patient-clinician communication, and provide access to medical information for patients with heart disease or cancer.

Table 34 Studies addressing the effect of health IT applications on shared decisionmaking, patient-clinician communication, and access to medical information in specific target conditions, target populations, and care focus areas

Target Focus Care Area | N (Specific Reference)
Heart disease | 5 41 56 33 35 50 350
Diabetes | 1^28^
Cancer | 3 215 282 349
Chronic condition/health problem | 1 96
Genetic counseling | 1 102
Menopause/hormone replacement therapy | 3 107 296 339
Migraine | 1 351
Obesity | 2 290 343
Pregnancy | 2 90 246
Primary care | 2^318^ 352
Skin lesions | 1 116
Smoking | 1 293
Wound care | 2 121 333

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 35 Studies addressing the effect of health IT applications on shared decisionmaking with patients, their families, and providers; patient-clinician communication; and access to medical information

Health IT Application | N (Specific Reference)
Care Management Tools
Clinical decision aids | 6^33^ 50 90 215 282 318
Computer-assisted self-care | 1 323 351
IT-guided disease management | 3^50^ 56 96
Personal Health Record and Patient Portal Related Applications
Education via IT | 4^56^ 102 296 352 353
Interactive lifestyle counseling | 2 290 293
Patient portals | 1 318
mHealth | 1^343^
Shared Decisionmaking
Shared decisionmaking tools | 7^33^ 102 107 215 246 296 339
Telehealth
Telemedicine | 4^28^ 41 121 333
Telemonitoring systems | 3 56 116 350 352
Secure Electronic Messaging
Information exchange | 4 35 56 107 349
Communication via e-mail | 1 56

E-mail: Electronic Mail, IT: Information Technology, mHealth: Mobile Health

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

Table 36 Studies addressing the effect of health IT applications on shared decisionmaking with patients, their families, and providers; patient-clinician communication; and access to medical information, broken down by specific components of PCC

Component of PCC | N (Specific References)
Coordination and Integration of Care
Quality and safety | 11^90^ 96 107 116 121 215 246 282 290 296 318 320
Quality improvement | 4^41^ 282 320 351 352
Integrated care | 3^102^ 116 293 353
Routine patient feedback to practice | 4 41 116 333 349
Prevention and health promotion | 3 28 56 102
Transition and continuity | 1 333
Whole-Person Orientation
Respecting patients’ values, preferences and needs | 3 121 339 351
Alleviation of fear and anxiety | 1 50
Exploring the disease and illness condition | 1 121
Enhanced Clinician-Patient Relationship
Patient engagement in care | 11^33^ 35 41 50 56 107 339 343 349–352
Patient empowerment | 3^33^ 50 56 353
Clinical Information Systems
Practice-based learning | 1 282
Socio-Cultural Competence
Community outreach | 2 28 33

IT: Information Technology

* Table includes all of the studies that were included in the evidence tables, not just the studies of frequently studied conditions that were highlighted in the text.

### Specific Findings

#### Outcomes Related to Improved Shared Decisionmaking With Patients, Their Families, and Providers; Patient-Clinician Communication; and Access to Medical Information in Patients With Diabetes Mellitus

One study addressed diabetes mellitus (Table 37a; Appendix G, Evidence Tables 26–29). This study received a moderate quality score because of the lack of blinding and the lack of detailed information on loss to followup. The overall grade of the strength of evidence in research on shared decisionmaking addressing diabetes mellitus was low (Table 37b; Appendix G, Evidence Tables 26–29).

Table 37a Summary of the impact of health IT applications on PCC outcomes related to diabetes mellitus in studies addressing shared decisionmaking with patients, their families, and providers; patient-clinician communication; and access to medical information (N=1)

Study, Year | Intervention Compared | Outcomes Measure | Positive Impact
Gomez, 2008 28 | DiabTel telemedicine system vs. usual care | Improving communication with the doctor | +
Gomez, 2008 28 | DiabTel telemedicine system vs. usual care | Help on diabetes education | +

IT: Information Technology

“+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 37b Overall grade of the quality of evidence in diabetes mellitus studies addressing shared decisionmaking with patients, their families, and providers; patient-clinician communication; and access to medical information

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | Moderate
* | Mean Jadad score^†^ | −2
2 | Number of studies | 1
3 | Did the studies have important inconsistency? | Not applicable
4 | Were the studies sparse? | Yes
5 | Overall grade of evidence | Low

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Gomez, 2002^28^ evaluated a telemedicine system (DIABTel) to support diabetes monitoring and intensive management via telemonitoring and telemedicine services. The system, which included a “patient unit” and a “medical workstation” for providers, allowed data collection and viewing as well as exchange of data and sending of messages. It included IT-guided self-care, IT-guided self-management, telemonitoring services, patient portals, and coordination of care tools that affect the clinician, the patient, and the overall health system. The average number of communications per patient was 21.6; mean number of days between communications was 5.4. System messages pertained to blood glucose levels, insulin doses, and exercise and dietary plans. Physicians sent 118 text messages. Providers using the system initiated more therapeutic changes than those who did not have access to it (Table 37a; Appendix G, Evidence Table 29).

#### Outcomes Related to Improved Shared Decisionmaking With Patients, Their Families, and Providers; Patient-Clinician Communication; and Access to Medical Information in Patients With Heart Disease

Five studies addressed cardiovascular disease and its prevention (Table 38a; Appendix G, Evidence Tables 26–28 and 30). These studies addressed hypertension and cardiovascular risk reduction,50 56 83 atrial fibrillation and anticoagulation,33 and congenital heart disease.41 The quality of the studies was high, with some variability in scores due to a lack of blinding and of information about loss to followup. The overall grade of the strength of evidence in studies of shared decisionmaking addressing heart disease was moderate, with relatively modest effects on shared decisionmaking, patient-clinician communication, or access to medical information (Table 38b; Appendix G, Evidence Tables 26–28 and 30).

Table 38a Summary of the impact of health IT applications on PCC outcomes related to heart disease in studies addressing shared decisionmaking with patients, their families, and providers; patient-clinician communication; and access to medical information

Study, Year | Intervention Compared | Outcomes Measure | Positive Impact
Fretheim, 2006^50^ | Educational outreach visit with audit and feedback, and computerized reminders linked to the medical record system vs. passive dissemination of guidelines | Shared decisionmaking | 0
Lowensteyn, 1998^35^ | Coronary risk profile to physician vs. no profile risk to physician | Ratio of high-risk to low-risk patients returning for followup visits | +
Green, 2008^56^ | Blood pressure monitoring and patient Web services vs. usual care | Electronic messaging and subsequent responses | +
Green, 2008^56^ | Blood pressure monitoring and patient Web services vs. usual care | Telephone encounters | +
Green, 2008^56^ | Blood pressure monitoring and patient Web services and pharmacist care vs. usual care | Electronic messaging and subsequent responses | +
Green, 2008^56^ | Blood pressure monitoring and patient Web services and pharmacist care vs. usual care | Telephone encounters | +
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median consultation times | −
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median clinician verbal dominance in 10 minutes preceding decision | −
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors information-seeking | −
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors pause | −
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median patients negative talk | +
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors nodding | +
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors head shake | −
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors smiling | +
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors point at the patient | +
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors touching/pointing at tool | −
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors eye-gaze toward tool | +
Kaner, 2007^33^ | Implicit computer-based decision aid, DARTS II used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median patients eye-gaze toward tool | +
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median consultation times | −
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median clinician verbal dominance in 10 minutes preceding decision | −
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors information-seeking | +
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors pause | −
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median patients negative talk | +
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors nodding | +
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors head shake | −
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors smiling | +
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors point at the patient | −
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors touching/pointing at tool | 0
Kaner, 2007^33^ | Explicit computer-based decision aid, DARTS II, used for clinician-patient treatment decision vs. paper-based guidelines for clinician-patient treatment decision | Median doctors eye-gaze toward tool | +
McCrossan, 2007^41^ | Videoconferencing for children with congenital heart disease vs. teleconferencing | Proportion with concern raised by parents | 0
McCrossan, 2007^41^ | Videoconferencing for children with congenital heart disease vs. teleconferencing | Proportion for whom no action needed after the post-discharge assessment | 0
McCrossan, 2007^41^ | Videoconferencing for children with congenital heart disease vs. teleconferencing | Proportion inform consultant of breathing difficulties | 0
McCrossan, 2007^41^ | Videoconferencing for children with congenital heart disease vs. teleconferencing | Proportion advised NHS action by consultant | +

BMI: Body Mass Index, CV: Cardiovascular, DARTS: Decision Analysis in Routine Treatment, HDL: High-Density Lipoprotein, HRT: Hormone Replacement Therapy, IT: Information Technology, IVD: Interactive Video Disk [system], LDL: Low-Density Lipoprotein, NetLET: Internet Letter, NHS: National Health Service, PSA: Prostate Specific Antigen, RCT: Randomized Controlled Trial

“+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 38b Overall grade of the quality of evidence in heart disease studies addressing shared decisionmaking between patients, their families, and providers; patient-clinician communication; and access to medical information

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.20
2 | Number of studies | 5
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | No
5 | Overall grade of evidence | Moderate

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Lowensteyn (1998)35 investigated the use of computerized coronary risk profiles to reduce cardiovascular risk and improve shared decisionmaking in a study of 253 providers and their 958 patients. The study gave coronary risk profiles to all patients and mailed results to their providers either within 10 working days (intervention group) or during their 3-month followup (control group). Patients were enrolled if their age was between 30 to 74 years, they had no diagnosis of coronary vascular disease, and their provider thought that performing a coronary risk profile for them would be clinically useful. The intervention affected patient-clinician communication in that providers in the intervention had a significantly higher ratio of high-risk to low-risk patients returning for followup visits (1.23 vs. 0.77). Intervention patients also had significantly higher reductions in total cholesterol (average reduction of −0.5 vs. − 0.1 mmol/L), low-density lipoproteins cholesterol (− 0.4 vs. 0.0 mmol/L), and predicted 8-year coronary risk (−1.8 vs. − 0.3%) at followup35(Table 38a; Appendix G, Evidence Table 30).

Kaner (2007)33 conducted a small video-based study comparing paper-based guidelines with two computer-based decision aids (an implicit aid and an explicit aid) during clinical encounters between patients and general physicians. The study randomized 25 elderly patients with atrial fibrillation into three groups to make treatment decisions on warfarin treatment for stroke prevention, and their clinical encounters were videotaped. The authors analyzed the videos to study the impact of decision support tools on shared decisionmaking. Paper-based guidelines took 21 minutes (range: 19–26 minutes) to work through versus 31 minutes (range: 16–41 minutes) for the implicit decision aid and 44 minutes (range: 39–55 minutes) for the explicit decision aid. In the 10 minutes immediately preceding the decision point, general practitioners dominated the conversation, accounting for 64 percent (58–66%) of all utterances, and this trend was similar across all three arms of the trial. Information-giving was the most frequent activity for both general physicians and patients, and the rate at which physicians gave information was twice that of the patients. These rates were higher in consultations involving computerized decision aids. The physicians’ language was highly technically focused, and only 7 percent of their conversations were socio-emotional in content; the patients’ language had twice the socio-emotional content (15%). However, frequent head nodding and a close mirroring in the direction of eye-gaze suggested that both parties were active participants in the conversation. Irrespective of the arm of the trial, both the patients’ and physicians’ behavior showed that they were reciprocally engaged in these consultations. However, even in consultations aimed at promoting shared decisionmaking, the physicians were verbally dominant, and they worked primarily as information providers for patients (Table 38a; Appendix G, Evidence Table 30).

McCrossan (2007)41 conducted a study testing the impact of videoconferencing (n= 25) versus telephone followup (n=22) or usual followup care (n=19) on improving the transition from hospital to home during the first 24 hours post-discharge for children with complex congenital heart disease. The videoconferencing allowed for education and ongoing contact with hospital staff and for providers to be able to visually assess the child. Study participants needed to have a child less than 3 years of age who was carrying a new diagnosis of congenital heart disease. Videoconferences required more time than telephone contacts (mean difference = 5.4 minutes, standard deviation = 0.62) but resulted in more adequate assessments of patients. The assessment rating was at least adequate in 94 percent of the videoconferencing assessments, as compared with 64 percent of the telephonic ones. The parental frequency of raising concerns was similar in both groups. After the telephone consultations, providers recommended contact with health service professionals in 22 percent of occasions, as compared with 4 percent after videoconference consultations. The results did not seem to reflect improved shared decisionmaking, although results did show improved access to medical information on the part of the families (Table 38a; Appendix G, Evidence Table 30).

Fretheim (2006)50 compared a passive dissemination of guidelines with a tailored intervention including a pharmacist outreach visit to patients and computerized reminders to providers. The tailored intervention resulted in higher rates of prescribing antihypertensive medication types that were adherent to guidelines, but had no statistically significant impact on shared decisionmaking (Table 38a; Appendix G, Evidence Table 30).

Green, (2008)56 compared usual care with two interventions, a home blood pressure monitoring intervention with a secure patient Web site, and a home blood pressure monitoring, a secure patient Web site, and pharmacist care. The patient Web site and pharmacist-care arm had significantly better blood pressure control, higher frequency of communications between patient and pharmacist, and a higher percentage of those communications initiated by patients than in the other two study arms. Telephone interactions initiated by patients were also higher in this arm (Table 38a; Appendix G, Evidence Table 30).

#### Outcomes Related to Improved Shared Decisionmaking With Patients, Their Families, and Providers; Patient-Clinician Communication; and Access to Medical Information in Patients With Cancer

Three studies (one each) addressed breast, prostate, and colon cancer (Table 39a; Appendix G, Evidence Tables 26–28 and 31). The quality of these three studies was high, with variability between the studies in terms of blinding and information regarding loss to followup. The overall grade of the strength of evidence in studies of shared decisionmaking addressing cancer was low, with a tendency toward improved patient-clinician communication but variable effects on shared decisionmaking (Table 39b; Appendix G, Evidence Tables 26–28 and 31)

Table 39a Summary of the impact of health IT applications on PCC outcomes related to cancer in studies addressing shared decisionmaking with patients, their families, and providers; patient-clinician communication; and access to medical information

Study, Year | Intervention Compared | Outcomes Measure | Positive Impact
Chan, 2008 349 | Emailed the NetLet vs. information sent through regular mail | Fecal occult blood tests returned | 0
Chan, 2008 349 | Emailed the NetLet vs. information sent through regular mail | Percentage of patients who made appointments todiscuss colon cancer screening with their doctor | +
Frosch, 2008^282^ | Traditional didactic decision aid providing information about prostate specific antigen (PSA) screening options and outcomes vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | Total knowledge score / imputed data | +
Frosch, 2008^282^ | | Total knowledge score / complete cases only | +
Frosch, 2008^282^ | | Reduced interest in PSA screening indicating increased interest in watchful waiting | +
Frosch, 2008^282^ | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | Total knowledge score / imputed data | +
Frosch, 2008^282^ | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | Total knowledge score / complete cases only | +
Frosch, 2008^282^ | Chronic disease trajectory model for prostate cancer followed by a time–trade-off exercise vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | Reduced interest in PSA screening indicating increased interest in watchful waiting | +
Frosch, 2008^282^ | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | Total knowledge score / imputed data | +
Frosch, 2008^282^ | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | Total knowledge score / complete cases only | +
Frosch, 2008^282^ | Both the didactic decision aid and the chronic disease trajectory model vs. links to public prostate cancer–specific Web sites from credible sources (control condition) | Reduced interest in PSA screening indicating increased interest in watchful waiting | +
Maslin, 1998^215^ | Intervention (interactive video disk system) plus usual care from multidisciplinary team vs. usual care from multidisciplinary team | Mental health score on Short Form-36 questionnaire | 0
Maslin, 1998^215^ | Intervention (interactive video disk system) plus usual care from multidisciplinary team vs. usual care from multidisciplinary team | Anxiety score on the hospital anxiety and depression scale | +
Maslin, 1998^215^ | Intervention (interactive video disk system) plus usual care from multidisciplinary team vs. usual care from multidisciplinary team | Viewing interactive video disk had impact on surgical choice | 0
Maslin, 1998^215^ | Intervention (interactive video disk system) plus usual care from multidisciplinary team vs. usual care from multidisciplinary team | Viewing interactive video disk had impact on adjuvant therapy choice | 0

E-mail: Electronic Mail, IT: Information Technology, NetLET: Internet Letter, PSA: Prostate Specific Antigen

“+” indicates that the intervention had a positive effect on the outcome in comparison with the control

“−” indicates that the intervention had a negative effect on the outcome in comparison with the control

“0” indicates that the intervention had no effect on the outcome in comparison with the control

Table 39b Overall grade of the quality of evidence in cancer studies addressing shared decisionmaking with patients, their families, and providers; patient-clinician communication; and access to medical information

1 | Protection against risk of bias (relates to study design, study quality, and reporting bias^*^ | High
* | Mean Jadad score^†^ | 0.67
2 | Number of studies | 3
3 | Did the studies have important inconsistency? | Yes
4 | Were the studies sparse? | Yes
5 | Overall grade of evidence | Low

* The Jadad scoring method, and rules for converting the numerical score to a rating for protection against risk of bias are described in the Quality Assessment subsection of Chapter 2, Methods.

† The rules for assessing the quantity and consistency of a body of evidence, and combining that with the mean Jadad score to produce the overall grade are described in the Grading of the Evidence subsection of Chapter 2.

Maslin (1998)215 compared the impact of using an interactive video disk system before a provider visit, versus standard informational materials to support decisionmaking for women with early breast cancer. The study measured patients’ anxiety and satisfaction with their care by using the Hospital Anxiety and Depression Scale and a patient-satisfaction survey. Patients gave the video disk system a high rating, and 92 percent said they would recommend it to “someone they knew with a diagnosis of breast cancer.” When asked whether the interactive video disk system had actually helped them make a decision, over half stated that it had not, while 30 percent reported that “it had definitely influenced their treatment decision.” The majority of patients in both arms of the study, however, reported that the doctor shared decisions with them (16%) or with them and a clinical specialist (44%). Overall, patients’ satisfaction with their decision was high, and no difference was detected between study groups. Both arms of this study reported that the clinical specialist played a strong role in decisionmaking (Table 39b; Appendix G, Evidence Table 31).

A study on prostate cancer by Frosch (2008)282 tested multiple approaches to support men’s decisions on having a prostate-specific antigen screening test. This study, which included 611 men over 50 years old, randomized its participants into four groups: a control group that was provided with links to general Web sites providing information on prostate cancer screening, a second group that had access to a didactic decision support aid on prostate cancer screening and its outcome, a third group that had access to a chronic disease trajectory model followed by a trade-off exercise, and a final group that had access to a combination of the didactic decision support aid, chronic disease trajectory model, and tradeoff exercise. The study found that patients in the control group were least likely to view information and had the lowest knowledge scores. Those in the second and third groups were most likely to view information, and those in the final combined-intervention group had the highest knowledge scores, followed by those in the second group who viewed the didactic decision aid. In general, patients in all four groups had high preferences for prostate-specific antigen testing at baseline (96.2%), which was reduced at the end of the study in favor of “watchful waiting” (66.2%), suggesting a positive impact of information exposure in all study groups. Study investigators commented that participants in the combined-intervention group were perhaps exposed to too much information, as only 21 percent of them reviewed both intervention materials (Table 39b; Appendix G, Evidence Table 31).

In a pilot study, Chan (2008)349 compared a generic reminder letter from the provider about colon cancer screening with an intervention involving a personalized email reminder from the provider with access to an intervention Web page that contained a video on fecal occult blood testing, a video-decision aid about colon cancer screening, and multiple links to other informational screening Web sites. The intervention resulted in an increased percentage of patients who discussed colon cancer screening with their doctor from 60 percent in control group to 83 percent in the intervention group. A quarter of patients in both the control and intervention groups returned the fecal occult blood test kits (Table 39b; Appendix G, Evidence Table 31).

#### Outcomes Related to Improved Shared Decisionmaking With Patients, Their Families, and Providers; Patient-Clinician Communication; and Access to Medical Information in Patients With Other Diseases and Conditions

##### Hormone Replacement Therapy

Three RCTs192 339 347 compared the impact of a Web-based decision support tool about hormone replacement therapy with a printed brochure and usual care. The first trial (409 participants visiting women’s health care and family medicine clinics in academic centers, inner city community health centers, and suburban women’s health clinics in two cities) compared 3 months of access to the support tool with a print brochure. The second trial (54 participants visiting a women’s health clinic at an academic center that serves predominantly white, well-educated, middle- to upper-income women) compared the Web-based decision support tool with usual care. Participants were all females with ages of 45 to 75 years. The first trial recruited women based on their attendance at a women’s health or family medicine clinic. The second trial screened women before recruitment and recruited only those who were “actively trying to make decisions addressed by the support.” The study measured decisional satisfaction, decisional conflict, and knowledge, and compared results of both trials. Patient knowledge levels were improved in one study.339 This study did not report any significant impact from the patient decisionmaking applications, except in the case of higher-educated patients who were actively “trying to make a decision.” intervention participants had a greater increase in knowledge in both trials and greater increases in decisional satisfaction in the second trial339 (Appendix G, Evidence Tables 26–28).

The Schapira (2007) study296 also evaluated the impact of a computer-based decision aid to support women making decisions on hormone replacement therapy in an RCT of 177 postmenopausal women. The study participants were patients receiving care at a Veterans Affairs Medical Center. The study randomized the patients to either using this decision aid or receiving a printed brochure. Inclusion criteria limited the patients to English-speaking women with no cognitive dysfunction who were amenorrheic for 12 months or had a documented follicle stimulating hormone level greater than 25 IU/L. The trial reported no significant difference between study groups in knowledge acquisition, decisional conflict or satisfaction, or use of hormone replacement therapy (Appendix G, Evidence Tables 28).

Barnabei (2008)107 studied the impact of a Web-based hormone replacement therapy support tool that created printouts of customized patient data and questions for patients to ask their providers. This study was an RCT of 288 women and 26 health care providers. The study assessed the impact of the tool on patient-provider communication and patient satisfaction with the discussion on hormone therapy. Patients using this tool were more engaged, asked more relevant questions, and were more likely to prepare for their visits with their provider. They thought that their providers responded well to their questions. Providers were more satisfied with the discussions they had with the patients in the intervention group and thought that those visits were more efficient (Appendix G, Evidence Tables 28).

##### Women’s Health

A large clinical trial evaluated a decisionmaking support tool to help pregnant women decide on undergoing further genetic testing (e.g., amniocentesis)90. The trial involved 496 pregnant women at less than or equal to 20 weeks of gestation. The study assigned participants to receive an interactive prenatal testing decision tool or the California Department of Health Services’ educational booklet. The study excluded women who did not speak English, were beyond 20 weeks of gestation, had already undergone genetic testing, were carrying more than one fetus, had become pregnant using in vitro fertilization, or were candidates for prenatal diagnosis because of family history. The primary outcomes were knowledge, risk awareness, intervention satisfaction, and decisional conflict. Women using this decisionmaking tool acquired more knowledge and were able to more accurately estimate their risk of having a baby with Down syndrome and miscarriage risk related to testing procedures. As compared to the control group, the women using the decision tool had less decisional conflict and were more likely to make decisions other than those they were originally inclined to make before using the tool (Appendix G, Evidence Tables 28).

An RCT, involving 742 pregnant women in Scotland who had had one previous lower segment Caesarean section,246 evaluated two approaches for computer-based decision support to help with decisionmaking on Caesarean section against usual care. The study randomized participants to one of three arms: usual care, use of a computer-based information program about clinical outcomes of vaginal birth and elective and emergency Caesarean section, and use of a computer-based decision analysis tool that provided delivery mode recommendations based on utility assessments provided by the pregnant woman and risk analysis based on a “concealed decision tree.” The study excluded non-English speakers and women whose most recent delivery was not a Caesarean section. The study outcome measures included the impact on decisional-conflict scale and mode of delivery. Women using both approaches had less decisional conflict than women in the usual care group. Vaginal birth rates, however, were similar among the usual care group and the group using the information-based computer program but significantly higher among women using the decision aid (Appendix G, Evidence Tables 28).

### How Does the Impact on Shared Decisionmaking Between Patients, Their Families, and Providers, Patient-Clinician Communication, and Access to Medical Information in Patients Vary by Type of Health IT Application?

Table 40 summarizes how the impact on shared decisionmaking, communication with patients, and access to medical information varied according to the type of health IT application (based on the five major health IT types as described in Chapter 2). The analysis demonstrated that relatively few studies have examined these outcomes for any of the types of health IT applications. The studies cited shared decisionmaking applications most frequently as having at least one positive effect on shared decisionmaking or communication, and in most cases those studies reported having a statistically significant effect. Although only four studies used care management tools to assess the impact on shared decisionmaking and communication, all four of those studies reported at least one positive outcome, which was statistically significant in three of them.

Table 40 The impact on shared decisionmaking between patients, their families, and providers; patient-clinician communication; and access to medical information by type of health IT application

Health IT Type | Number of Studies | Studies With at Least 1 Outcome With a Positive Impact, n (%) | Studies With at Least 1 Outcome With a Statistically Significant Positive Impact, n (%)
Care management tools | 4 | 4 (100) | 3 (75)
Telehealth | 3 | 3 (100) | 0 (0)
PHR/patient portals | 1 | 0 (0) | 0 (0)
Secure electronic messaging | 4 | 3 (75) | 2 (50)
Shared decisionmaking | 7 | 6(86) | 4 (57)

IT: Information Technology, PHR: Personal Health Record

## Key Question 2 What are barriers and facilitators that clinicians, developers, patients and their families or caregivers encounter that may impact implementation and use of health IT applications that address patient-centered care, and how do these barriers and facilitators vary by type of health IT application?

We identified 206 articles that examined barriers and facilitators to the use of health IT applications that address components of patient-centered care. Studies focused on a wide variety of clinical conditions, including diabetes mellitus, cardiovascular disease, heart failure, chronic obstructive pulmonary disorder, cancer, asthma, mental health, sickle cell disease, and chronic pain. The articles included usability and feasibility studies, RCTs, quasi-experimental studies, pilot studies, case studies, surveys, cost-benefit analyses, and qualitative research. Health IT barriers and facilitators can apply to the health care system, clinicians, or patients (Appendix G, Evidence Tables 32 and 33) (Figure 1).

### Barriers

#### Usability

Forty-nine studies addressed the usability of computer applications as a major barrier to the effective use of the applications by medical providers and patients (Appendix G, Evidence Table 32 and 33). We listed four of those studies that we deemed particularly significant.

A study conducted by Saleem (2005)354 addressed the usability of computerized clinical reminders. For two days, three observers recorded how clinicians interacted with the computerized clinical reminders. The study subjects were 35 nurses and 55 physicians and mid-level practitioners at four Veterans Administration medical centers. The authors coded field notes and sorted them into categories, and then integrated the findings into meaningful patterns and themes. Nine themes translated directly to barriers to effective use of the computerized reminders. Several comments were directly related to the poor interface usability of the reminders. Authors reported inflexibility of the dialogue options within the dialogue box of the specific reminders. Because of this problem, nurses and providers had difficulty satisfying certain computerized reminders. They needed more options; without more options they often used workarounds. Another barrier they encountered was that the summary cover sheet (a list of patient’s problems, allergies, and appointments) would often not load quickly. This delay resulted in the use of strategies that lessened the effectiveness of the reminders. For instance, some nurses and providers clicked on the progress notes tab before the reminders were displayed, or reported setting a default tab to bypass the cover sheet.

A study conducted by Ash (2003)355 evaluated the perceptions of medical professionals involved in computerized provider order entry. The study collected data at three teaching and nonteaching hospitals in the United States using observation, focus groups, and interviews with clinical, administrative, and information technology staff. The study employed an inductive approach to code field notes and transcripts to identify patterns and themes in the data. Technical and implementation issues included usability, time, training, and support. In particular, participants reported that there were often too many screens that needed to be accessed to place an order. Authors also reported frequent use of workarounds by clinicians as a way to make the system more effective for users.

Tierney (2003)37 assessed the barriers to using computer-based cardiac-care suggestions by primary care physicians and pharmacists. The study provided evidence-based cardiac care suggestions approved by local cardiologists and internists to physicians and pharmacists as they cared for a total of 706 outpatients with heart failure and/or ischemic heart disease. The intervention had no effect on physician adherence to these care suggestions (23% for intervention patients vs. 22% for controls). One barrier the researchers identified was physicians were reluctant to integrate these computer-based suggestions with their practice. Although physicians viewed guidelines as providing helpful information, they resisted using the guidelines because they said the guidelines constrained their practice and did not see the guidelines as helpful in making decisions for individual patients.

Kaufman (2006)356 conducted an RCT involving Medicare beneficiaries living in medically underserved areas in New York state. The study evaluated the usability of a telemedicine diabetes education and monitoring device. The PCC components evaluated in this study included quality and safety. The investigators observed numerous barriers to patients’ use of the Web components, including: perceptual-motor skills, especially in relation to the use of the mouse; mental models that referred to a basic understanding of system navigation; and health literacy, including basic literacy.

#### Access

Forty-seven studies identified barriers or facilitators related to access to the Internet, computers, or devices that could affect the use of health IT by patients and providers (Appendix G, Evidence Table 32 and 33). Two of those studies that we deemed particularly significant are listed here.

Lober (2006)357 evaluated barriers to the use of a PHR by 38 low-income elderly and disabled patients residing in a publicly subsidized housing project. Twenty-seven of the participants did not own computers and reported access as a barrier to using the system. Their access to computers was limited to the open hours of the computer room in the building. The entire group reported difficulties gaining access to assistance with data entry because of problems with nurse schedules and/or the availability of the social worker. The study also revealed cognitive barriers to access to the computers in one-third of the participants. Among the barriers were problems with memory and cognitive impairments as a result of Alzheimer’s dementia, or other conditions. These conditions affected the residents’ ability to enter or maintain their PHR and to access the Web site because of an inability to remember their password, user name, or the site’s uniform resource locator.

In a study of an integrated pediatric health care delivery system, Kleiner (2002)358 explored issues that parents, general pediatricians, and subspecialty pediatricians had using email for physician-patient communication. Some of the information parents wanted to communicate using email included scheduling appointments, getting information or test results, and discussing a particular symptom. A total of 325 parents, pediatricians, and medical staff were interviewed using a standardized survey tool for parents and a separate instrument for physicians. One barrier that was identified was almost half of the parents did not have access to email. Factors that improved the likelihood of access to email included a higher family income, parental education and age (parents aged 31 to 40 years were more likely to have access to email than were those in the other age groups). The study also showed that although parents were generally positive about the idea, physicians were opposed to the practice of using email for physician-patient communication.

#### Training

Forty-five studies addressed a need for clinic staff to obtain additional training in order to use a new health IT application (Appendix G, Evidence Table 32 and 33). One of those studies that we deemed particularly significant, Patterson (2005),359 identified the lack of clinicians’ computer training as one of the barriers to the effective and consistent use of computerized reminders in the Veteran’s Health Administration. The authors conducted two studies. In the first study, they used ethnographic observations and semi-structured interviews of HIV-related computerized reminders to identify barriers to effective use. The two barriers to effective use that they identified were limited knowledge of how to use the computerized reminder software and an insufficient basic formal training class on the computerized patient record system. The second study assessed more general barriers and facilitators. The authors collected open-ended and closed-ended data through a survey of 261 participants at a national informatics meeting. Seven percent of the respondents indicated that insufficient training made using computerized reminders more difficult. In particular, the respondents felt that more training was needed in the following areas: computerized reminder use in general, removing inapplicable reminders, general computer skills, creating computerized reminders, generating reports, and viewing active reminders.

#### Cost

Thirty-two studies mentioned the cost of health IT implementation (Appendix G, Evidence Table 32 and 33). The evidence clearly indicated that the higher cost associated with implementation of electronic health records was a significant barrier.

#### Computer Literacy

Thirty-one studies explored deficits in patients’ and clinicians’ computer literacy and skills as barriers to the use of a health IT application (Appendix G, Evidence Table 32 and 33). We listed two of those studies we deemed particularly significant.

Trivedi (2009)360 examined the feasibility and effectiveness of a clinical decision support system for depression in routine public mental health care implemented in Texas. Fifteen study clinicians (13 physicians and two advanced nurse practitioners) from five sites participated in the study, accruing over 300 outpatient visits with 168 patients. They identified computer literacy and hardware/software requirements as barriers to the use of a clinical decision support system for depression. Specifically, for many clinicians, technical errors encountered during the introduction and early use of the software program frequently precipitated a loss of confidence in the program. Some clinicians were not willing to tolerate technical errors during the patient visit. Finally, almost all physicians thought the clinical decision support system was too complex.

Another study conducted by Chu (2009)353 evaluated the computer literacy and psychosocial influence of computer anxiety, computer confidence, and computer self-efficacy on older adults at six meal congregate sites. The study randomized 137 participants, aged 65 and older, in a controlled, two-group, pre-post, repeated measures design. Participants in the intervention group received a two-hour training session once a week for five weeks. Of the 112 participants eligible for analysis, 70 percent had never used a computer before. Among the reasons given for not using a computer or Internet, participants mentioned they did not have the opportunity to learn or did not have access to a computer or Internet. Surprisingly, almost 92 percent of the participants were not aware of the availability of computers and Internet access to the public at community centers and public libraries. The intervention group demonstrated a reduction in computer anxiety and increases in computer confidence and computer self-efficacy in retrieving and evaluating online health information.

#### Increases in Workload or Changes in Workflow

Thirty-eight studies identified workload-related issues as barriers (Appendix G, Evidence Table 32 and 33). One of the studies that we found particularly illustrative was Varonen (2008)361 which identified potential barriers implementing clinical decision support systems in health care, as perceived by clinicians. The authors conducted a qualitative focus group study with 39 physicians representing primary and secondary health care settings in six areas of Finland. Respondents identified a potential increase in workload due to excessive computerized reminders as one of the barriers to implementing these support systems.

#### Implementation

Twenty-eight articles discussed issues with implementation of health IT applications (Appendix G, Evidence Table 32 and 33). One example that we deemed significant, Samoutis (2007),362 introduced an electronic medical record system in two public primary care centers in Cyprus that did not previously have computers. One urban and one rural primary care center and their personnel (physicians and nurses) participated in the project. The study used both qualitative and quantitative evaluation tools during the implementation phase. A total of 10 health professionals served as electronic medical record system evaluators. Physicians, nurses and patients stated that they saw clear benefits to having electronic medical records. However, physicians said they believed the system was difficult to use and that it negatively affected their workflow and raised legal concerns. They cited system breakdowns, software design problems, transition difficulties, and lack of familiarity with electronic equipment as some of the main implementation issues.

#### Confidentiality

Twenty-two articles discussed confidentiality issues resulting from use of health IT, three of these we highlighted below (Appendix G, Evidence Table 32 and 33).

The study by Garcia-Sanchez (2008)363 assessed the prevalence of worries among patients about confidentiality breaches of computer records. Sixty-two patients filled out a questionnaire. Forty-eight percent of them experienced confidentiality worries during past consultations. The subjects who worried most about confidentiality were those who were less familiar with computers and less aware about their general practitioner’s actions at the computer.

In the study by Likourezos (2004),364 researchers surveyed 44 emergency medicine clinicians (23 physicians and 21 nurses) regarding their satisfaction with an electronic medical record system recently introduced in the emergency department at a large urban teaching hospital. The questionnaire assessed computer background and experience, perceptions regarding electronic medical record use, and concerns about impact upon quality of patient care. The clinicians found the electronic medical record easy to use and were generally satisfied with the impact on their work. However, they were concerned about issues related to the confidentiality of patient information.

Kleiner, 2002^358^ explored attitudes of parents and clinicians regarding the potential issues involved in using email for physician–patient communication. The authors interviewed a total of 325 parents, general pediatricians, and subspecialty pediatricians, from an integrated pediatric-health-care-delivery system, using a standardized survey tool for parents and a separate instrument for physicians. More than half of parents and general pediatricians had access to email and all subspecialty pediatricians had access to email. All three groups (parents, general pediatricians, and subspecialty pediatricians) expressed concerns about confidentiality and time demands in using email communication for patient-physician communication.

#### Other Barriers

Depersonalization was mentioned in 10 studies as a potential barrier. Another five studies cited incompatibility with current health care practices as a barrier. Five articles cited problems with reimbursement as barriers. Three studies identified problems with patient retention and liability as barriers.

### Facilitators

#### Satisfaction

Forty-seven studies evaluated satisfaction with a health IT application (Appendix G, Evidence Table 32 and 33). The studies generally did not provide a sufficient level of granularity to distinguish among different dimensions of satisfaction. A number of these studies are highlighted below.

Bobrie (2007)365 evaluated the satisfaction with and feasibility of home blood pressure measurements using telemedicine in a multicenter, prospective, single-group, open-label pilot study of 111 patients with uncontrolled hypertension despite monotherapy. Authors reported that 80 percent of the patients were satisfied or very satisfied with the program, and 52 percent of the physicians were satisfied and 22 percent very satisfied with the program.

Shore (2008)366 compared the satisfaction of 53 rural American Indian Vietnam War veterans with telepsychiatry. The study gave The Structured Clinical Interview for DSM-IIIR to participants both in person and by videoconference. The study used a process measure to assess participants’ satisfaction with the interview and the interview process, responses to the interview type concerning the usability of the technology, the perceptions of the interviewee/interviewer interaction, and the cultural competence of the interview. The study also asked interviewers several of the same questions as the participants; answers were compared to the corresponding participant responses. Overall, interviewees were highly satisfied with both the in-person interview and the telehealth interview. Ninety-four percent (50) of the subjects had a general positive response to the videoconferencing. Interestingly, the interviewers’ ratings of perceived interviewee satisfaction were universally lower than the interviewee ratings: Interviewers underestimated how comfortable the interviewee was during the interview, the interviewee’s overall amount of satisfaction with the interview, and how much the interviewee understood the physician’s questions and trusted the physician. The authors concluded that telepsychiatry was well-received and comparable in terms of patient comfort, satisfaction, and cultural acceptance to in-person interviews.

#### Ease of Use

Forty-eight studies addressed ease of use as a potential facilitator of the implementation of health IT (Appendix G, Evidence Table 32 and 33). In one of those studies, a 12-month trial in two outpatient mental health clinics in Los Angeles, Chinman (2007)367 assessed the feasibility of using audio computer-assisted self-interviewing to ask clinical questions of patients with severe mental illness waiting for appointments. Audio computer-assisted self-interviewing is a visual and aural, Internet-based, touch screen system that asks questions about symptoms, drug use, medication adherence, and side effects. The patient gives a one-page printed summary of the results to the psychiatrist during the appointment. Authors collected data from 266 patients with severe mental illness and 14 psychiatrists using surveys and provider focus groups The results indicated that patients felt that the system was enjoyable, easy to learn and use, and improved communication with their psychiatrists. Providers evaluated the system as easy to use, having a small impact on care, and requiring outside support to continue its use.

#### Usefulness

Twenty-six studies evaluated the usefulness of health IT (Appendix G, Evidence Table 32 and 33). Two that we thought were especially significant we listed below.

Dombkowski (2007)368 integrated information from Medicaid administrative claims data into the Michigan Care Improvement Registry to remind providers about influenza vaccination for children with high-risk conditions such as asthma. The authors conducted a survey to assess the attitudes of pediatric primary care providers regarding the implementation of the system. Of the 389 respondents, 48 percent believed that the implementation of a high-risk indicator in the Registry for identifying children with asthma who should receive the influenza vaccine would be “very helpful,” and 27 percent believed it would be “helpful.”

Eminovic (2004)369 explored issues of safety, feasibility, and patient perceptions concerning the Clinical Enquiry Service, which uses a Web chat for the public to contact a nurse for any kind of health problem in the U.K. In a 6-day pilot program, the study used the service during an office visit in an inner-city general practice involving non-urgent patients. First, patients completed out three Web forms. They then used a simple Web chat application to communicate with trained National Health Service direct-triage nurses, who responded with appropriate triage advice. The general practitioner saw all patients immediately after using the Web chat service. Twenty-five patient volunteers considered the intervention to be a useful addition to regular care, but not a replacement for it.

#### Efficiency

Thirty-three articles evaluated the efficiency of health IT applications (Appendix G, Evidence Table 32 and 33). The studies used different approaches to assessing efficiency. We highlighted two of these studies below that we deemed significant.

Christensen (2008)370 studied the use of electronic patient record systems by Norwegian general practitioners. Authors examined the use of different electronic patient record functions and the time spent on using the records, as well as the potential effects of such systems on the clinician-patient relationship. They conducted a combined qualitative and quantitative study that used data collected from focus groups, observations of primary care encounters, and responses to a questionnaire survey of a random sample of 247 general practitioners to describe their use of this IT application in primary care. The focus group results indicated that a majority of the clinicians believed that these systems, compared to paper systems, saved both time and work. However, they did say that these systems resulted in the transfer of some administrative work from secretaries to the physicians.

Wang (2004)371 evaluated Web-based PHR used by patients to collect and manage their health information, request self-referrals, and store a record of their consultations. Two patient care coordinators managed the referrals for five specialists. Results showed that 94 percent of the 32 patients who completed a survey were satisfied with the online referral process. In addition, the specialists were satisfied with the informational content of patients’ PHR and were able to effectively prioritize all requested referrals based on information in the PHR that the patient provided.

#### Other Facilitators

Eleven studies identified comfort in use of health IT as a facilitator – defined as being comfortable with using technology, which is distinct from how easy the technology is to use. For example, a patient may find a technology easy to use but may not be comfortable placing it at home. Thirteen studies addressed issues related to support for the use of health IT applications. Nine studies explored site location as a facilitator of health IT implementation and use. The issues of operability and resources were discussed in eight articles. Six articles discussed the need for standardization of health IT applications.

### Variation by Health IT Type

None of the included studies were specifically designed to assess how barriers and facilitators differed by type of health IT. When reviewing the published literature on care coordination tools, increases in workload or changes in workflow (24 of 127 studies) was noted as the most common barrier to use, while the most common facilitator was ease of use (26 of 127 studies) (Tables 41 and 42, Appendix G, Evidence Tables 32 and 33).

Table 41 Variation in reported barriers by health IT type

| Care Management Tools (127 Studies) | Telehealth (59 Studies) | PHR/Patient Portals (41 Studies) | Secure Electronic Mesaging (22 Studies) | Shared Decisionmaking (5 Studies) | Total
Access | 16 | 12 | 13 | 6 | 0 | 47
Training | 22 | 12 | 4 | 7 | 0 | 45
Cost | 17 | 9 | 4 | 2 | 0 | 32
Computer Literacy | 16 | 6 | 7 | 2 | 0 | 31
Workflow | 24 | 7 | 2 | 3 | 2 | 38
Implementation | 14 | 9 | 3 | 2 | 0 | 28
Confidentiality | 7 | 4 | 4 | 7 | 0 | 22
Usability | 25 | 12 | 11 | 1 | 0 | 49

IT: Information Technology, PHR: Personal Health Record

Table 42 Variation in reported facilitators by health IT type

| Care Management Tools (127 Studies) | Telehealth (59 Studies) | PHR/Patient Portals (41 Studies) | Secure Electronic Messaging (22 Studies) | Shared Decisionmaking (5 Studies) | Total
Satisfaction | 21 | 12 | 9 | 2 | 3 | 47
Ease of use | 26 | 7 | 9 | 4 | 2 | 48
Usefulness | 16 | 8 | 1 | 1 | 0 | 26
Efficiency | 18 | 3 | 6 | 4 | 2 | 33

IT: Information Technology

Among studies in telehealth, the most frequently reported barriers were access, training, and usability (12 of 59 studies each), while satisfaction was the most frequently reported facilitator (in 12 of 59 studies). In studies examining PHR use and patient portals, more than 30% of studies (31 of 41 studies) reported access as a barrier to use, while satisfaction and ease of use were seen as facilitators in another 20% of studies (9 of 41 studies). Studies of secure electronic communication cited training and confidentiality as substantial barriers to use (in 7 of 22 studies), while ease of use and efficiency wre the most common facilitators of use (in 4 studies). Two studies of shared decisionmaking reported increases in workload or changes in workflow as a barrier to use, while satisfaction, ease of use and efficiency were seen as facilitators of shared decisionmaking interventions in two studies.

## Key Question 3 What knowledge or evidence deficits exist regarding needed information to support estimates of cost, benefit, impact, sustainability, and net value with regard to enabling PCC through health IT?

For Key Questions 1 and 2, our team identified deficits in the literature included in this review regarding estimates of cost, benefit, impact, sustainability, and net value of health IT application that enable PCC. Deficits fall into several general categories: types of conditions that are currently understudied; patient subgroups that are underrepresented; and characteristics of health IT that address components of PCC that are underspecified (see Table 43).

Table 43 Knowledge or evidence deficits regarding health IT applications

Key Question | Conditions Which Have Not Been Sufficiently Addressed in the Literature Regarding PCC Through HIT | Subpopulations Which Have Not Been Sufficiently Addressed in the Literature | Outcomes Relating to Health IT and Definitions of Those Outcomes
1a—health care processes | Conditions other than diabetes, hypertension and heart disease; substance abuse, infectious diseases, surgical conditions, and critical illnesses | Studies among women, children, the elderly, and patients with cancer | Effects of health IT on cost and provider efficiency
1b—clinical outcomes | Conditions other than diabetes, hypertension, and heart disease; e.g., substance abuse including tobacco use, chronic pain, and cancer | Studies on women, children, the elderly
1c—intermediate outcomes | | | Categorical, mutually exclusive, standardized definitions of intermediate outcomes; studies addressing “intermediate outcomes” as primary outcomes
1d—needs, values, preferences | Studies of conditions other than diabetes, heart disease, and cancer, including chronic pain and smoking cessation | Studies in vulnerable populations such as the elderly, racial and ethnic minorities, and pregnant women
1e—shared decisionmaking | | Studies among children | Impact of patient factors such as age, education, and socioeconomic status and how those can be best addressed to maximize effects of health IT applications designed to enable PCC. Time requirements for using decision support tools, especially those targeting providers
2—barriers or facilitator | | | Initiation, capital, and revenue concerns in implementation of health IT to enable PCC

IT: Information Technology

As can be seen in the results section for Key Question 1, the majority of the existing research focuses on “process outcomes,” clinical outcomes,” and “intermediate outcomes,” with a clear paucity of research regarding “improved responsiveness to the needs and preferences of individual patients” and “improved shared decisionmaking between patients, their families, and providers; patient-clinician communication; and access to medical information.” This is likely due to the fact that the success of health care is more traditionally gauged by clinical, intermediate, and process outcomes. In fact, most of the studies we reviewed were primarily interested in clinical outcomes, and even intermediate and process outcomes sometimes seemed to be an afterthought.

To better understand the impact of health IT on PCC, we clearly need to conduct more focused research on improving responsiveness to the needs and preferences of individual patients; shared decisionmaking between patients, their families, and providers; patient-clinician communication; and access to medical information. This is especially important since these outcome measures are more directly associated with PCC than clinical, intermediate, and process outcomes.

Another research gap is that few studies focused on the role of health IT in improving PCC among the pediatric and elderly populations. We need to better understand how patients with cognitive or physical impairments interact with health IT. More research is also needed to understand the impact that racial and ethnic backgrounds, education, and socioeconomic levels have on the effectiveness of health IT on improving PCC. Because no studies sought to answer this question, the impact of health IT on health care across populations remains unclear.

With more care being delivered in the home and community-based setting, more research needs to be done to elucidate the impact of community, environment, and culture on the health care utilization and health outcomes associated with health IT. In addition, the needs, concerns and impact of health IT on formal and informal caregivers should be explored.

It also is important to study how to make decision support tools more efficient for providers. Significant effort is needed to improve the accuracy and dependability of high impact health IT tools that address components of PCC.

Other important areas of study are: developing integrative measures for gauging compliance of health IT applications with PCC principles, integrating PCC components into electronic health record systems used in routine clinical practice, how different types of outcomes interact when health IT supports PCC, and how to use principles of PCC in a systematic way. Finally, few studies addressed cost or sustainability. These evidence deficits will need to be addressed or they will limit the future success of the use of health IT to enable patient-centered care.

## Key Question 4 What critical information regarding the impact of health IT applications implemented to enable PCC is needed to give consumers, their families, clinicians, and developers a clear understanding of the value proposition particular to them?

Our team also used the literature reviewed in this report to identify the information needs of various stakeholders regarding health IT and PCC, and summarized these needs in Table 44. In previous sections we discussed deficits regarding needed information to support estimates of cost, benefit, impact, sustainability, and net value with regard to enabling PCC using health IT.

Table 44 Information needs of various stakeholders regarding health IT applications

Stakeholders | Information That is Needed Regarding Health IT in PCC and Not Currently Available in the Literature
Patients | Quality of confidentiality, privacy, portability; whether health IT leads to improved outcomes in a wide range of health conditions; efficiency; whether health IT can be tailored to individual preferences; ease of use in real-life situations, e.g., home, clinic, work; whether implementation cost will be passed down to patients
Family members | Effectiveness of health IT interventions for improving quality of care, coordination of care, and costs
Clinicians | Effectiveness of health IT interventions to enable PCC in real-time in day-to-day practice, especially among various sub-populations (women, minorities, the elderly, children)
Developers | Preferences of patients, family members, and clinicians regarding health IT used to enable PCC

IT: Information Technology

The most important stakeholders are health care providers, patients, and their families. To understand the value of health IT in promoting PCC, all stakeholders need information not only about the effectiveness of specific health IT applications for specific purposes, but also information about the applicability of health IT applications to their particular settings. These needs create a dilemma for investigators. On one hand, stakeholders first need to obtain a better understanding of the effectiveness of specific health IT applications at a specific level of system implementation for achieving specific types of outcomes. This calls for studies focusing on a narrow set of promising systems using standardized definitions of interventions and outcomes, and adequate sample sizes. On the other hand, studies must be generalizable to meet the needs of stakeholders working in different settings. Research in the use of health IT deliver patient-centered care would be useful to more providers, patients, and families if researchers designed studies to maximize applicability to different settings. We need a coordinated strategy to meet these competing needs, with large generalizable studies following initial demonstrations of the effectiveness of an intervention.

The primary outcomes studied to date have been very diverse, even within the types of outcomes we defined in our analytic framework (Figure 1). Various stakeholders are likely to differ in the outcomes that are most important to them. To meet the needs of different types of stakeholders, investigators may need to engage targeted stakeholders in the design of studies and the selection of most important outcomes to assess. While real improvements in all outcomes are the ultimate goal, that may not be realistic for most studies due to funding and resource constraints. In any case, stakeholders will have a better understanding of the effects of health IT applications on the outcomes most important to them if outcomes are defined in a more standardized way across studies. This is especially true of PCC-related outcomes, which should be included as primary study outcomes.

As mentioned above, it would also be useful to stakeholders to have more studies that describe the effects of health IT on cost and provider efficiency. More data supporting health IT as being at least cost- and time-neutral would go a long way toward encouraging providers and patients to welcome the use of health IT in daily practice.