# References

1 Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC. National Academy Press. 2001;6.
2 Davis K, Schoenbaum SC, Audet AM. A 2020 vision of patient-centered primary care. J Gen Intern Med. 2005;20(10):953-7. [pmid: 16191145].
3 American Academy of Family Physicians, American Academy of Pediatrics, American College of Physicians, American Osteopathic Association. The Joint Principles of the Patient-Centered Medical Home. 2007.
4 Silow-Carroll S, Alteras T, Stepnick L. Centered Care for Underserved Populations: Definition and Best Practices. 2006.
5 Stewart M, Brown J, Weston W, McWhinney I, McWilliam C, Freeman T. Patient-centered medicine: transforming the clinical method. 1995.
6 Gerteis M, Edgman-Levitan S, Daley J, Delbanco TL, editors. Through the Patient’s Eyes. Picker/Commonwealth Program for Patient-Centered Care. Jossey-Bass. 1993.
7 Shortliffe EH, Sondik EJ. The public health informatics infrastructure: anticipating its role in cancer. Cancer Causes Control. 2006;17(7):861-9. [pmid: 16841254].
8 Gruman J, Rovner MH, French ME, et al. From patient education to patient engagement: implications for the field of patient education. Patient Educ Couns. 2010;78(3):350-6. [pmid: 20202780].
9 A New Definition of Patient Engagement: What is Engagement and Why is it Important?. Washington, DC. 2010. http://www.cfah.org/pdfs/CFAH_Engagement_Behavior_Framework_2010.pdf.
10 Balint E. The possibilities of patient-centered medicine. J R Coll Gen Pract. 1969;17(82):269-76. [pmid: 5770926].
11 American Academy of Family Physicians, American Academy of Pediatrics, American College of Physicians, American Osteopathic Association. The Joint Principles of the Patient-Centered Medical Home. 2007.
12 Epstein RM, Franks P, Shields CG, et al. Patient-centered communication and diagnostic testing. Annals of Family Medicine. 2005;3(5):415-21. [pmid: 16189057].
13 Robinson KA, Dickersin K. Development of a highly sensitive search strategy for the retrieval of reports of controlled trials using PubMed. (0300-5771 (Print). 0300-5771 (Linking)).
14 Institute of Medicine. Key Capabilities of Electronic Health Systems. 2003.
15 Chaudhry B, Wang J, Wu S, et al. Systematic review: impact of health information technology on quality, efficiency, and costs of medical care. Ann Intern Med. 2006;144(10):742-52. [pmid: 16702590].
16 Harris L, Dresser C, Kreps GL. E-health as dialogue: Communication and quality of cancer care. 2004 AAAI Fall Symposium. October 21,2004 - October 24, 2004. Arlington, VA, United states. American Association for Artificial Intelligence. 2004:50-7.
17 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. (0197-2456 (Print). 0197-2456 (Linking)).
18 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. (1468-5833 (Electronic). (0959-535X (Linking)).
19 Methods Reference Manual for Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. 2007.
20 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
21 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
22 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
23 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
24 Persell S, Denecke-Dattalo T, Dunham D, Baker D. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194].
25 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].
26 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
27 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
28 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
29 Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. 2005;28(1):33-9. [pmid: 15616230].
30 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
31 Murtaugh CM, Pezzin LE, McDonald MV, Feldman PH, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res. 2005;40(3):849-64. [pmid: 15960694].
32 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
33 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
34 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
35 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
36 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
37 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
38 Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. [pmid: 17389290].
39 Murray MD, Loos B, Tu W, Eckert GJ, Zhou XH, Tierney WM. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506].
40 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
41 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
42 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemed J E Health. 2008;14(8):753-61. [pmid: 18954244].
43 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
44 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
45 Scherr D, Kastner P, Kollmann A, et al. Effect of home-based telemonitoring using mobile phone technology on the outcome of heart failure patients after an episode of acute decompensation: randomized controlled trial. J Med Internet Res. 2009;11(3):e34. [pmid: 19687005].
46 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
47 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
48 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
49 Nguyen BH, Nguyen KP, McPhee SJ, Nguyen AT, Tran DQ, Jenkins CN. Promoting cancer prevention activities among Vietnamese physicians in California. J Cancer Educ. 2000;15(2):82-5. [pmid: 10879896].
50 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
51 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
52 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
53 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
54 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
55 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
56 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
57 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
58 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
59 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
60 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
61 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
62 Kattan M, Crain EF, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117(6):e1095-103. [pmid: 16740812].
63 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
64 Cannon DS, Allen SN. A comparison of the effects of computer and manual reminders on compliance with a mental health clinical practice guideline. J Am Med Inform Assoc. 2000;7(2):196-203. [pmid: 10730603].
65 Rollman BL, Hanusa BH, Lowe HJ, Gilbert T, Kapoor WN, Schulberg HC. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139].
66 Marks IM, Kenwright M, McDonough M, Whittaker M, Mataix-Cols D. Saving clinicians’ time by delegating routine aspects of therapy to a computer: a randomized controlled trial in phobia/panic disorder. Psychological Medicine. 2004;34(1):9-17. [pmid: 14971623].
67 Linder JA, Rigotti NA, Schneider LI, Kelley JH, Brawarsky P, Haas JS. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. [pmid: 19398690].
68 Wolfenden L, Wiggers J, Knight J, et al. Increasing smoking cessation care in a preoperative clinic: a randomized controlled trial. Preventive Medicine. 2005;41(1):284-90. [pmid: 15917023].
69 Bentz CJ, Bayley KB, Bonin KE, et al. Provider feedback to improve 5A’s tobacco cessation in primary care: a cluster randomized clinical trial. Nicotine Tob Res. 2007;9(3):341-9. [pmid: 17365766].
70 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
71 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemed J E Health. 2008;14(8):753-61. [pmid: 18954244].
72 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
73 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
74 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
75 Murtaugh CM, Pezzin LE, McDonald MV, Feldman PH, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res. 2005;40(3):849-64. [pmid: 15960694].
76 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
77 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
78 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
79 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
80 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
81 Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. [pmid: 17389290].
82 Murray MD, Loos B, Tu W, Eckert GJ, Zhou XH, Tierney WM. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506].
83 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
84 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
85 Santamore WP, Homko CJ, Kashem A, McConnell TR, Menapace FJ, Bove AA. Accuracy of blood pressure measurements transmitted through a telemedicine system in underserved populations. Telemed J E Health. 2008;14(4):333-8. [pmid: 18570561].
86 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
87 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav. 2006;9(5):603-7. [pmid: 17034328].
88 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
89 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
90 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
91 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
92 Raebel MA, Carroll NM, Kelleher JA, Chester EA, Berga S, Magid DJ. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
93 Hogg WE, Bass M, Calonge N, Crouch H, Satenstein G. Randomized controlled study of customized preventive medicine reminder letters in a community practice. Can Fam Physician. 1998;44:81-8. [pmid: 9481466].
94 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by off-line data analysis. Stud Health Technol Inform. 2004;107(Pt 1):135-9. [pmid: 15360790].
95 Rothschild JM, McGurk S, Honour M, et al. Assessment of education and computerized decision support interventions for improving transfusion practice. Transfusion. 2007;47(2):228-39. [pmid: 17302768].
96 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
97 Bindels R, Hasman A, Kester AD, Talmon JL, De Clercq PA, Winkens RA. The efficacy of an automated feedback system for general practitioners. Inform Prim Care. 2003;11(2):69-74. [pmid: 14567873].
98 Rhodes KV, Drum M, Anliker E, Frankel RM, Howes DS, Levinson W. Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Archives of Internal Medicine. 2006;166(10):1107-14. [pmid: 16717173].
99 Overhage JM, Dexter PR, Perkins SM, et al. A randomized, controlled trial of clinical information shared from another institution. Ann Emerg Med. 2002;39(1):14-23. [pmid: 11782726].
100 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
101 Roukema J, Steyerberg EW, van der Lei J, Moll HA. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. 2008;15(1):107-13. [pmid: 17947627].
102 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005;7(4):221-9. [pmid: 15834239].
103 Walker I, Sigouin C, Sek J, et al. Comparing hand-held computers and paper diaries for haemophilia home therapy: a randomized trial. Haemophilia. 2004;10(6):698-704. [pmid: 15569164].
104 Lester WT, Grant R, Barnett GO, Chueh H. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809].
105 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
106 Baker AM, McCarthy B, Gurley VF, Yood MU. Influenza immunization in a managed care organization. J Gen Intern Med. 1998;13(7):469-75. [pmid: 9686713].
107 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
108 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
109 Quinn P, Goka J, Richardson H. Assessment of an electronic daily diary in patients with overactive bladder. BJU Int. 2003;91(7):647-52. [pmid: 12699477].
110 Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-8. [pmid: 16776793].
111 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
112 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. [pmid: 18373136].
113 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
114 Hogg WE, Bass M, Calonge N, Crouch H, Satenstein G. Randomized controlled study of customized preventive medicine reminder letters in a community practice. Can Fam Physician. 1998;44:81-8. [pmid: 9481466].
115 Trautmann E, Kröner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008;36(2):241-5.
116 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemed J E Health. 2002;8(3):313-21. [pmid: 12419025].
117 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-8. [pmid: 16565867].
118 Soopramanien A, Pain H, Stainthorpe A, Menarini M, Ventura M. Using telemedicine to provide post-discharge support for patients with spinal cord injuries. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):68-70. [pmid: 16036001].
119 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
120 Madaras-Kelly KJ, Hannah EL, Bateman K, Samore MH. Experience with a clinical decision support system in community pharmacies to recommend narrow-spectrum antimicrobials, nonantimicrobial prescriptions, and OTC products to decrease broad-spectrum antimicrobial use. J Manag Care Pharm. 2006;12(5):390-7. [pmid: 16792446].
121 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
122 Hassol A, Walker JM, Kidder D, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
123 Tamblyn R, Huang A, Taylor L, et al. A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc. 2008;15(4):430-8. [pmid: 18436904].
124 Rothschild JM, McGurk S, Honour M, et al. Assessment of education and computerized decision support interventions for improving transfusion practice. Transfusion. 2007;47(2):228-39. [pmid: 17302768].
125 van Wijk MA, van der Lei J, Mosseveld M, Bohnen AM, van Bemmel JH. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
126 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
127 Bowns IR, Collins K, Walters SJ, McDonagh AJ. Telemedicine in dermatology: a randomised controlled trial. Health Technol Assess. 2006;10(43):iii-iv. ix. xi. 1. 39. [pmid: 17049140].
128 Bindels R, Hasman A, van Wersch JW, Talmon J, Winkens RA. Evaluation of an automated test ordering and feedback system for general practitioners in daily practice. Int J Med Inform. 2004;73(9–10):705-12. [pmid: 15325327].
129 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
130 Glassman PA, Belperio P, Lanto A, et al. The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc. 2007;14(4):424-31. [pmid: 17460134].
131 Dykes PC, Carroll DL, Benoit A, et al. A randomized trial of standardized nursing patient assessment using wireless devices. AMIA Annu Symp Proc. 2007:206-10. [pmid: 18693827].
132 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
133 Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
134 Bindels R, Hasman A, Kester AD, Talmon JL, De Clercq PA, Winkens RA. The efficacy of an automated feedback system for general practitioners. Inform Prim Care. 2003;11(2):69-74. [pmid: 14567873].
135 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
136 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
137 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
138 Rollman BL, Hanusa BH, Lowe HJ, Gilbert T, Kapoor WN, Schulberg HC. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139].
139 Madaras-Kelly KJ, Hannah EL, Bateman K, Samore MH. Experience with a clinical decision support system in community pharmacies to recommend narrow-spectrum antimicrobials, nonantimicrobial prescriptions, and OTC products to decrease broad-spectrum antimicrobial use. J Manag Care Pharm. 2006;12(5):390-7. [pmid: 16792446].
140 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
141 Lester WT, Grant R, Barnett GO, Chueh H. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809].
142 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
143 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
144 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
145 Cannon DS, Allen SN. A comparison of the effects of computer and manual reminders on compliance with a mental health clinical practice guideline. J Am Med Inform Assoc. 2000;7(2):196-203. [pmid: 10730603].
146 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
147 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
148 Nguyen BH, Nguyen KP, McPhee SJ, Nguyen AT, Tran DQ, Jenkins CN. Promoting cancer prevention activities among Vietnamese physicians in California. J Cancer Educ. 2000;15(2):82-5. [pmid: 10879896].
149 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
150 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. [pmid: 18373136].
151 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
152 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
153 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
154 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
155 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
156 Roukema J, Steyerberg EW, van der Lei J, Moll HA. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. 2008;15(1):107-13. [pmid: 17947627].
157 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
158 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
159 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
160 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by off-line data analysis. Stud Health Technol Inform. 2004;107(Pt 1):135-9. [pmid: 15360790].
161 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
162 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
163 Persell S, Denecke-Dattalo T, Dunham D, Baker D. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194].
164 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].
165 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
166 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
167 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
168 Bentz CJ, Bayley KB, Bonin KE, et al. Provider feedback to improve 5A’s tobacco cessation in primary care: a cluster randomized clinical trial. Nicotine Tob Res. 2007;9(3):341-9. [pmid: 17365766].
169 Overhage JM, Dexter PR, Perkins SM, et al. A randomized, controlled trial of clinical information shared from another institution. Ann Emerg Med. 2002;39(1):14-23. [pmid: 11782726].
170 Linder JA, Rigotti NA, Schneider LI, Kelley JH, Brawarsky P, Haas JS. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. [pmid: 19398690].
171 Marks IM, Kenwright M, McDonough M, Whittaker M, Mataix-Cols D. Saving clinicians’ time by delegating routine aspects of therapy to a computer: a randomized controlled trial in phobia/panic disorder. Psychological Medicine. 2004;34(1):9-17. [pmid: 14971623].
172 Wolfenden L, Wiggers J, Knight J, et al. Increasing smoking cessation care in a preoperative clinic: a randomized controlled trial. Preventive Medicine. 2005;41(1):284-90. [pmid: 15917023].
173 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
174 Trautmann E, Kröner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008;36(2):241-5.
175 Mayo-Smith MF, Agrawal A. Factors associated with improved completion of computerized clinical reminders across a large healthcare system. Int J Med Inform. 2007;76(10):710-6. [pmid: 16935025].
176 Baker AM, McCarthy B, Gurley VF, Yood MU. Influenza immunization in a managed care organization. J Gen Intern Med. 1998;13(7):469-75. [pmid: 9686713].
177 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
178 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
179 Kattan M, Crain EF, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117(6):e1095-103. [pmid: 16740812].
180 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-8. [pmid: 16565867].
181 Soopramanien A, Pain H, Stainthorpe A, Menarini M, Ventura M. Using telemedicine to provide post-discharge support for patients with spinal cord injuries. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):68-70. [pmid: 16036001].
182 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
183 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
184 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemed J E Health. 2002;8(3):313-21. [pmid: 12419025].
185 Quinn P, Goka J, Richardson H. Assessment of an electronic daily diary in patients with overactive bladder. BJU Int. 2003;91(7):647-52. [pmid: 12699477].
186 Raebel MA, Chester EA, Newsom EE, et al. Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy. 2006;26(5):619-26. [pmid: 16637791].
187 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
188 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005;7(4):221-9. [pmid: 15834239].
189 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. J Am Med Inform Assoc. 2003;10(6):573-9. [pmid: 12925545].
190 Rhodes KV, Drum M, Anliker E, Frankel RM, Howes DS, Levinson W. Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Archives of Internal Medicine. 2006;166(10):1107-14. [pmid: 16717173].
191 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
192 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
193 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006;30(4):397-405.
194 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
195 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav. 2006;9(5):603-7. [pmid: 17034328].
196 Walker I, Sigouin C, Sek J, et al. Comparing hand-held computers and paper diaries for haemophilia home therapy: a randomized trial. Haemophilia. 2004;10(6):698-704. [pmid: 15569164].
197 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
198 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
199 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
200 Yoon KH, Kim HS. A short message service by cellular phone in type 2 diabetic patients for 12 months. Diabetes Res Clin Pract. 2008;79(2):256-61. [pmid: 17988756].
201 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: a randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
202 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
203 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
204 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
205 Benhamou PY, Melki V, Boizel R, et al. One-year efficacy and safety of Web-based follow-up using cellular phone in type 1 diabetic patients under insulin pump therapy: the PumpNet study. Diabetes & Metabolism. 2007;33(3):220-6. [pmid: 17395516].
206 Cadario F, Binotti M, Brustia M, et al. Telecare for teenagers with type 1 diabetes: a trial. Minerva Pediatr. 2007;59(4):299-305. [pmid: 17947836].
207 Farmer AJ, Gibson OJ, Dudley C, et al. A randomized controlled trial of the effect of real-time telemedicine support on glycemic control in young adults with type 1 diabetes (ISRCTN 46889446). Diabetes Care. 2005;28(11):2697-702. [pmid: 16249542].
208 Montori VM, Helgemoe PK, Guyatt GH, et al. Telecare for patients with type 1 diabetes and inadequate glycemic control: a randomized controlled trial and meta-analysis. Diabetes Care. 2004;27(5):1088-94. [pmid: 15111526].
209 Shea S. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
210 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
211 Benhamou PY, Melki V, Boizel R, et al. One-year efficacy and safety of Web-based follow-up using cellular phone in type 1 diabetic patients under insulin pump therapy: the PumpNet study. Diabetes & Metabolism. 2007;33(3):220-6. [pmid: 17395516].
212 Poller L, Keown M, Ibrahim S, et al. A multicentre randomised clinical endpoint study of PARMA 5 computer-assisted oral anticoagulant dosage. Br J Haematol. 2008;143(2):274-83. [pmid: 18759767].
213 Verheijden M, Bakx JC, Akkermans R, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. 2004;6(4):e44. [pmid: 15631968].
214 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
215 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
216 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
217 Madsen LB, Kirkegaard P, Pedersen EB. Blood pressure control during telemonitoring of home blood pressure. A randomized controlled trial during 6 months. Blood Press. 2008;17(2):78-86. [pmid: 18568696].
218 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
219 Madsen LB, Kirkegaard P, Pedersen EB. Blood pressure control during telemonitoring of home blood pressure. A randomized controlled trial during 6 months. Blood Press. 2008;17(2):78-86. [pmid: 18568696].
220 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
221 McCowan C, Neville RG, Ricketts IW, Warner FC, Hoskins G, Thomas GE. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
222 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-68. [pmid: 17603828].
223 East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc AMIA Symp. 1999:251-5. [pmid: 10566359].
224 Kerr J, Patrick K, Norman G, et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety. 2008;25(7):555-8. [pmid: 17557319].
225 Proudfoot J, Ryden C, Everitt B, et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46-54. [pmid: 15231555].
226 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
227 Hansson L, Svensson B, Björkman T, et al. What works for whom in a computer-mediated communication intervention in community psychiatry? Moderators of outcome in a cluster randomized trial. Acta Psychiatrica Scandinavica. 2008;118(5):404-9. [pmid: 18759805].
228 Kenwright M, Marks I, Graham C, Franses A, Mataix-Cols D. Brief scheduled phone support from a clinician to enhance computer-aided self-help for obsessive-compulsive disorder: randomized controlled trial. Journal of Clinical Psychology. 2005;61(12):1499-508. [pmid: 16173084].
229 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
230 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial internet weight loss program. Obes Res. 2004;12(6):1011-8. [pmid: 15229342].
231 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991].
232 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231-43. [pmid: 16899804].
233 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166(15):1620-5. [pmid: 16908795].
234 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
235 Tate DF, Wing RR, Winett RA. Using Internet technology to deliver a behavioral weight loss program. JAMA. 2001;285(9):1172-7. [pmid: 11231746].
236 Napolitano MA, Fotheringham M, Tate D, et al. Evaluation of an Internet-based physical activity intervention: A preliminary investigation. Annals of Behavioral Medicine. 2003;25(2):92-9. [pmid: 12704010].
237 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
238 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111(3):368-77. [pmid: 15363881].
239 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
240 Phillips VL, Vesmarovich S, Hauber R, Wiggers E, Egner A. Telehealth: reaching out to newly injured spinal cord patients. Public Health Reports (Washington, D.C.: 1974). Suppl 1. 2001;116:94-102.
241 Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. 2009;169(8):771-80. [pmid: 19398689].
242 Glassman PA, Belperio P, Lanto A, et al. The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc. 2007;14(4):424-31. [pmid: 17460134].
243 Raebel MA, Carroll NM, Kelleher JA, Chester EA, Berga S, Magid DJ. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
244 Berner ES, Houston TK, Ray MN, et al. Improving ambulatory prescribing safety with a handheld decision support system: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(2):171-9. [pmid: 16357350].
245 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
246 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
247 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
248 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
249 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
250 East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc AMIA Symp. 1999:251-5. [pmid: 10566359].
251 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111(3):368-77. [pmid: 15363881].
252 Deutscher D, Hart DL, Dickstein R, Horn SD, Gutvirtz M. Implementing an integrated electronic outcomes and electronic health record process to create a foundation for clinical practice improvement. Phys Ther. 2008;88(2):270-85. [pmid: 18042656].
253 Chima CS, Farmer-Dziak N, Cardwell P, Snow S. Use of technology to track program outcomes in a diabetes self-management program. J Am Diet Assoc. 2005;105(12):1933-8. [pmid: 16321600].
254 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
255 Deutscher D, Hart DL, Dickstein R, Horn SD, Gutvirtz M. Implementing an integrated electronic outcomes and electronic health record process to create a foundation for clinical practice improvement. Phys Ther. 2008;88(2):270-85. [pmid: 18042656].
256 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
257 Trief P, Morin P, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31.
258 Mayo-Smith MF, Agrawal A. Factors associated with improved completion of computerized clinical reminders across a large healthcare system. Int J Med Inform. 2007;76(10):710-6. [pmid: 16935025].
259 Rinfret S, Lussier MT, Peirce A, et al. The impact of a multidisciplinary information technology-supported program on blood pressure control in primary care. Circulation. Cardiovascular Quality and Outcomes. 2009;2(3):170-7. [pmid: 20031834].
260 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
261 Bever J. Self assessment for practices considering electronic medical record systems. J Med Pract Manage. 2007;23(2):80-3. [pmid: 17974082].
262 O’Grady MA, Gitelson E, Swaby RF, et al. Development and implementation of a medical oncology quality improvement tool for a regional community oncology network: the Fox Chase Cancer Center Partners initiative. J Natl Compr Canc Netw. 2007;5(9):875-82. [pmid: 17977500].
263 Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. 2009;169(8):771-80. [pmid: 19398689].
264 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
265 Cadario F, Binotti M, Brustia M, et al. Telecare for teenagers with type 1 diabetes: a trial. Minerva Pediatr. 2007;59(4):299-305. [pmid: 17947836].
266 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
267 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
268 Napolitano MA, Fotheringham M, Tate D, et al. Evaluation of an Internet-based physical activity intervention: a preliminary investigation. Annals of Behavioral Medicine. 2003;25(2):92-9. [pmid: 12704010].
269 Hansson L, Svensson B, Björkman T, et al. What works for whom in a computer-mediated communication intervention in community psychiatry? Moderators of outcome in a cluster randomized trial. Acta Psychiatrica Scandinavica. 2008;118(5):404-9. [pmid: 18759805].
270 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure: Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
271 Farmer AJ, Gibson OJ, Dudley C, et al. A randomized controlled trial of the effect of real-time telemedicine support on glycemic control in young adults with type 1 diabetes (ISRCTN 46889446). Diabetes Care. 2005;28(11):2697-702. [pmid: 16249542].
272 Kenwright M, Marks I, Graham C, Franses A, Mataix-Cols D. Brief scheduled phone support from a clinician to enhance computer-aided self-help for obsessive-compulsive disorder: randomized controlled trial. Journal of Clinical Psychology. 2005;61(12):1499-508. [pmid: 16173084].
273 Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. 2005;28(1):33-9. [pmid: 15616230].
274 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991].
275 Proudfoot J, Ryden C, Everitt B, et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46-54. [pmid: 15231555].
276 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
277 Williams GC, Lynch M, Glasgow RE. Computer-assisted intervention improves patient-centered diabetes care by increasing autonomy support. Health Psychology: Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(6):728-34.
278 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: a randomized, controlled trial. 2006;30(4):397-405.
279 Sevick MA, Zickmund S, Korytkowski M, et al. Design, feasibility, and acceptability of an intervention using personal digital assistant-based self-monitoring in managing type 2 diabetes. Contemp Clin Trials. 2008;29(3):396-409. [pmid: 17997364].
280 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. 2008;17(3):182-99. [pmid: 18617707].
281 Glazebrook C, Garrud P, Avery A, Coupland C, Williams H. Impact of a multimedia intervention “Skinsafe” on patients’ knowledge and protective behaviors. Preventive Medicine. 2006;42(6):449-54. [pmid: 16580059].
282 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
283 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
284 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
285 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
286 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166(15):1620-5. [pmid: 16908795].
287 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231-43. [pmid: 16899804].
288 Sevick MA, Zickmund S, Korytkowski M, et al. Design, feasibility, and acceptability of an intervention using personal digital assistant-based self-monitoring in managing type 2 diabetes. Contemp Clin Trials. 2008;29(3):396-409. [pmid: 17997364].
289 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. 2008;17(3):182-99. [pmid: 18617707].
290 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
291 Helzer JE, Rose GL, Badger GJ, et al. Using interactive voice response to enhance brief alcohol intervention in primary care settings. Journal of Studies on Alcohol and Drugs. 2008;69(2):251-8. [pmid: 18299766].
292 Neumann T, Neuner B, Weiss-Gerlach E, et al. The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. The Journal of Trauma. 2006;61(4):805-14. [pmid: 17033544].
293 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. Int J Med Inform. 2008;77(11):715-22. [pmid: 18417417].
294 Japuntich SJ, Zehner ME, Smith SS, et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res. 2006;8(Suppl 1):S59-67. [pmid: 17491172].
295 Patten CA, Croghan IT, Meis TM, et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns. 2006;64(1–3):249-58. [pmid: 16616449].
296 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
297 Col NF, Ngo L, Fortin JM, Goldberg RJ, O’Connor AM. Can computerized decision support help patients make complex treatment decisions? A randomized controlled trial of an individualized menopause decision aid. Med Decis Making. 2007;27(5):585-98. [pmid: 17873260].
298 Graham ID, Logan J, Bennett CL, et al. Physicians’ intentions and use of three patient decision aids. BMC Med Inform Decis Mak. 2007;7:20. [pmid: 17617908].
299 Stevens J, Kelleher KJ, Gardner W, et al. Trial of computerized screening for adolescent behavioral concerns. Pediatrics. 2008;121(6):1099-105. [pmid: 18519478].
300 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure: Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
301 Marceau LD, Link C, Jamison RN, Carolan S. Electronic diaries as a tool to improve pain management: is there any evidence?. Pain Med. 2007;8(Suppl 3):S101-9. [pmid: 17877520].
302 Tuil WS, Verhaak CM, Braat DD, de Vries Robbe PF, Kremer JA. Empowering patients undergoing in vitro fertilization by providing Internet access to medical data. Fertil Steril. 2007;88(2):361-8. [pmid: 17416366].
303 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp. 2002:410-4. [pmid: 12463857].
304 Winzelberg AJ, Eppstein D, Eldredge KL, et al. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol. 2000;68(2):346-50. [pmid: 10780136].
305 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
306 Woods KF, Kutlar A, Johnson JA, et al. Sickle cell telemedicine and standard clinical encounters: a comparison of patient satisfaction. Telemedicine Journal. 1999;5(4):349-56. [pmid: 10908450].
307 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410-7. [pmid: 15500594].
308 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemed J E Health. 2004;10:S, 26-s-34.
309 Gray JE, Safran C, Davis RB, et al. Baby CareLink: using the internet and telemedicine to improve care for high-risk infants. Pediatrics. 2000;106(6):1318-24. [pmid: 11099583].
310 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: a randomized controlled evaluation. Health Promotion International. 2007;22(2):122-8. [pmid: 17355994].
311 McDonald EM, Solomon B, Shields W, et al. Evaluation of kiosk-based tailoring to promote household safety behaviors in an urban pediatric primary care practice. Patient Education and Counseling. 2005;58(2):168-81. [pmid: 16009293].
312 Matheny ME, Gandhi TK, Orav EJ, et al. Impact of an automated test results management system on patients’ satisfaction about test result communication. Arch Intern Med. 2007;167(20):2233-9. [pmid: 17998497].
313 Marcus BH, Napolitano MA, King AC, et al. Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychology : Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(4):401-9.
314 Barak A, Bloch N. Factors Related to Perceived Helpfulness in Supporting Highly Distressed Individuals through an Online Support Chat. CyberPsychology & Behavior. 2006;9(1):60-8. [pmid: 16497119].
315 Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: a randomized controlled trial. Journal of Zhejiang University. Science. B. 2008;9(1):34-8. [pmid: 18196610].
316 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
317 Finch T, Mort M, May C, Mair F. Telecare: perspectives on the changing role of patients and citizens. J Telemed Telecare. 2005;11(Suppl 1):51-3. [pmid: 16035993].
318 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
319 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
320 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
321 Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self-management tools for asthma--patients’ opinions and quality of data in a randomized crossover study. Stud Health Technol Inform. 2007;127:178-89. [pmid: 17901611].
322 Beale I, Marin-Bowling V, Guthrie N, Kato P. Young cancer patients’ perceptions of a video game used to promote self care. International Electronic Journal of Health Education. 2006;9:202-12.
323 Finch T, Mort M, May C, Mair F. Telecare: perspectives on the changing role of patients and citizens. J Telemed Telecare. 2005;11(Suppl 1):51-3. [pmid: 16035993].
324 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: A randomized controlled evaluation. Health Promotion International. 2007;22(2):122-8. [pmid: 17355994].
325 Hassol A, Walker JM, Kidder D, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
326 Matheny ME, Gandhi TK, Orav EJ, et al. Impact of an automated test results management system on patients’ satisfaction about test result communication. Arch Intern Med. 2007;167(20):2233-9. [pmid: 17998497].
327 Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: a randomized controlled trial. Journal of Zhejiang University. Science. B. 2008;9(1):34-8. [pmid: 18196610].
328 Santamore WP, Homko CJ, Kashem A, McConnell TR, Menapace FJ, Bove AA. Accuracy of blood pressure measurements transmitted through a telemedicine system in underserved populations. Telemed J E Health. 2008;14(4):333-8. [pmid: 18570561].
329 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-68. [pmid: 17603828].
330 Helzer JE, Rose GL, Badger GJ, et al. Using interactive voice response to enhance brief alcohol intervention in primary care settings. Journal of Studies on Alcohol and Drugs. 2008;69(2):251-8. [pmid: 18299766].
331 Graham ID, Logan J, Bennett CL, et al. Physicians’ intentions and use of three patient decision aids. BMC Med Inform Decis Mak. 2007;7:20. [pmid: 17617908].
332 Wakefield BJ, Bylund CL, Holman JE, et al. Nurse and patient communication profiles in a home-based telehealth intervention for heart failure management. Patient Education and Counseling. 2008;71(2):285-92. [pmid: 18337049].
333 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient attitudes toward a web-based system for monitoring chronic wounds. Telemed J E Health. 2004;10:S, 26-s-34.
334 Marcus BH, Napolitano MA, King AC, et al. Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychology: Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(4):401-9.
335 Gray JE, Safran C, Davis RB, et al. Baby CareLink: using the internet and telemedicine to improve care for high-risk infants. Pediatrics. 2000;106(6):1318-24. [pmid: 11099583].
336 McDonald EM, Solomon B, Shields W, et al. Evaluation of kiosk-based tailoring to promote household safety behaviors in an urban pediatric primary care practice. Patient Education and Counseling. 2005;58(2):168-81. [pmid: 16009293].
337 Yeh Y-T, Liu C-T, Wu S-J, Lee TI. Assessment of user satisfaction with an internet-based integrated patient education system for diabetes management. 2008 10th IEEE Intl. Conf. on e-Health Networking, Applications and Service, HEALTHCOM 2008. July 07,2008- July 09,2008. Singapore, Singapore. Inst. of Elec. and Elec. Eng Computer Society. 2008:85-9.
338 Barak A, Bloch N. Factors related to perceived helpfulness in supporting highly distressed individuals through an online support chat. CyberPsychology & Behavior. 2006;9(1):60-8. [pmid: 16497119].
339 Saver BG, Gustafson D, Taylor TR, et al. A tale of two studies: The importance of setting, subjects and context in two randomized, controlled trials of a web-based decision support for perimenopausal and postmenopausal health decisions. Patient Education and Counseling. 2007;66(2):211-22. [pmid: 17317080].
340 Roek MG, Welschen LM, Kostense PJ, Dekker JM, Snoek FJ, Nijpels G. Web-based guided insulin self-titration in patients with type 2 diabetes: the Di@log study. Design of a cluster randomised controlled trial. BMC Fam Pract. 2009;10:40. [pmid: 19508712].
341 Stang P, Suppapanaya N, Hogue SL, Park D, Rigney U. Persistence with once-daily versus twice-daily bupropion for the treatment of depression in a large managed-care population. Am J Ther. 2007;14(3):241-6. [pmid: 17515697].
342 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
343 Kornman KP, Shrewsbury VA, Chou AC, et al. Electronic therapeutic contact for adolescent weight management: the Loozit study. Telemed J E Health. 2010;16(6):678-85. [pmid: 20575613].
344 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
345 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
346 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
347 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
348 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. Int J Med Inform. 2008;77(11):715-22. [pmid: 18417417].
349 Chan EC, Vernon SW. Implementing an intervention to promote colon cancer screening through e-mail over the Internet: lessons learned from a pilot study. Medical Care. 2008;46(9 Suppl 1):S117-22. [pmid: 18725823].
350 Morgan GJ, Grant B, Craig B, Sands A, Casey F. Supporting families of critically ill children at home using videoconferencing. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):91-2. [pmid: 16036009].
351 Sciamanna CN, Nicholson RA, Lofland JH, Manocchia M, Mui S, Hartman CW. Effects of a website designed to improve the management of migraines. Headache: The Journal of Head and Face Pain. 2006;46(1):92-100.
352 Schifferdecker KE, Reed VA, Homa K. A training intervention to improve information management in primary care. Fam Med. 2008;40(6):423-32. [pmid: 18773781].
353 Chu A, Huber J, Mastel-Smith B, Cesario S. “Partnering with Seniors for Better Health”: computer use and Internet health information retrieval among older adults in a low socioeconomic community”. Journal of the Medical Library Association: JMLA. 2009;97(1):12-20. [pmid: 19159002].
354 Saleem JJ, Patterson ES, Militello L, Render ML, Orshansky G, Asch SM. Exploring barriers and facilitators to the use of computerized clinical reminders. J Am Med Inform Assoc. 2005;12(4):438-47. [pmid: 15802482].
355 Ash JS, Gorman PN, Lavelle M, et al. A cross-site qualitative study of physician order entry. J Am Med Inform Assoc. 2003;10(2):188-200. [pmid: 12595408].
356 Kaufman D, Pevzner J, Hilliman C, et al. Technology topics. Redesigning a telehealth diabetes management program for a digital divide seniors population. Home Health Care Management & Practice. 2006;18(3):223-34.
357 Lober WB, Zierler B, Herbaugh A, et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc. 2006:514-8. [pmid: 17238394].
358 Kleiner KD, Akers R, Burke BL, Werner EJ. Parent and physician attitudes regarding electronic communication in pediatric practices. Pediatrics. 2002;109(5):740-4. [pmid: 11986430].
359 Patterson ES, Doebbeling BN, Fung CH, Militello L, Anders S, Asch SM. Identifying barriers to the effective use of clinical reminders: bootstrapping multiple methods. J Biomed Inform. 2005;38(3):189-99. [pmid: 15896692].
360 Trivedi MH, Daly EJ, Kern JK, Grannemann BD, Sunderajan P, Claassen CA. Barriers to implementation of a computerized decision support system for depression: an observational report on lessons learned in “real world” clinical settings. BMC Med Inform Decis Mak. 2009;9:6. [pmid: 19159458].
361 Varonen H, Kortteisto T, Kaila M. What may help or hinder the implementation of computerized decision support systems (CDSSs): a focus group study with physicians. Fam Pract. 2008;25(3):162-7. [pmid: 18504253].
362 Samoutis G, Soteriades ES, Kounalakis DK, Zachariadou T, Philalithis A, Lionis C. Implementation of an electronic medical record system in previously computer-naive primary care centres: a pilot study from Cyprus. Inform Prim Care. 2007;15(4):207-16. [pmid: 18237477].
363 Garcia-Sanchez R. The patient’s perspective of computerised records: a questionnaire survey in primary care. Inform Prim Care. 2008;16(2):93-9. [pmid: 18713525].
364 Likourezos A, Chalfin DB, Murphy DG, Sommer B, Darcy K, Davidson SJ. Physician and nurse satisfaction with an Electronic Medical Record system. J Emerg Med. 2004;27(4):419-24. [pmid: 15498630].
365 Bobrie G, Postel-Vinay N, Delonca J, Corvol P. Self-measurement and self-titration in hypertension: a pilot telemedicine study. Am J Hypertens. 2007;20(12):1314-20. [pmid: 18047923].
366 Shore JH, Brooks E, Savin D, Orton H, Grigsby J, Manson SM. Acceptability of telepsychiatry in American Indians. Telemedicine and E-Health. 2008;14(5):461-6. [pmid: 18578681].
367 Chinman M, Hassell J, Magnabosco J, Nowlin-Finch N, Marusak S, Young AS. The feasibility of computerized patient self-assessment at mental health clinics. Adm Policy Ment Health. 2007;34(4):401-9. [pmid: 17453332].
368 Dombkowski KJ, Leung SW, Clark SJ. Provider attitudes regarding use of an immunization information system to identify children with asthma for influenza vaccination. J Public Health Manag Pract. 2007;13(6):567-71. [pmid: 17984709].
369 Eminovic N, Wyatt JC, Tarpey AM, Murray G, Ingrams GJ. First evaluation of the NHS Direct Online Clinical Enquiry Service: A Nurse-led Web Chat Triage Service for the Public. J Med Internet Res. 2004;6(2).
370 Christensen T, Grimsmo A. Instant availability of patient records, but diminished availability of patient information: a multi-method study of GP’s use of electronic patient records. BMC Med Inform Decis Mak. 2008;8:12. [pmid: 18373858].
371 Wang Maisie, Lau C, Matsen FAI, Kim Yongmin. Personal health information management system and its application in referral management. IEEE Transactions on Information Technology in Biomedicine. 2004;8(3):287-97. [pmid: 15484434].