# Introduction

## Background

The Institute of Medicine defines patient-centered care (PCC) as “care that is respectful of and responsive to individual patient preferences, needs and values, and ensuring that patient values guide all clinical decisions.”1 The Institute of Medicine recognizes PCC as one of the six major domains of health care quality (the other domains include effectiveness, safety, timeliness, efficiency, and equity). To enhance our understanding of what is involved in delivering PCC, experts have identified several different components of PCC: coordination and integration of care, whole-person orientation, enhanced clinician-patient relationship, clinical information systems, and socio-cultural competence

(See Figure 1 and Tables 1–4).2–6 Despite the fact that many experts agree about the importance of PCC, the United States health care system faces enormous challenges in finding ways to deliver it.

Figure 1 Conceptual framework^*^ * Key questions 3 (knowledge of evidence deficits) and 4 (critical information regarding health IT applications) are not included in this conceptual framework. on enabling patient-centered care through health information technology

KQ = Key Question

Figure 1. Conceptual framework* on enabling patient-centered care through health information technology. This framework defines health information technologies under investigation (care management, telehealth, personal health record/patient portals, electronic messaging, and shared decisionmaking) and the components of patient-centered care that they may impact (coordination and integration of care, whole-person orientation, enhanced clinician/patient relationship, clinical information systems, and socio-cultural competence). Further this framework illustrates that there are barriers and facilitators(Key Question 2) to the health information technology applications affecting the components of patient centered care. Specific outcomes of interest are defines as system/healthcare processes (Key Question 1a), clinical (Key Question 1b), intermediate (Key Question 1c), responsiveness to patient needs and preferences (Key Question 1d), and patient-provider communication (Key Question 1e).

Table 1 Categorization of outcomes addressed in Key Question 1

System/health care process (KQ1a)
Receiving appropriate treatment
Guideline adherence
Quality of care metrics
Documentation completeness
Cost-effectiveness
Timeliness
Clinical (KQ1b)
Disease-specific parameters
Quality of life
Safety
Intermediate (KQ1c)
Health knowledge
Health behaviors
Patient satisfaction
Responsiveness to patient needs and preferences (KQ1d)
Patient
Patient preferences, values, and treatment needs
Patient-provider communication (KQ1e)
Shared decisionmaking
Health communication
Patient and clinician access

Table 2 Categorization of barriers and facilitators addressed in Key Question 2

Barriers
Usability
Access
Training
Cost
Computer literacy
Increased workload or change in workflow
Implementation
Confidentiality
Facilitators
Satisfaction
Ease of use
Usefulness
Efficiency

Table 3 Categorization of health information technology

Care management tools
Information technology guided self care
Social networking
Peer-to-peer support
Information technology guided disease management
Electronic medical records
Computerized order entry
Disease registry
Electronic prescribing
Clinical decision support
Telehealth
Telemonitoring systems
Telemedicine
Personal health record and patient portal related applications (PHR/patient portals)
Personal health record
Patient portal
Education via information technology
Interactive lifestyle counseling
mHealth
Secure electronic messaging
Information exchange
Communication via e-mail
Social networking/peer-to-peer sites
Shared decisionmaking
Shared decisionmaking tools

Table 4 Categorization of components of patient centered care

Coordination and integration of care
Quality improvement
Quality and safety
Integrated care
Prevention and health promotion
Routine patient feedback to the practice
Transition and continuity of care
Whole-person orientation
Alleviation of fear and anxiety
Respecting patients’ values, preferences and needs
Emotional support
Exploring the disease and illness condition
Physical comfort
Enhanced clinician-patient relationship
Patient engagement in their care
Patient empowerment
Finding common ground
Clinical information systems
Publicly available information on practices
Practice-based learning
Socio-cultural competence
Community outreach
Family and friend involvement in care

One of the most promising ways to support the delivery of PCC is through the use of health information technology (health IT). For this evidence report, we broadly define health IT as “the use of information and communication technology in health care to support the delivery of patient or population care or to support patient self-management.”7 In this report, we will examinie health IT types in the following categories: care management tools, telehealth, personal health records/patient portals, secure electronic messaging, and shared decisionmaking. (See the Glossary for definitions and examples of health IT applications.) In recent years, the health care industry has developed an increasing number of health IT applications designed to provide PCC. However, studies of such applications have varied widely in their methods and results, making it challenging to determine the overall role and usefulness of health IT in delivering this level of care.

## Purpose of Evidence Report

The purpose of this evidence report is to improve our understanding of the impact of health IT applications that address PCC. While the health care community has widely recognized the potential of health IT to enable PCC, to date no one has conducted a comprehensive evidence-based analysis of the effectiveness of health IT enabled PCC. In addition, we have yet to clearly identify barriers and facilitators that affect health IT’s ability to enable PCC. For this report, we reviewed the evidence regarding four specific Key Questions. The first Key Question focuses on the outcomes of health IT applications that address components of PCC, and how those outcomes vary by type of health IT application. The second Key Question focuses on identifying barriers and facilitators to the implementation of health IT applications that address PCC. The last two Key Questions focus on defining gaps in our knowledge about health IT applications that address PCC, and identifying their specific value to consumers, their families, clinicians, and developers of this technology. The target population of interest includes health care providers using health IT to deliver PCC. By addressing these questions in a systematic way, we sought to provide a comprehensive synthesis of the evidence on the effectiveness of using health IT in promote PCC. We hope this review will inform both the designers and adopters of health IT applications as well as health policy makers.

## Key Questions

Key Question 1. Are health IT applications that address one or more components of PCC effective in improving the following outcomes, and how do the outcomes vary by type of health IT application?

a. Health care process outcomes (e.g., receiving appropriate treatment)
b. Clinical outcomes for patients (including quality of life)
c. Intermediate outcomes (such as patients’ improved health knowledge, health behaviors and physiologic measures, patient satisfaction, and reduced costs)
d. Responsiveness to the needs and preferences of individual patients
e. Shared decisionmaking between patients, their families, and providers; patient-clinician communication; and access to medical information

Key Question 2. What are barriers or facilitators that clinicians, developers, patients and their families or caregivers encounter that may impact implementation and use of health IT applications to enable PCC?

Key Question 3. What knowledge or evidence deficits exist regarding needed information to support estimates of cost, benefit, impact, sustainability, and net value with regard to enabling PCC through health IT?

Key Question 4. What critical information regarding the impact of health IT applications implemented to enable PCC is needed to give consumers, their families, clinicians, and developers a clear understanding of the value proposition particular to them?