# Peer Reviewers

Tina Cheng, M.D., M.P.H.

Johns Hopkins University School of Medicine

Baltimore, MD

Paul Cleary, Ph.D.

Yale University School of Public Health

New Haven, CT

Ronald Epstein, M.D.

University of Rochester Medical Center

Rochester, NY

Don Steinwachs, Ph.D.

Johns Hopkins Bloomberg School of Public Health

Baltimore, MD

Michael Weiner, M.D.

Regenstrief Institute, Inc.

Indianapolis, IN