# Technical Expert Panel

Hilary Llewellyn-Thomas, Ph.D.

Dartmouth Medical School

Lebanon, NH

Dana Safran, Sc.D.

Tufts Medical Center

Boston, MA

Jonathan Wald, M.D., M.P.H.

Harvard Medical School

Boston, MA

Steven Waldren, M.D., M.S.

American Academy of Family Physicians

Leawood, KS

Yan Xiao, Ph.D.

University of Maryland, Baltimore

Baltimore, MD