# Discussion

Health information technology (health IT) is a rapidly expanding field that is changing the way health care is administered. With patient-centered care (PCC) emerging as the agreed-upon model for best practice by patients, providers, and family members, it’s not surprising that health IT’s impact on PCC is of great interest to many in the health care field. Yet, to date, there has not been a comprehensive study on how health IT enables PCC. This report does just this.

Our team has successfully identified 327 articles that contain data on this important topic. We tried to examine a comprehensive range of PCC outcome measures, and feel that the chosen parameters (processes outcomes; clinical outcomes; intermediate outcomes; responsiveness to the needs and preferences of individual patients; and shared decisionmaking between stakeholders, patient-clinician communication, and access to medical information) give us a clear view of how effective health IT is at enabling PCC. Similarly, we believe the health IT types we identified (care management tools, telehealth, personal health records/patient portals, secure electronic messaging, and shared decisionmaking) cover the full gammet of pertinent health IT applications relevant to PCC.

One major challenge we faced was the diverse study populations (varying from as few as a dozen patients to more than 1,000), varied settings, and wide range of interventions (delivered at system, provider, and patient levels), making it difficult to directly compare studies. However, regardless of the heterogeneous nature of the articles reviewed, we feel the data reviewed in this report clearly shows that health IT applications are successful at enabling PCC.

## Process Outcomes

After reviewing the 97 studies cited in this report, we found that diabetes mellitus, hypertension, congestive heart failure, cancer and asthma were the conditions the studies most commonly targeted (Table 5). In addition we found that process outcomes were clearly the most commonly addressed measure—among these process outcomes, the studies predominantly focused on adherence to standards of care for testing and treatment and use of health care resources (Tables 8–11). Studies cited telehealth applications and care management tools as the IT types that most commonly improved these outcomes. However, we also found that the other three types of health IT had a significant positive effect in the majority of studies (Table 6). Finally, we found that patient engagement in care, quality improvement, quality and safety, prevention and health promotion, and integrated care were the PCC components these studies most commonly addressed (Table 7).

After reviewing each of these articles, we concluded that process outcomes generally improve with health IT interventions that involve components of PCC. We found strong evidence of this in Filippi (2003),20 where a simple electronic reminder system helped increase by two-fold the likelihood that physicians would prescribe an antiplatelet drug to diabetes patients at high risk for cardiovascular disease. Similarly, in Murtaugh (2005)31, we saw how nurses who received electronic messages, prompts, and educational material, delivered significantly better and more comprehensive care to their patients with heart failure. In Jones (1999),46 cancer care patients who received a personalized “consultation” about their condition using a touch screen computer had considerably better knowledge about their condition and treatment than a group given a personalized consultation or booklets.

The large volume of data uncovered in this review provides a rather convincing argument supporting the use of health IT applications that address components of PCC as a method for improving process outcomes. Perhaps one reason for this is that, in general, Internet technologies often directly address the speed and accuracy of processes. Therefore, it’s not surprising that we should see this kind of result in health care.

## Clinical Outcomes

Ninty-two studies examined clinical outcomes in areas that employed health IT applications addressing components of PCC. Telehealth applications and care management tools were the health IT types most frequently associated with an improvement in clinical outcomes, but personal health records/patient portals and secure electronic messaging also produced significant improvement in at least one clinical outcome in most studies (Table 14). The studies we reviewed most commonly addressed the PCC components patient engagement in their care, quality improvement, quality and safety, and integrated care (Table 15). They most commonly targeted heart disease, diabetes, asthma, obesity, mental health, chronic obstructive pulmonary disease, and cancer (Table 13).

The study results overall suggest clinical outcomes generally improve with health IT interventions that have components of PCC. One clear example was Montori (2004),208 where using telehealth in diabetes care to send glucometer readings had a positive impact on mean HbA1c levels. In heart disease care, Feldman (2005)32 illustrated how recommendations and additional resources sent by email to nurses caring for the patients improved physical limitation, symptom domains, qualityoflife, social limitation, self-efficacy, and depression. Also, in cancer care, Ruland (2003)47 illustrated how a computer application resulted in significantly higher scores on symptom reporting.

Not all health IT applications studied provided a clear clinical improvement when compared with control groups. These conflicting results might be due to the relatively short duration of many of these studies—a direct product of the short history of health IT use. Future studies that span years instead of weeks or months may provide more conclusive data on the ability of health IT to enable PCC.

## Intermediate Outcomes

We found 87 studies that addressed the effects of health IT applications that address components of PCC on intermediate outcomes. The studies most frequently reported telehealth applications as having the most significant positive effect on intermediate outcomes, but less than half of the telehealth applications had a significant positive effect on an intermediate outcome (Table 20). Fewer studies reported personal health records/patient portals, secure electronic messaging, and shared decisionmaking tools as having a significant positive effect on intermediate outcomes, but most of those studies reported a positive effect on at least one intermediate outcome. The studies most commonly targeted telemonitoring systems, clinical decision aids, IT-guided self-management, IT-guided disease management, and computer-assisted self-care as PCC components (Table 23). They predominantly addressed the intermediate outcomes patient knowledge or behaviors and patient satisfaction (Tables 24–26). The studies predominantly targeted diabetes, heart disease, obesity, cancer, hypertension, and alcohol abuse (Table 22).

The study results suggested intermediate outcomes generally improve with health IT interventions that have components of PCC. Good examples of this are Homko (2007),203 where women with gestational diabetes felt a greater sense of self-efficacy when given access to a Web site established for documentation of glucose values and communication between the patient and the health care team. In Feldman (2005),32 heart disease patients had a higher quality of life score and better medication knowledge, diet, and weight monitoring as a result of an email reminder sent to their nurse highlighting six heart failure-specific clinical recommendations. In Gaertner (2004),256 patients suffering from chronic cancer pain had a higher level of satisfaction with an electronic version of a pain diary.

Not all of the articles reviewed provided convincing evidence that health IT applications that address components of PCC improved intermediate outcomes. However, similar to with clinical outcomes, it’s believed that as health IT becomes more common practice, the evidence supporting a positive effect on intermediate outcomes will be more consistent and abundant. It should also be noted that most of the data addressed these first three outcomes, process outcomes, clinical outcomes, and intermediate outcomes. The reason for this is two-fold. One, these outcomes are more easily assessed since they are more concrete in nature than the remaining two outcomes: responsiveness to the needs, preferences, and values of individual patients; and shared decisionmaking between patients, their families, and providers, patient-clinician communication, and access to medical information. Secondly, the success of health care is more often gauged by process measures, clinical measures and intermediate outcome measures. Since these measures are significant to health care—from the perspective of patients, providers, and administrators alike—the positive results may have a significant effect on encouraging more widespread implementation of health IT applications in the health care industry.

## Improved Responsiveness to the Needs, Preferences, and Values of Individual Patients

We found only 14 studies that directly examined the effect of health IT applications on responsiveness to the needs, preferences, and values of individual patients. Three of these studies related to cancer care (Table 28). There were too few studies to draw any conclusion about how the effects on these outcomes might vary by the type of health IT. The studies addressed the PCC components of patient satisfaction; quality of life; medication recognition and adherence; patient symptom recognition; patient knowledge; patient preferences for in-person or IT-based consultation; health care processes; and patient social, emotional, cognitive, and physical functioning (see Table 30).

With the small number of studies that addressed the effect of health IT applications on responsiveness to the needs, preferences, and values of individual patients, it’s difficult to make any significant conclusion about the effect of health IT on this important outcome. However, it is encouraging that the three articles addressing cancer reported a positive effect in this important outcome category. Taenzer (2000),216 provided patient-specific computerized quality of life information to clinic staff before an appointment in a lung cancer outpatient clinic resulting in a trend towards clinicians charting more concerns and taking more action with regard to these concerns. In Ruland (2003),47 cancer patients using a computerized decision support system reported that significantly more symptoms were addressed in patient consultations. In Frosch (2008),282 a patient decision support Web site was more effective at improving decision quality and prostate cancer knowledge and reducing decisional conflict than was guiding patients to public sources of information. Hopefully, these positive results will generate future studies on this important aspect of the use of health IT to deliver patient-centered care.

## Improved Shared Decisionmaking Between Patients, Their Families, and Providers; Patient-Clinician Communication; and Access to Medical Information

Twenty five studies reported on how health IT applications affected shared decisionmaking between patients, their families, and providers; patient-clinician communication; and access to medical information. The studies most frequently cited shared decisionmaking applications as the type of health IT having least one positive effect on shared decisionmaking or communication, and in most cases those studies reported having a statistically significant effect (Table 32). Although only four studies used care management tools to assess the impact on shared decisionmaking and communication, three of those studies reported at least one statistically significant positive outcome. The studies we reviewed most commonly addressed the PCC components quality and safety, patient engagement in care, and quality improvement (Table 34). These studies predominantly examined outcomes that included health care choices after exposure to health IT interventions, satisfaction with decisions, decisional conflict, and communication with providers (Tables 36–38). The studies most commonly targeted cardiovascular conditions, cancer, and hormone replacement therapy for perimenopausal and postmenopausal care (Table 33).

One of the studies that clearly showed improvements in these outcome areas was Gomez (2002),28 where a telehealth system to support diabetes monitoring increased communication significantly between providers and patients. Also, in Green (2008),56 home blood pressure monitoring, a secure patient Web site, and pharmacist care resulted in a higher frequency of communications between patient and pharmacist.

We were surprised to see so few studies related to this outcome, since it is intuitive to assume health IT would improve information sharing between stakeholders. Once again, as this field matures, we predict we will see more studies that show how health IT affects information sharing, decisionmaking, and access to medical information.

## Additional Observations

It is important to note that, among the articles we reviewed, often the health IT applications the researchers most commonly studied were not the ones that proved most effective. This is likely due to the fact that health IT is a relatively new field with little available data to guide usage. What might appear to be effective theoretically might not produce practical results. We also likely see this discrepancy because the decision to implement many of these applications was often made on an availability basis, rather than on a need basis. We believe that as health IT applications gain longevity and ubiquity, consistency and predictability will improve. In addition, we learned that an impact on some outcomes does not necessarily mean a positive impact on PCC. Equally important, an impact on the PCC outcomes does not necessarily translate into an improvement in clinical outcomes. This was the rationale for our analytical framework, which did not make too many assumptions about the relationships between the different types of outcomes.

## Barriers and Facilitators

We encountered a number of barriers to the use of health IT applications that enable PCC. We saw poor interface usability due to old age, low income, education, cognitive impairments, low computer literacy, and insufficient training. We also saw physicians who were concerned about potential more or new work, unfavorable workflow, and problems related to new system implementation—including the lack of adequate funding. Both patients and physicians worried about confidentiality of patient information. Other barriers cited in these articles were depersonalization, incompatibility with current health care, the need for standardization of health IT applications, and problems with reimbursement.

Some of the facilitators we saw were high rates of satisfaction with an application’s ease of use, perceived usefulness, and efficiency of use. We recognize the complexity of the satisfaction construct and that it can be gauged across various dimensions. However, in this review we used a less granular approach to assessing this concept due to significant heterogeneity of reviewed studies and approaches used for measuring satisfaction. A number of these studies also named availability of support, comfort in use, and site location as facilitators of health IT implementation and use. These results led us to conclude that health IT is in fact effective at enabling PCC and that although barriers do exist, they are not significant enough to discredit the benefits of health IT in enabling PCC. Furthermore, facilitators exist that help offset the barriers. Finally, we conclude that the results obtained in this study warrant further research on how to address the barriers and promote the facilitators in this emerging field.

## Limitations

Health IT clearly is an emerging field. As such, interested parties do not agree on the definitions and categorizations of its various components. We considered different options for classifying and including different types of health IT and could have focused narrowly only on studies of health IT applications that were reported as being designed specifically to improve PCC. But very few, if any, studies reported that they were designed to improve PCC as it is now being defined. Furthermore, the studies we examined varied greatly in the terminology they used to characterize the health IT applications, making it more challenging to assign applications to specific categories. Therefore, we decided to include any study of any health IT application that addressed one or more components of PCC. By using a scheme that included health types that were not necessarily developed specifically to improve PCC, we learned that system-level applications may have an important role in facilitating PCC even if they are not necessarily designed specifically with that in mind.

Another limitation of this review is the wide heterogeneity of included articles. This heterogeneity pertains not only to diversity of systems used (in terms of hardware and software) or settings, sample sizes and methods, but also the level of system implementation. Some studies focused on design implications, others on implementation challenges, formative versus summative evaluation, or iterative designs. These issues affect the study designs in a manner somewhat unique to health IT-related studies, where there is no clear definition of research phases as would be the case with pharmaceutical studies or interventions. We believe that this heterogeneity reflects the current trend of explosive expansion of health IT applications in various areas of health care delivery. Such heterogeneity prevented us from being able to carry out a meta-analysis since too few articles had fully comparable interventions with similar outcomes.

In addition to the heterogeneity of the subjects, the primary outcomes studied have been very diverse even in the framework of each key question. While real improvements in all outcomes are the ultimate goal, standardization of core outcomes pertinent to each key question may be helpful in future analyses.

Another limitation is that only a few studies have described the effects of health IT on cost and provider efficiency, and even fewer have done so in a high-quality fashion. Although cost was mentioned in a number of studies, the studies generally were not designed to systematically assess costs from a well-defined economic perspective. Without more demonstrations of health IT being at least cost- and time-neutral, improvements in health care processes may not be enough to justify their implementation.

Furthermore, in many of the trials, the primary outcomes studied have been clinical, not processes of care. While real improvements in patient outcomes are the ultimate goal, the sense from reviewing the literature is that effects on process outcomes were often an afterthought. The strongest studies describing effects on process outcomes were those whose primary endpoints were indeed process outcomes.

## Future Research Needs

A great deal of research is needed to address the evidence deficits we identified in our review of the literature for Key Question 3. Priority should be given to research that will provide the critical information regarding the impact of health IT applications implemented to enable PCC that will give consumers, their families, clinicians, and developers an understanding of the value proposition particular to them (as described in the results on Key Question 4).

Clearly, more research is needed to determine the extent to which health IT applications can improve clinical outcomes by promoting PCC. Particular attention needs to be given to studies that directly examine the effects of health IT applications on measures of PCC, including shared decisionmaking, patient-clinician communication, access to information, and responsiveness to the needs and preferences of individual patients.

There is also a need for categorical and mutually exclusive, standardized definitions of PCC-related study outcomes and health IT applications, so that meta-analyses and systematic reviews can provide practical and evidence-based guidance to health IT researchers and implementers. In particular, these studies should be designed with each type of outcome as a primary outcome, placing PCC at the center rather than the periphery of health IT interventions.

Future research should target the populations that have been under-studied, including the pediatric and elderly populations. We also need to better understand how patients with cognitive or physical impairments interact with health IT. More research is also needed to understand the impact that racial and ethnic backgrounds, education, and socioeconomic levels have on the effectiveness of health IT applications that address components of PCC.

With more care being delivered in the home and community-based settings, more research needs to be done to elucidate the impact of community, environment, and culture on the health care utilization and health outcomes associated with health IT. In addition, the needs, concerns and impact of health IT on formal and informal caregivers should be explored.

Few studies addressed cost or sustainability of health IT. These are clearly important areas of interest that will have enormous impact on the future success of the use of health IT to deliver patient-centered care and therefore need to be addressed and explored. Future research on the costs of health IT will need to take into consideration the specific economic perspective of stakeholders including patients, clinicians, health care providers, and health care insurers.

It also is important to study how to make decision support tools more efficient for providers. Significant effort is needed to improve the accuracy and dependability of high impact health IT tools that address components of PCC.

Other important areas of study are: developing integrative measures for gauging compliance of health IT applications with PCC principles, integrating PCC components into electronic health records used in routine clinical practice, and investigating how processes and outcomes interact when health IT supports PCC, and, finally, using principles of PCC in a systematic and comprehensive way to guide development of future health IT applications.

## Implications and Conclusions

This review provides a comprehensive overview of the current state-of-the art on health IT interventions involving components of PCC. We conclude that significant evidence exists confirming the positive impact on health care outcomes of health IT applications having PCC-related components. The evidence points to clinical areas in which health IT is most likely to foster PCC and yield clinical benefits, but the evidence is not strong enough to provide clear guidance to health care systems on how best to use health IT in promoting PCC system-wide. Much more research is needed, as indicated above, to determine the extent to which health IT interventions will enhance the delivery of PCC and improve clinical outcomes for patients with different types of clinical conditions. More research also is needed to give health care providers better information on how to weigh the value of health IT applications for promoting PCC relative to the investment of resources needed. To fully realize the potential for health IT applications to facilitate PCC, future research and development should incorporate the principles of PCC in a more systematic and comprehensive way. One way to advance efforts in this area would be to develop and use an integrative measure for assessing how well health IT applications address principles of PCC. With better assessments of how outcomes relate to the incorporation of principles of PCC into health IT applications, health care providers will be in a better position to select the health IT applications that provide the best value for promoting PCC and improving clinical outcomes.