# Evidence Tables

Evidence Table 1 Study characteristics of studies addressing health care process outcomes

Evidence Table 2 Participant characteristics of studies addressing healthcare process outcomes

Evidence Table 3 All outcomes of studies addressing healthcare process outcomes

Evidence Table 4 Outcomes related to diabetes mellitus in studies addressing healthcare process outcomes

Evidence Table 5 Outcomes related to heart disease in studies addressing healthcare process outcomes

Evidence Table 6 Outcomes related to cancer in studies addressing healthcare process outcomes

Evidence Table 7 Outcomes related to hypertension in studies addressing healthcare process outcomes

Evidence Table 8 Study characteristics of studies addressing clinical outcomes

Evidence Table 9 Participant characteristics of studies addressing clinical outcomes

Evidence Table 10 All outcomes of studies addressing clinical outcomes

Evidence Table 11 Outcomes related to diabetes mellitus in studies addressing clinical outcomes

Evidence Table 12 Outcomes related to heart disease in studies addressing clinical outcomes

Evidence Table 13 Outcomes related to cancer in studies addressing clinical outcomes

Evidence Table 14 Outcomes related to hypertension in studies addressing clinical outcomes

Evidence Table 15 Study characteristics of studies addressing intermediate outcomes

Evidence Table 16 Participant characteristics of studies addressing intermediate outcomes

Evidence Table 17 All outcomes of studies addressing intermediate outcomes

Evidence Table 18 Outcomes related to diabetes mellitus in studies addressing intermediate outcomes

Evidence Table 19 Outcomes related to heart disease in studies addressing intermediate outcomes

Evidence Table 20 Outcomes related to cancer in studies addressing intermediate outcomes

Evidence Table 21 Outcomes related to hypertension in studies addressing intermediate outcomes

Evidence Table 22 Study characteristics of studies addressing improving responsiveness to the needs and preferences of individual patients

Evidence Table 23 Participant characteristics of studies addressing improving responsiveness to the needs and preferences of individual patients

Evidence Table 24 All outcomes of studies addressing the responsiveness to the needs and preferences of individual patients

Evidence Table 25 Outcomes related to cancer in studies addressing improving responsiveness to the needs and preferences of individual patients

Evidence Table 26 Study characteristics of studies addressing provider patient communication

Evidence Table 27 Participant characteristics of studies related to shared decision-making between patients, their families, and providers, clinician communication, or providing patients and clinicians access to medical information

Evidence Table 28 All outcomes of studies addressing improving shared decision-making between the patient and clinician

Evidence Table 29 Outcomes related to diabetes mellitus in studies related to shared decision-making between patients, their families, and providers, clinician communication, or providing patients and clinicians access to medical information

Evidence Table 30 Outcomes related to heart disease in studies related to shared decision-making between patients, their families, and providers, clinician communication, or providing patients and clinicians access to medical information

Evidence Table 31 Outcomes related to cancer in studies related to shared decision-making between patients, their families, and providers, clinician communication, or providing patients and clinicians access to medical information

Evidence Table 32 Characteristics of studies addressing barriers, facilitators, and/or drivers to the use of health IT to implement patent-centered care

Evidence Table 33 Characteristics of patients in studies addressing barriers, facilitators, and/or drivers to the use of health IT to implement patent-centered care

## References

### Evidence Table 1 References

1 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
2 Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. [pmid: 17389290].
3 Baker AM, McCarthy B, Gurley VF, Yood MU. Influenza immunization in a managed care organization. J Gen Intern Med. 1998;13(7):469-75. [pmid: 9686713].
4 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
5 Bentz CJ, Bayley KB, Bonin KE, et al. Provider feedback to improve 5A’s tobacco cessation in primary care: a cluster randomized clinical trial. Nicotine Tob Res. 2007;9(3):341-9. [pmid: 17365766].
6 Bindels R, Hasman A, Kester AD, Talmon JL, De Clercq PA, Winkens RA. The efficacy of an automated feedback system for general practitioners. Inform Prim Care. 2003;11(2):69-74. [pmid: 14567873].
7 Bindels R, Hasman A, van Wersch JW, Talmon J, Winkens RA. Evaluation of an automated test ordering and feedback system for general practitioners in daily practice. Int J Med Inform. 2004;73(9–10):705-12. [pmid: 15325327].
8 Bowns IR, Collins K, Walters SJ, McDonagh AJ. Telemedicine in dermatology: a randomised controlled trial. Health Technol Assess. 2006;10(43):iii-iv. ix. xi. 1. 39. [pmid: 17049140].
9 Cannon DS, Allen SN. A comparison of the effects of computer and manual reminders on compliance with a mental health clinical practice guideline. J Am Med Inform Assoc. 2000;7(2):196-203. [pmid: 10730603].
10 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
11 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
12 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
13 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
14 Dykes PC, Carroll DL, Benoit A, et al. A randomized trial of standardized nursing patient assessment using wireless devices. AMIA ... Annual Symposium Proceedings / AMIA Symposium. AMIA Symposium. 2007:206-10. [pmid: 18693827].
15 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
16 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
17 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
18 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
19 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
20 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
21 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
22 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005;7(4):221-9. [pmid: 15834239].
23 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
24 Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
25 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
26 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
27 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
28 Hogg WE, Bass M, Calonge N, Crouch H, Satenstein G. Randomized controlled study of customized preventive medicine reminder letters in a community practice. Can Fam Physician. 1998;44:81-8. [pmid: 9481466].
29 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
30 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
31 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
32 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by off-line data analysis. Stud Health Technol Inform. 2004;107(Pt 1):135-9. [pmid: 15360790].
33 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
34 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
35 Lester WT, Grant R, Barnett GO, Chueh H. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809].
36 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav. 2006;9(5):603-7. [pmid: 17034328].
37 Linder JA, Rigotti NA, Schneider LI, Kelley JH, Brawarsky P, Haas JS. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. [pmid: 19398690].
38 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
39 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
40 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
41 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
42 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
43 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
44 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
45 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
46 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
47 Morgan GJ, Grant B, Craig B, Sands A, Casey F. Supporting families of critically ill children at home using videoconferencing. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):91-2. [pmid: 16036009].
48 Murray MD, Loos B, Tu W, Eckert GJ, Zhou XH, Tierney WM. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506].
49 Murtaugh CM, Pezzin LE, McDonald MV, Feldman PH, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res. 2005;40(3):849-64. [pmid: 15960694].
50 Nguyen BH, Nguyen KP, McPhee SJ, Nguyen AT, Tran DQ, Jenkins CN. Promoting cancer prevention activities among Vietnamese physicians in California. J Cancer Educ. 2000;15(2):82-5. [pmid: 10879896].
51 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
52 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
53 Overhage JM, Dexter PR, Perkins SM, et al. A randomized, controlled trial of clinical information shared from another institution. Ann Emerg Med. 2002;39(1):14-23. [pmid: 11782726].
54 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
55 Persell S, Denecke-Dattalo T, Dunham D, Baker D. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194].
56 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
57 Quinn P, Goka J, Richardson H. Assessment of an electronic daily diary in patients with overactive bladder. BJU Int. 2003;91(7):647-52. [pmid: 12699477].
58 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
59 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
60 Raebel MA, Carroll NM, Kelleher JA, Chester EA, Berga S, Magid DJ. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
61 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
62 Rhodes KV, Drum M, Anliker E, Frankel RM, Howes DS, Levinson W. Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Archives of Internal Medicine. 2006;166(10):1107-14. [pmid: 16717173].
63 Rollman BL, Hanusa BH, Lowe HJ, Gilbert T, Kapoor WN, Schulberg HC. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139].
64 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
65 Rothschild JM, McGurk S, Honour M, et al. Assessment of education and computerized decision support interventions for improving transfusion practice. Transfusion. 2007;47(2):228-39. [pmid: 17302768].
66 Roukema J, Steyerberg EW, van der Lei J, Moll HA. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. 2008;15(1):107-13. [pmid: 17947627].
67 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
68 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
69 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
70 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
71 Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-8. [pmid: 16776793].
72 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
73 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
74 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
75 Tamblyn R, Huang A, Taylor L, et al. A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc. 2008;15(4):430-8. [pmid: 18436904].
76 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-8. [pmid: 16565867].
77 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
78 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
79 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
80 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008;36(2):241-5.
81 van Wijk MA, van der Lei J, Mosseveld M, Bohnen AM, van Bemmel JH. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
82 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemedicine Journal and E-Health : the Official Journal of the American Telemedicine Association. 2008;14(8):753-61. [pmid: 18954244].
83 Walker I, Sigouin C, Sek J, et al. Comparing hand-held computers and paper diaries for haemophilia home therapy: a randomized trial. Haemophilia. 2004;10(6):698-704. [pmid: 15569164].
84 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. [pmid: 18373136].
85 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemedicine Journal and E-Health. 2002;8(3):313-21. [pmid: 12419025].
86 Wolfenden L, Wiggers J, Knight J, et al. Increasing smoking cessation care in a preoperative clinic: a randomized controlled trial. Preventive Medicine. 2005;41(1):284-90. [pmid: 15917023].
87 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].

### Evidence Table 2 Reference List

1 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
2 Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. [pmid: 17389290].
3 Baker AM, McCarthy B, Gurley VF, Yood MU. Influenza immunization in a managed care organization. J Gen Intern Med. 1998;13(7):469-75. [pmid: 9686713].
4 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
5 Bentz CJ, Bayley KB, Bonin KE, et al. Provider feedback to improve 5A’s tobacco cessation in primary care: a cluster randomized clinical trial. Nicotine Tob Res. 2007;9(3):341-9. [pmid: 17365766].
6 Bindels R, Hasman A, Kester AD, Talmon JL, De Clercq PA, Winkens RA. The efficacy of an automated feedback system for general practitioners. Inform Prim Care. 2003;11(2):69-74. [pmid: 14567873].
7 Bindels R, Hasman A, van Wersch JW, Talmon J, Winkens RA. Evaluation of an automated test ordering and feedback system for general practitioners in daily practice. Int J Med Inform. 2004;73(9–10):705-12. [pmid: 15325327].
8 Bowns IR, Collins K, Walters SJ, McDonagh AJ. Telemedicine in dermatology: a randomised controlled trial. Health Technol Assess. 2006;10(43):iii-iv. ix. xi. 1. 39. [pmid: 17049140].
9 Cannon DS, Allen SN. A comparison of the effects of computer and manual reminders on compliance with a mental health clinical practice guideline. J Am Med Inform Assoc. 2000;7(2):196-203. [pmid: 10730603].
10 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
11 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
12 De Las Cuevas C, Arredondo MT, Cabrera MF, Sulzenbacher H, Meise U. Randomized Clinical Trial of Telepsychiatry through Videoconference versus Face-to-Face Conventional Psychiatric Treatment. Telemedicine and E-Health. 2006;12(3):341-50. [pmid: 16796502].
13 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
14 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
15 Dykes PC, Carroll DL, Benoit A, et al. A randomized trial of standardized nursing patient assessment using wireless devices. AMIA ... Annual Symposium Proceedings / AMIA Symposium. AMIA Symposium. 2007:206-10. [pmid: 18693827].
16 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
17 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
18 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
19 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
20 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
21 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
22 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
23 Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. 2005;28(1):33-9. [pmid: 15616230].
24 Glassman PA, Belperio P, Lanto A, et al. The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc. 2007;14(4):424-31. [pmid: 17460134].
25 Goldman RD, Mehrotra S, Pinto TR, Mounstephen W. Follow-up after a pediatric emergency department visit: telephone versus e-mail?. Pediatrics. 2004;114(4):988-91. [pmid: 15466095].
26 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
27 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005;7(4):221-9. [pmid: 15834239].
28 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
29 Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
30 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
31 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
32 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
33 Hogg WE, Bass M, Calonge N, Crouch H, Satenstein G. Randomized controlled study of customized preventive medicine reminder letters in a community practice. Can Fam Physician. 1998;44:81-8. [pmid: 9481466].
34 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
35 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
36 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
37 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
38 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
39 Kattan M, Crain EF, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117(6):e1095-103. [pmid: 16740812].
40 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by off-line data analysis. Stud Health Technol Inform. 2004;107(Pt 1):135-9. [pmid: 15360790].
41 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
42 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
43 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
44 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
45 Lester WT, Grant R, Barnett GO, Chueh H. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809].
46 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav. 2006;9(5):603-7. [pmid: 17034328].
47 Linder JA, Rigotti NA, Schneider LI, Kelley JH, Brawarsky P, Haas JS. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. [pmid: 19398690].
48 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
49 Marks IM, Kenwright M, McDonough M, Whittaker M, Mataix-Cols D. Saving clinicians’ time by delegating routine aspects of therapy to a computer: a randomized controlled trial in phobia/panic disorder. Psychological Medicine. 2004;34(1):9-17. [pmid: 14971623].
50 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
51 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
52 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
53 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
54 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
55 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
56 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
57 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
58 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
59 Morgan GJ, Grant B, Craig B, Sands A, Casey F. Supporting families of critically ill children at home using videoconferencing. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):91-2. [pmid: 16036009].
60 Murray MD, Loos B, Tu W, Eckert GJ, Zhou XH, Tierney WM. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506].
61 Murtaugh CM, Pezzin LE, McDonald MV, Feldman PH, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res. 2005;40(3):849-64. [pmid: 15960694].
62 Nguyen BH, Nguyen KP, McPhee SJ, Nguyen AT, Tran DQ, Jenkins CN. Promoting cancer prevention activities among Vietnamese physicians in California. J Cancer Educ. 2000;15(2):82-5. [pmid: 10879896].
63 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
64 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
65 Overhage JM, Dexter PR, Perkins SM, et al. A randomized, controlled trial of clinical information shared from another institution. Ann Emerg Med. 2002;39(1):14-23. [pmid: 11782726].
66 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
67 Persell S, Denecke-Dattalo T, Dunham D, Baker D. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194].
68 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
69 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
70 Quinn P, Goka J, Richardson H. Assessment of an electronic daily diary in patients with overactive bladder. BJU Int. 2003;91(7):647-52. [pmid: 12699477].
71 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
72 Raebel MA, Chester EA, Newsom EE, et al. Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy. 2006;26(5):619-26. [pmid: 16637791].
73 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
74 Raebel MA, Carroll NM, Kelleher JA, Chester EA, Berga S, Magid DJ. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
75 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
76 Rhodes KV, Drum M, Anliker E, Frankel RM, Howes DS, Levinson W. Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Archives of Internal Medicine. 2006;166(10):1107-14. [pmid: 16717173].
77 Rollman BL, Hanusa BH, Lowe HJ, Gilbert T, Kapoor WN, Schulberg HC. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139].
78 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
79 Rothschild JM, McGurk S, Honour M, et al. Assessment of education and computerized decision support interventions for improving transfusion practice. Transfusion. 2007;47(2):228-39. [pmid: 17302768].
80 Roukema J, Steyerberg EW, van der Lei J, Moll HA. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. 2008;15(1):107-13. [pmid: 17947627].
81 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
82 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
83 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
84 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
85 Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-8. [pmid: 16776793].
86 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
87 Soopramanien A, Pain H, Stainthorpe A, Menarini M, Ventura M. Using telemedicine to provide post-discharge support for patients with spinal cord injuries. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):68-70. [pmid: 16036001].
88 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
89 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
90 Tamblyn R, Huang A, Taylor L, et al. A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc. 2008;15(4):430-8. [pmid: 18436904].
91 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-8. [pmid: 16565867].
92 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
93 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
94 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
95 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
96 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006;30(4):397-405.
97 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008;36(2):241-5.
98 Trief P, Morin P, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31.
99 Tsang MW, Mok M, Kam G, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. Journal of Telemedicine and Telecare. 2001;7(1):47-50. [pmid: 11265938].
100 van Wijk MA, van der Lei J, Mosseveld M, Bohnen AM, van Bemmel JH. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
101 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemedicine Journal and E-Health : the Official Journal of the American Telemedicine Association. 2008;14(8):753-61. [pmid: 18954244].
102 Walker I, Sigouin C, Sek J, et al. Comparing hand-held computers and paper diaries for haemophilia home therapy: a randomized trial. Haemophilia. 2004;10(6):698-704. [pmid: 15569164].
103 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. [pmid: 18373136].
104 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemedicine Journal and E-Health. 2002;8(3):313-21. [pmid: 12419025].
105 Wolfenden L, Wiggers J, Knight J, et al. Increasing smoking cessation care in a preoperative clinic: a randomized controlled trial. Preventive Medicine. 2005;41(1):284-90. [pmid: 15917023].
106 Yoon KH, Kim HS. A short message service by cellular phone in type 2 diabetic patients for 12 months. Diabetes Res Clin Pract. 2008;79(2):256-61. [pmid: 17988756].
107 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].

### Evidence Table 3 References

1 Baker AM, McCarthy B, Gurley VF, Yood MU. Influenza immunization in a managed care organization. J Gen Intern Med. 1998;13(7):469-75. [pmid: 9686713].
2 Bentz CJ, Bayley KB, Bonin KE, et al. Provider feedback to improve 5A’s tobacco cessation in primary care: a cluster randomized clinical trial. Nicotine Tob Res. 2007;9(3):341-9. [pmid: 17365766].
3 Bindels R, Hasman A, van Wersch JW, Talmon J, Winkens RA. Evaluation of an automated test ordering and feedback system for general practitioners in daily practice. Int J Med Inform. 2004;73(9–10):705-12. [pmid: 15325327].
4 Bowns IR, Collins K, Walters SJ, McDonagh AJ. Telemedicine in dermatology: a randomised controlled trial. Health Technol Assess. 2006;10(43):iii-iv. ix. xi. 1. 39. [pmid: 17049140].
5 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
6 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
7 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
8 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
9 Dykes PC, Carroll DL, Benoit A, et al. A randomized trial of standardized nursing patient assessment using wireless devices. AMIA ... Annual Symposium Proceedings / AMIA Symposium. AMIA Symposium. 2007:206-10. [pmid: 18693827].
10 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
11 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
12 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
13 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
14 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
15 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
16 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
17 Glassman PA, Belperio P, Lanto A, et al. The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc. 2007;14(4):424-31. [pmid: 17460134].
18 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
19 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005;7(4):221-9. [pmid: 15834239].
20 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
21 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
22 Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
23 Hassol A, Walker JM, Kidder D, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
24 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
25 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
26 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
27 Hogg WE, Bass M, Calonge N, Crouch H, Satenstein G. Randomized controlled study of customized preventive medicine reminder letters in a community practice. Can Fam Physician. 1998;44:81-8. [pmid: 9481466].
28 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
29 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
30 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
31 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
32 Kattan M, Crain EF, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117(6):e1095-103. [pmid: 16740812].
33 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by off-line data analysis. Stud Health Technol Inform. 2004;107(Pt 1):135-9. [pmid: 15360790].
34 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
35 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
36 Lester WT, Grant R, Barnett GO, Chueh H. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809].
37 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav. 2006;9(5):603-7. [pmid: 17034328].
38 Linder JA, Rigotti NA, Schneider LI, Kelley JH, Brawarsky P, Haas JS. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. [pmid: 19398690].
39 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
40 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
41 Madaras-Kelly KJ, Hannah EL, Bateman K, Samore MH. Experience with a clinical decision support system in community pharmacies to recommend narrow-spectrum antimicrobials, nonantimicrobial prescriptions, and OTC products to decrease broad-spectrum antimicrobial use. J Manag Care Pharm. 2006;12(5):390-7. [pmid: 16792446].
42 Marks IM, Kenwright M, McDonough M, Whittaker M, Mataix-Cols D. Saving clinicians’ time by delegating routine aspects of therapy to a computer: a randomized controlled trial in phobia/panic disorder. Psychological Medicine. 2004;34(1):9-17. [pmid: 14971623].
43 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
44 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
45 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
46 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
47 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
48 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
49 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
50 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
51 Morgan GJ, Grant B, Craig B, Sands A, Casey F. Supporting families of critically ill children at home using videoconferencing. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):91-2. [pmid: 16036009].
52 Murray MD, Loos B, Tu W, Eckert GJ, Zhou XH, Tierney WM. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506].
53 Murtaugh CM, Pezzin LE, McDonald MV, Feldman PH, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res. 2005;40(3):849-64. [pmid: 15960694].
54 Nguyen BH, Nguyen KP, McPhee SJ, Nguyen AT, Tran DQ, Jenkins CN. Promoting cancer prevention activities among Vietnamese physicians in California. J Cancer Educ. 2000;15(2):82-5. [pmid: 10879896].
55 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
56 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
57 Overhage JM, Dexter PR, Perkins SM, et al. A randomized, controlled trial of clinical information shared from another institution. Ann Emerg Med. 2002;39(1):14-23. [pmid: 11782726].
58 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
59 Persell S, Denecke-Dattalo T, Dunham D, Baker D. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194].
60 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
61 Quinn P, Goka J, Richardson H. Assessment of an electronic daily diary in patients with overactive bladder. BJU Int. 2003;91(7):647-52. [pmid: 12699477].
62 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
63 Raebel MA, Carroll NM, Kelleher JA, Chester EA, Berga S, Magid DJ. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
64 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
65 Rhodes KV, Drum M, Anliker E, Frankel RM, Howes DS, Levinson W. Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Archives of Internal Medicine. 2006;166(10):1107-14. [pmid: 16717173].
66 Rollman BL, Hanusa BH, Lowe HJ, Gilbert T, Kapoor WN, Schulberg HC. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139].
67 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
68 Rothschild JM, McGurk S, Honour M, et al. Assessment of education and computerized decision support interventions for improving transfusion practice. Transfusion. 2007;47(2):228-39. [pmid: 17302768].
69 Roukema J, Steyerberg EW, van der Lei J, Moll HA. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. 2008;15(1):107-13. [pmid: 17947627].
70 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
71 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
72 Santamore WP, Homko CJ, Kashem A, McConnell TR, Menapace FJ, Bove AA. Accuracy of blood pressure measurements transmitted through a telemedicine system in underserved populations. Telemed J E Health. 2008;14(4):333-8. [pmid: 18570561].
73 Scherr D, Kastner P, Kollmann A, et al. Effect of home-based telemonitoring using mobile phone technology on the outcome of heart failure patients after an episode of acute decompensation: randomized controlled trial. Journal of Medical Internet Research. 2009;11(3):e34. [pmid: 19687005].
74 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
75 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
76 Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-8. [pmid: 16776793].
77 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
78 Soopramanien A, Pain H, Stainthorpe A, Menarini M, Ventura M. Using telemedicine to provide post-discharge support for patients with spinal cord injuries. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):68-70. [pmid: 16036001].
79 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
80 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
81 Tamblyn R, Huang A, Taylor L, et al. A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc. 2008;15(4):430-8. [pmid: 18436904].
82 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-8. [pmid: 16565867].
83 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
84 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
85 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
86 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008;36(2):241-5.
87 van Wijk MA, van der Lei J, Mosseveld M, Bohnen AM, van Bemmel JH. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
88 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemedicine Journal and E-Health : the Official Journal of the American Telemedicine Association. 2008;14(8):753-61. [pmid: 18954244].
89 Walker I, Sigouin C, Sek J, et al. Comparing hand-held computers and paper diaries for haemophilia home therapy: a randomized trial. Haemophilia. 2004;10(6):698-704. [pmid: 15569164].
90 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. [pmid: 18373136].
91 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemedicine Journal and E-Health. 2002;8(3):313-21. [pmid: 12419025].
92 Wolfenden L, Wiggers J, Knight J, et al. Increasing smoking cessation care in a preoperative clinic: a randomized controlled trial. Preventive Medicine. 2005;41(1):284-90. [pmid: 15917023].
93 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].

### Evidence Table 4 References

1 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
2 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
3 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
4 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
5 Persell S, Denecke-Dattalo T, Dunham D, Baker D. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194].
6 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
7 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
8 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
9 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
10 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
11 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].

### Evidence Table 5 References

1 Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. [pmid: 17389290].
2 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
3 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
4 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
5 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
6 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
7 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
8 Murray MD, Loos B, Tu W, Eckert GJ, Zhou XH, Tierney WM. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506].
9 Murtaugh CM, Pezzin LE, McDonald MV, Feldman PH, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on nurse practices. Health Serv Res. 2005;40(3):849-64. [pmid: 15960694].
10 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
11 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
12 Scherr D, Kastner P, Kollmann A, et al. Effect of home-based telemonitoring using mobile phone technology on the outcome of heart failure patients after an episode of acute decompensation: randomized controlled trial. Journal of Medical Internet Research. 2009;11(3):e34. [pmid: 19687005].
13 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
14 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
15 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemedicine Journal and E-Health : the Official Journal of the American Telemedicine Association. 2008;14(8):753-61. [pmid: 18954244].

### Evidence Table 6 References

1 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
2 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
3 Nguyen BH, Nguyen KP, McPhee SJ, Nguyen AT, Tran DQ, Jenkins CN. Promoting cancer prevention activities among Vietnamese physicians in California. J Cancer Educ. 2000;15(2):82-5. [pmid: 10879896].
4 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].

### Evidence Table 7 Reference List

1 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
2 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
3 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
4 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
5 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
6 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
7 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
8 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
9 Santamore WP, Homko CJ, Kashem A, McConnell TR, Menapace FJ, Bove AA. Accuracy of blood pressure measurements transmitted through a telemedicine system in underserved populations. Telemed J E Health. 2008;14(4):333-8. [pmid: 18570561].

### Evidence Table 8 Reference List

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991].
2 Benhamou PY, Melki V, Boizel R, et al. One-year efficacy and safety of Web-based follow-up using cellular phone in type 1 diabetic patients under insulin pump therapy: the PumpNet study. Diabetes & Metabolism. 2007;33(3):220-6. [pmid: 17395516].
3 Berner ES, Houston TK, Ray MN, et al. Improving ambulatory prescribing safety with a handheld decision support system: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(2):171-9. [pmid: 16357350].
4 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
5 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111(3):368-77. [pmid: 15363881].
6 Cadario F, Binotti M, Brustia M, et al. Telecare for teenagers with type 1 diabetes: a trial. Minerva Pediatr. 2007;59(4):299-305. [pmid: 17947836].
7 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
8 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
9 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
10 East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc AMIA Symp. 1999:251-5. [pmid: 10566359].
11 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
12 Farmer AJ, Gibson OJ, Dudley C, et al. A randomized controlled trial of the effect of real-time telemedicine support on glycemic control in young adults with type 1 diabetes (ISRCTN 46889446). Diabetes Care. 2005;28(11):2697-702. [pmid: 16249542].
13 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
14 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
15 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
16 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
17 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
18 Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. 2005;28(1):33-9. [pmid: 15616230].
19 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
20 Glassman PA, Belperio P, Lanto A, et al. The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc. 2007;14(4):424-31. [pmid: 17460134].
21 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
22 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
23 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
24 Hansson L, Svensson B, Björkman T, et al. What works for whom in a computer-mediated communication intervention in community psychiatry? Moderators of outcome in a cluster randomized trial. Acta Psychiatrica Scandinavica. 2008;118(5):404-9. [pmid: 18759805].
25 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
26 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
27 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
28 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
29 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
30 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-68. [pmid: 17603828].
31 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
32 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
33 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
34 Kattan M, Crain EF, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117(6):e1095-103. [pmid: 16740812].
35 Kenwright M, Marks I, Graham C, Franses A, Mataix-Cols D. Brief scheduled phone support from a clinician to enhance computer-aided self-help for obsessive-compulsive disorder: randomized controlled trial. Journal of Clinical Psychology. 2005;61(12):1499-508. [pmid: 16173084].
36 Kerr J, Patrick K, Norman G, et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety. 2008;25(7):555-8. [pmid: 17557319].
37 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
38 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
39 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
40 Lester WT, Grant R, Barnett GO, Chueh H. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809].
41 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
42 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
43 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
44 Madsen LB, Kirkegaard P, Pedersen EB. Blood pressure control during telemonitoring of home blood pressure. A randomized controlled trial during 6 months. Blood Press. 2008;17(2):78-86. [pmid: 18568696].
45 McCowan C, Neville RG, Ricketts IW, Warner FC, Hoskins G, Thomas GE. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
46 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
47 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
48 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
49 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
50 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
51 Montori VM, Helgemoe PK, Guyatt GH, et al. Telecare for patients with type 1 diabetes and inadequate glycemic control: a randomized controlled trial and meta-analysis. Diabetes Care. 2004;27(5):1088-94. [pmid: 15111526].
52 Morgan GJ, Grant B, Craig B, Sands A, Casey F. Supporting families of critically ill children at home using videoconferencing. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):91-2. [pmid: 16036009].
53 Napolitano MA, Fotheringham M, Tate D, et al. Evaluation of an Internet-based physical activity intervention: A preliminary investigation. Annals of Behavioral Medicine. 2003;25(2):92-9. [pmid: 12704010].
54 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
55 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
56 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
57 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
58 Phillips VL, Vesmarovich S, Hauber R, Wiggers E, Egner A. Telehealth: reaching out to newly injured spinal cord patients. Public Health Reports (Washington, D.C.: 1974). 2001;116(Suppl 1):94-102.
59 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
60 Poller L, Keown M, Ibrahim S, et al. A multicentre randomised clinical endpoint study of PARMA 5 computer-assisted oral anticoagulant dosage. Br J Haematol. 2008;143(2):274-83. [pmid: 18759767].
61 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
62 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
63 Proudfoot J, Ryden C, Everitt B, et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46-54. [pmid: 15231555].
64 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
65 Raebel MA, Carroll NM, Kelleher JA, Chester EA, Berga S, Magid DJ. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
66 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
67 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
68 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
69 Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. 2009;169(8):771-80. [pmid: 19398689].
70 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
71 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
72 Soopramanien A, Pain H, Stainthorpe A, Menarini M, Ventura M. Using telemedicine to provide post-discharge support for patients with spinal cord injuries. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):68-70. [pmid: 16036001].
73 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
74 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
75 Tate DF, Wing RR, Winett RA. Using Internet technology to deliver a behavioral weight loss program. JAMA : the Journal of the American Medical Association. 2001;285(9):1172-7. [pmid: 11231746].
76 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166(15):1620-5. [pmid: 16908795].
77 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-8. [pmid: 16565867].
78 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
79 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
80 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
81 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
82 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
83 Trief P, Morin P, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31.
84 Verheijden M, Bakx JC, Akkermans R, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. 2004;6(4):e44. [pmid: 15631968].
85 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. [pmid: 18373136].
86 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231-43. [pmid: 16899804].
87 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial internet weight loss program. Obes Res. 2004;12(6):1011-8. [pmid: 15229342].

### Evidence Table 9 References

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991].
2 Benhamou PY, Melki V, Boizel R, et al. One-year efficacy and safety of Web-based follow-up using cellular phone in type 1 diabetic patients under insulin pump therapy: the PumpNet study. Diabetes & Metabolism. 2007;33(3):220-6. [pmid: 17395516].
3 Berner ES, Houston TK, Ray MN, et al. Improving ambulatory prescribing safety with a handheld decision support system: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(2):171-9. [pmid: 16357350].
4 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
5 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111(3):368-77. [pmid: 15363881].
6 Cadario F, Binotti M, Brustia M, et al. Telecare for teenagers with type 1 diabetes: a trial. Minerva Pediatr. 2007;59(4):299-305. [pmid: 17947836].
7 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
8 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
9 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
10 East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc AMIA Symp. 1999:251-5. [pmid: 10566359].
11 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
12 Farmer AJ, Gibson OJ, Dudley C, et al. A randomized controlled trial of the effect of real-time telemedicine support on glycemic control in young adults with type 1 diabetes (ISRCTN 46889446). Diabetes Care. 2005;28(11):2697-702. [pmid: 16249542].
13 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
14 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
15 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
16 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
17 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
18 Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. 2005;28(1):33-9. [pmid: 15616230].
19 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
20 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
21 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
22 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
23 Hansson L, Svensson B, Björkman T, et al. What works for whom in a computer-mediated communication intervention in community psychiatry? Moderators of outcome in a cluster randomized trial. Acta Psychiatrica Scandinavica. 2008;118(5):404-9. [pmid: 18759805].
24 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
25 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
26 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
27 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
28 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
29 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-68. [pmid: 17603828].
30 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
31 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
32 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
33 Kattan M, Crain EF, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117(6):e1095-103. [pmid: 16740812].
34 Kenwright M, Marks I, Graham C, Franses A, Mataix-Cols D. Brief scheduled phone support from a clinician to enhance computer-aided self-help for obsessive-compulsive disorder: randomized controlled trial. Journal of Clinical Psychology. 2005;61(12):1499-508. [pmid: 16173084].
35 Kerr J, Patrick K, Norman G, et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety. 2008;25(7):555-8. [pmid: 17557319].
36 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
37 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
38 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
39 Lester WT, Grant R, Barnett GO, Chueh H. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809].
40 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
41 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
42 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
43 Madsen LB, Kirkegaard P, Pedersen EB. Blood pressure control during telemonitoring of home blood pressure. A randomized controlled trial during 6 months. Blood Press. 2008;17(2):78-86. [pmid: 18568696].
44 McCowan C, Neville RG, Ricketts IW, Warner FC, Hoskins G, Thomas GE. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
45 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
46 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
47 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
48 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
49 Montori VM, Helgemoe PK, Guyatt GH, et al. Telecare for patients with type 1 diabetes and inadequate glycemic control: a randomized controlled trial and meta-analysis. Diabetes Care. 2004;27(5):1088-94. [pmid: 15111526].
50 Morgan GJ, Grant B, Craig B, Sands A, Casey F. Supporting families of critically ill children at home using videoconferencing. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):91-2. [pmid: 16036009].
51 Napolitano MA, Fotheringham M, Tate D, et al. Evaluation of an Internet-based physical activity intervention: A preliminary investigation. Annals of Behavioral Medicine. 2003;25(2):92-9. [pmid: 12704010].
52 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
53 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
54 Phillips VL, Vesmarovich S, Hauber R, Wiggers E, Egner A. Telehealth: reaching out to newly injured spinal cord patients. Public Health Reports (Washington, D.C.: 1974). 2001;116(Suppl 1):94-102.
55 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
56 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
57 Poller L, Keown M, Ibrahim S, et al. A multicentre randomised clinical endpoint study of PARMA 5 computer-assisted oral anticoagulant dosage. Br J Haematol. 2008;143(2):274-83. [pmid: 18759767].
58 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
59 Proudfoot J, Ryden C, Everitt B, et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46-54. [pmid: 15231555].
60 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
61 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
62 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
63 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
64 Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. 2009;169(8):771-80. [pmid: 19398689].
65 Soopramanien A, Pain H, Stainthorpe A, Menarini M, Ventura M. Using telemedicine to provide post-discharge support for patients with spinal cord injuries. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):68-70. [pmid: 16036001].
66 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
67 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
68 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
69 Tate DF, Wing RR, Winett RA. Using Internet technology to deliver a behavioral weight loss program. JAMA : the Journal of the American Medical Association. 2001;285(9):1172-7. [pmid: 11231746].
70 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166(15):1620-5. [pmid: 16908795].
71 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
72 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
73 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
74 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
75 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
76 Trief P, Morin P, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31.
77 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. [pmid: 18373136].
78 Glassman PA, Belperio P, Lanto A, et al. The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc. 2007;14(4):424-31. [pmid: 17460134].
79 Raebel MA, Carroll NM, Kelleher JA, Chester EA, Berga S, Magid DJ. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
80 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
81 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-8. [pmid: 16565867].
82 Verheijden M, Bakx JC, Akkermans R, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. 2004;6(4):e44. [pmid: 15631968].
83 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231-43. [pmid: 16899804].
84 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial internet weight loss program. Obes Res. 2004;12(6):1011-8. [pmid: 15229342].
85 Yoon KH, Kim HS. A short message service by cellular phone in type 2 diabetic patients for 12 months. Diabetes Res Clin Pract. 2008;79(2):256-61. [pmid: 17988756].

### Evidence Table 10 References

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991].
2 Benhamou PY, Melki V, Boizel R, et al. One-year efficacy and safety of Web-based follow-up using cellular phone in type 1 diabetic patients under insulin pump therapy: the PumpNet study. Diabetes & Metabolism. 2007;33(3):220-6. [pmid: 17395516].
3 Berner ES, Houston TK, Ray MN, et al. Improving ambulatory prescribing safety with a handheld decision support system: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(2):171-9. [pmid: 16357350].
4 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
5 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111(3):368-77. [pmid: 15363881].
6 Cadario F, Binotti M, Brustia M, et al. Telecare for teenagers with type 1 diabetes: a trial. Minerva Pediatr. 2007;59(4):299-305. [pmid: 17947836].
7 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
8 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
9 Deutscher D, Hart DL, Dickstein R, Horn SD, Gutvirtz M. Implementing an integrated electronic outcomes and electronic health record process to create a foundation for clinical practice improvement. Phys Ther. 2008;88(2):270-85. [pmid: 18042656].
10 East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc AMIA Symp. 1999:251-5. [pmid: 10566359].
11 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
12 Farmer AJ, Gibson OJ, Dudley C, et al. A randomized controlled trial of the effect of real-time telemedicine support on glycemic control in young adults with type 1 diabetes (ISRCTN 46889446). Diabetes Care. 2005;28(11):2697-702. [pmid: 16249542].
13 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
14 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
15 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
16 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
17 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
18 Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. 2005;28(1):33-9. [pmid: 15616230].
19 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
20 Glassman PA, Belperio P, Lanto A, et al. The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc. 2007;14(4):424-31. [pmid: 17460134].
21 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
22 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
23 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
24 Hansson L, Svensson B, Björkman T, et al. What works for whom in a computer-mediated communication intervention in community psychiatry? Moderators of outcome in a cluster randomized trial. Acta Psychiatrica Scandinavica. 2008;118(5):404-9. [pmid: 18759805].
25 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
26 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
27 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
28 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
29 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
30 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-68. [pmid: 17603828].
31 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
32 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
33 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
34 Kattan M, Crain EF, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117(6):e1095-103. [pmid: 16740812].
35 Kerr J, Patrick K, Norman G, et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety. 2008;25(7):555-8. [pmid: 17557319].
36 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
37 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
38 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
39 Lester WT, Grant R, Barnett GO, Chueh H. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809].
40 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
41 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
42 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
43 Madsen LB, Kirkegaard P, Pedersen EB. Blood pressure control during telemonitoring of home blood pressure. A randomized controlled trial during 6 months. Blood Press. 2008;17(2):78-86. [pmid: 18568696].
44 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
45 McCowan C, Neville RG, Ricketts IW, Warner FC, Hoskins G, Thomas GE. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
46 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
47 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
48 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
49 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
50 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
51 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
52 Montori VM, Helgemoe PK, Guyatt GH, et al. Telecare for patients with type 1 diabetes and inadequate glycemic control: a randomized controlled trial and meta-analysis. Diabetes Care. 2004;27(5):1088-94. [pmid: 15111526].
53 Morgan GJ, Grant B, Craig B, Sands A, Casey F. Supporting families of critically ill children at home using videoconferencing. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):91-2. [pmid: 16036009].
54 Napolitano MA, Fotheringham M, Tate D, et al. Evaluation of an Internet-based physical activity intervention: A preliminary investigation. Annals of Behavioral Medicine. 2003;25(2):92-9. [pmid: 12704010].
55 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
56 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
57 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
58 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
59 Phillips VL, Vesmarovich S, Hauber R, Wiggers E, Egner A. Telehealth: reaching out to newly injured spinal cord patients. Public Health Reports (Washington, D.C.: 1974). 2001;116(Suppl 1):94-102.
60 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
61 Poller L, Keown M, Ibrahim S, et al. A multicentre randomised clinical endpoint study of PARMA 5 computer-assisted oral anticoagulant dosage. Br J Haematol. 2008;143(2):274-83. [pmid: 18759767].
62 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
63 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
64 Proudfoot J, Ryden C, Everitt B, et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46-54. [pmid: 15231555].
65 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
66 Raebel MA, Carroll NM, Kelleher JA, Chester EA, Berga S, Magid DJ. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
67 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
68 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
69 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
70 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
71 Scherr D, Kastner P, Kollmann A, et al. Effect of home-based telemonitoring using mobile phone technology on the outcome of heart failure patients after an episode of acute decompensation: randomized controlled trial. Journal of Medical Internet Research. 2009;11(3):e34. [pmid: 19687005].
72 Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. 2009;169(8):771-80. [pmid: 19398689].
73 Shea S. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
74 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
75 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
76 Soopramanien A, Pain H, Stainthorpe A, Menarini M, Ventura M. Using telemedicine to provide post-discharge support for patients with spinal cord injuries. Journal of Telemedicine and Telecare. 2005;11(Suppl 1):68-70. [pmid: 16036001].
77 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
78 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
79 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
80 Tate DF, Wing RR, Winett RA. Using Internet technology to deliver a behavioral weight loss program. JAMA : the Journal of the American Medical Association. 2001;285(9):1172-7. [pmid: 11231746].
81 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166(15):1620-5. [pmid: 16908795].
82 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-8. [pmid: 16565867].
83 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
84 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
85 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
86 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
87 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
88 Verheijden M, Bakx JC, Akkermans R, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. 2004;6(4):e44. [pmid: 15631968].
89 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemedicine Journal and E-Health : the Official Journal of the American Telemedicine Association. 2008;14(8):753-61. [pmid: 18954244].
90 Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. [pmid: 18373136].
91 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231-43. [pmid: 16899804].
92 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial internet weight loss program. Obes Res. 2004;12(6):1011-8. [pmid: 15229342].
93 Yoon KH, Kim HS. A short message service by cellular phone in type 2 diabetic patients for 12 months. Diabetes Res Clin Pract. 2008;79(2):256-61. [pmid: 17988756].

### Evidence Table 11 References

1 Benhamou PY, Melki V, Boizel R, et al. One-year efficacy and safety of Web-based follow-up using cellular phone in type 1 diabetic patients under insulin pump therapy: the PumpNet study. Diabetes & Metabolism. 2007;33(3):220-6. [pmid: 17395516].
2 Cadario F, Binotti M, Brustia M, et al. Telecare for teenagers with type 1 diabetes: a trial. Minerva Pediatr. 2007;59(4):299-305. [pmid: 17947836].
3 Farmer AJ, Gibson OJ, Dudley C, et al. A randomized controlled trial of the effect of real-time telemedicine support on glycemic control in young adults with type 1 diabetes (ISRCTN 46889446). Diabetes Care. 2005;28(11):2697-702. [pmid: 16249542].
4 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
5 Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. 2005;28(1):33-9. [pmid: 15616230].
6 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
7 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
8 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
9 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
10 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
11 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
12 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
13 Montori VM, Helgemoe PK, Guyatt GH, et al. Telecare for patients with type 1 diabetes and inadequate glycemic control: a randomized controlled trial and meta-analysis. Diabetes Care. 2004;27(5):1088-94. [pmid: 15111526].
14 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
15 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
16 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
17 Ralston JD, Hirsch IB, Hoath J, Mullen M, Cheadle A, Goldberg HI. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
18 Shea S. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
19 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
20 Thomas KG, Thomas MR, Stroebel RJ, et al. Use of a registry-generated audit, feedback, and patient reminder intervention in an internal medicine resident clinic--a randomized trial. J Gen Intern Med. 2007;22(12):1740-4. [pmid: 17973175].
21 Yoon KH, Kim HS. A short message service by cellular phone in type 2 diabetic patients for 12 months. Diabetes Res Clin Pract. 2008;79(2):256-61. [pmid: 17988756].

### Evidence Table 12 References

1 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
2 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
3 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
4 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
5 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
6 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
7 Poller L, Keown M, Ibrahim S, et al. A multicentre randomised clinical endpoint study of PARMA 5 computer-assisted oral anticoagulant dosage. Br J Haematol. 2008;143(2):274-83. [pmid: 18759767].
8 Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430].
9 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
10 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
11 Scherr D, Kastner P, Kollmann A, et al. Effect of home-based telemonitoring using mobile phone technology on the outcome of heart failure patients after an episode of acute decompensation: randomized controlled trial. Journal of Medical Internet Research. 2009;11(3):e34. [pmid: 19687005].
12 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
13 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
14 Verheijden M, Bakx JC, Akkermans R, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. 2004;6(4):e44. [pmid: 15631968].
15 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemedicine Journal and E-Health : the Official Journal of the American Telemedicine Association. 2008;14(8):753-61. [pmid: 18954244].

### Evidence Table 13 References

1 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
2 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
3 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
4 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].

### Evidence Table 14 References

1 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
2 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
3 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
4 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
5 Madsen LB, Kirkegaard P, Pedersen EB. Blood pressure control during telemonitoring of home blood pressure. A randomized controlled trial during 6 months. Blood Press. 2008;17(2):78-86. [pmid: 18568696].
6 Mitchell E, Sullivan F, Watt G, Grimshaw JM, Donnan PT. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994].
7 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
8 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].

### Evidence Table 15 Reference List

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991].
2 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
3 Barak A, Bloch N. Factors Related to Perceived Helpfulness in Supporting Highly Distressed Individuals through an Online Support Chat. CyberPsychology & Behavior. 2006;9(1):60-8. [pmid: 16497119].
4 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
5 Beale I, Marin-Bowling V, Guthrie N, Kato P. Young cancer patients’ perceptions of a video game used to promote self care. International Electronic Journal of Health Education. 2006;9:202-12.
6 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
7 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111(3):368-77. [pmid: 15363881].
8 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
9 Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: a randomized controlled trial. Journal of Zhejiang University. Science. B. 2008;9(1):34-8. [pmid: 18196610].
10 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
11 Col NF, Ngo L, Fortin JM, Goldberg RJ, O’Connor AM. Can computerized decision support help patients make complex treatment decisions? A randomized controlled trial of an individualized menopause decision aid. Med Decis Making. 2007;27(5):585-98. [pmid: 17873260].
12 Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self-management tools for asthma--patients’ opinions and quality of data in a randomized crossover study. Stud Health Technol Inform. 2007;127:178-89. [pmid: 17901611].
13 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. 2008;17(3):182-99. [pmid: 18617707].
14 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
15 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
16 East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc AMIA Symp. 1999:251-5. [pmid: 10566359].
17 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
18 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
19 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
20 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
21 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
22 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: Results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
23 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
24 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
25 Glazebrook C, Garrud P, Avery A, Coupland C, Williams H. Impact of a multimedia intervention “Skinsafe” on patients’ knowledge and protective behaviors. Preventive Medicine. 2006;42(6):449-54. [pmid: 16580059].
26 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
27 Gray JE, Safran C, Davis RB, et al. Baby CareLink: using the internet and telemedicine to improve care for high-risk infants. Pediatrics. 2000;106(6):1318-24. [pmid: 11099583].
28 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
29 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
30 Helzer JE, Rose GL, Badger GJ, et al. Using interactive voice response to enhance brief alcohol intervention in primary care settings. Journal of Studies on Alcohol and Drugs. 2008;69(2):251-8. [pmid: 18299766].
31 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
32 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
33 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-68. [pmid: 17603828].
34 Japuntich SJ, Zehner ME, Smith SS, et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res. 2006;8(Suppl 1):S59-67. [pmid: 17491172].
35 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
36 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
37 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemedicine Journal and E-Health. 2004;10:S, 26-s-34.
38 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
39 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp. 2002:410-4. [pmid: 12463857].
40 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
41 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410-7. [pmid: 15500594].
42 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
43 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
44 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav. 2006;9(5):603-7. [pmid: 17034328].
45 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
46 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
47 Marceau LD, Link C, Jamison RN, Carolan S. Electronic diaries as a tool to improve pain management: is there any evidence?. Pain Med. 2007;8(Suppl 3):S101-9. [pmid: 17877520].
48 Marcus BH, Napolitano MA, King AC, et al. Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychology : Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(4):401-9.
49 Marks IM, Kenwright M, McDonough M, Whittaker M, Mataix-Cols D. Saving clinicians’ time by delegating routine aspects of therapy to a computer: a randomized controlled trial in phobia/panic disorder. Psychological Medicine. 2004;34(1):9-17. [pmid: 14971623].
50 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
51 Matheny ME, Gandhi TK, Orav EJ, et al. Impact of an automated test results management system on patients’ satisfaction about test result communication. Arch Intern Med. 2007;167(20):2233-9. [pmid: 17998497].
52 McDonald EM, Solomon B, Shields W, et al. Evaluation of kiosk-based tailoring to promote household safety behaviors in an urban pediatric primary care practice. Patient Education and Counseling. 2005;58(2):168-81. [pmid: 16009293].
53 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
54 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
55 Napolitano MA, Fotheringham M, Tate D, et al. Evaluation of an Internet-based physical activity intervention: A preliminary investigation. Annals of Behavioral Medicine. 2003;25(2):92-9. [pmid: 12704010].
56 Neumann T, Neuner B, Weiss-Gerlach E, et al. The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. The Journal of Trauma. 2006;61(4):805-14. [pmid: 17033544].
57 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
58 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
59 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
60 Patten CA, Croghan IT, Meis TM, et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns. 2006;64(1–3):249-58. [pmid: 16616449].
61 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
62 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
63 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
64 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
65 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
66 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
67 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
68 Santamore WP, Homko CJ, Kashem A, McConnell TR, Menapace FJ, Bove AA. Accuracy of blood pressure measurements transmitted through a telemedicine system in underserved populations. Telemed J E Health. 2008;14(4):333-8. [pmid: 18570561].
69 Saver BG, Gustafson D, Taylor TR, et al. A tale of two studies: The importance of setting, subjects and context in two randomized, controlled trials of a web-based decision support for perimenopausal and postmenopausal health decisions. Patient Education and Counseling. 2007;66(2):211-22. [pmid: 17317080].
70 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
71 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
72 Sevick MA, Zickmund S, Korytkowski M, et al. Design, feasibility, and acceptability of an intervention using personal digital assistant-based self-monitoring in managing type 2 diabetes. Contemp Clin Trials. 2008;29(3):396-409. [pmid: 17997364].
73 Shea S. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
74 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
75 Stevens J, Kelleher KJ, Gardner W, et al. Trial of computerized screening for adolescent behavioral concerns. Pediatrics. 2008;121(6):1099-105. [pmid: 18519478].
76 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
77 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
78 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166(15):1620-5. [pmid: 16908795].
79 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
80 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
81 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
82 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
83 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006;30(4):397-405.
84 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008;36(2):241-5.
85 Tuil WS, Verhaak CM, Braat DD, de Vries Robbe PF, Kremer JA. Empowering patients undergoing in vitro fertilization by providing Internet access to medical data. Fertil Steril. 2007;88(2):361-8. [pmid: 17416366].
86 Wakefield BJ, Bylund CL, Holman JE, et al. Nurse and patient communication profiles in a home-based telehealth intervention for heart failure management. Patient Education and Counseling. 2008;71(2):285-92. [pmid: 18337049].
87 Williams GC, Lynch M, Glasgow RE. Computer-assisted intervention improves patient-centered diabetes care by increasing autonomy support. Health Psychology : Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(6):728-34.
88 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231-43. [pmid: 16899804].
89 Winzelberg AJ, Eppstein D, Eldredge KL, et al. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol. 2000;68(2):346-50. [pmid: 10780136].
90 Woods KF, Kutlar A, Johnson JA, et al. Sickle cell telemedicine and standard clinical encounters: A comparison of patient satisfaction. Telemedicine Journal. 1999;5(4):349-56. [pmid: 10908450].
91 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: A randomized controlled evaluation. Health Promotion International. 2007;22(2):122-8. [pmid: 17355994].
92 Yeh Y-T, Liu C-T, Wu S-J, Lee TI. Assessment of user satisfaction with an internet-based integrated patient education system for diabetes management. 2008 10th IEEE Intl. Conf. on e-Health Networking, Applications and Service, HEALTHCOM 2008. July 07, 2008 – July 09, 2008. Singapore, Singapore. Inst. of Elec. and Elec. Eng. Computer Society. 2008:85-9.

### Evidence Table 16 Reference List

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991].
2 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
3 Barak A, Bloch N. Factors Related to Perceived Helpfulness in Supporting Highly Distressed Individuals through an Online Support Chat. CyberPsychology & Behavior. 2006;9(1):60-8. [pmid: 16497119].
4 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
5 Beale I, Marin-Bowling V, Guthrie N, Kato P. Young cancer patients’ perceptions of a video game used to promote self care. International Electronic Journal of Health Education. 2006;9:202-12.
6 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
7 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111(3):368-77. [pmid: 15363881].
8 Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self-management tools for asthma--patients’ opinions and quality of data in a randomized crossover study. Stud Health Technol Inform. 2007;127:178-89. [pmid: 17901611].
9 Col NF, Ngo L, Fortin JM, Goldberg RJ, O’Connor AM. Can computerized decision support help patients make complex treatment decisions? A randomized controlled trial of an individualized menopause decision aid. Med Decis Making. 2007;27(5):585-98. [pmid: 17873260].
10 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
11 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
12 Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: a randomized controlled trial. Journal of Zhejiang University. Science. B. 2008;9(1):34-8. [pmid: 18196610].
13 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
14 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
15 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. 2008;17(3):182-99. [pmid: 18617707].
16 East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc AMIA Symp. 1999:251-5. [pmid: 10566359].
17 Finch T, Mort M, May C, Mair F. Telecare: perspectives on the changing role of patients and citizens. J Telemed Telecare. 2005;11(Suppl 1):51-3. [pmid: 16035993].
18 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
19 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
20 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
21 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
22 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
23 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: Results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
24 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
25 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
26 Glazebrook C, Garrud P, Avery A, Coupland C, Williams H. Impact of a multimedia intervention “Skinsafe” on patients’ knowledge and protective behaviors. Preventive Medicine. 2006;42(6):449-54. [pmid: 16580059].
27 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
28 Graham ID, Logan J, Bennett CL, et al. Physicians’ intentions and use of three patient decision aids. BMC Med Inform Decis Mak. 2007;7:20. [pmid: 17617908].
29 Gray JE, Safran C, Davis RB, et al. Baby CareLink: using the internet and telemedicine to improve care for high-risk infants. Pediatrics. 2000;106(6):1318-24. [pmid: 11099583].
30 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
31 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
32 Hassol A, Walker JM, Kidder D, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
33 Helzer JE, Rose GL, Badger GJ, et al. Using interactive voice response to enhance brief alcohol intervention in primary care settings. Journal of Studies on Alcohol and Drugs. 2008;69(2):251-8. [pmid: 18299766].
34 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
35 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
36 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-68. [pmid: 17603828].
37 Japuntich SJ, Zehner ME, Smith SS, et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res. 2006;8(Suppl 1):S59-67. [pmid: 17491172].
38 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
39 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
40 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemedicine Journal and E-Health. 2004;10:S, 26-s-34.
41 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
42 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp. 2002:410-4. [pmid: 12463857].
43 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
44 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410-7. [pmid: 15500594].
45 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
46 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
47 Lieberman A, Adalist-Estrin A, Erinle O, Sloan N. On-site mental health care: a route to improving access to mental health services in an inner-city, adolescent medicine clinic. Child: Care, Health and Development. 2006;32(4):407-13.
48 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
49 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
50 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
51 Marceau LD, Link C, Jamison RN, Carolan S. Electronic diaries as a tool to improve pain management: is there any evidence?. Pain Med. 2007;8(Suppl 3):S101-9. [pmid: 17877520].
52 Marcus BH, Napolitano MA, King AC, et al. Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychology : Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(4):401-9.
53 Marks IM, Kenwright M, McDonough M, Whittaker M, Mataix-Cols D. Saving clinicians’ time by delegating routine aspects of therapy to a computer: a randomized controlled trial in phobia/panic disorder. Psychological Medicine. 2004;34(1):9-17. [pmid: 14971623].
54 Matheny ME, Gandhi TK, Orav EJ, et al. Impact of an automated test results management system on patients’ satisfaction about test result communication. Arch Intern Med. 2007;167(20):2233-9. [pmid: 17998497].
55 McDonald EM, Solomon B, Shields W, et al. Evaluation of kiosk-based tailoring to promote household safety behaviors in an urban pediatric primary care practice. Patient Education and Counseling. 2005;58(2):168-81. [pmid: 16009293].
56 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
57 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
58 Napolitano MA, Fotheringham M, Tate D, et al. Evaluation of an Internet-based physical activity intervention: A preliminary investigation. Annals of Behavioral Medicine. 2003;25(2):92-9. [pmid: 12704010].
59 Neumann T, Neuner B, Weiss-Gerlach E, et al. The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. The Journal of Trauma. 2006;61(4):805-14. [pmid: 17033544].
60 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
61 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
62 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
63 Patten CA, Croghan IT, Meis TM, et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns. 2006;64(1–3):249-58. [pmid: 16616449].
64 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
65 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
66 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
67 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
68 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
69 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
70 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
71 Santamore WP, Homko CJ, Kashem A, McConnell TR, Menapace FJ, Bove AA. Accuracy of blood pressure measurements transmitted through a telemedicine system in underserved populations. Telemed J E Health. 2008;14(4):333-8. [pmid: 18570561].
72 Saver BG, Gustafson D, Taylor TR, et al. A tale of two studies: The importance of setting, subjects and context in two randomized, controlled trials of a web-based decision support for perimenopausal and postmenopausal health decisions. Patient Education and Counseling. 2007;66(2):211-22. [pmid: 17317080].
73 Sevick MA, Zickmund S, Korytkowski M, et al. Design, feasibility, and acceptability of an intervention using personal digital assistant-based self-monitoring in managing type 2 diabetes. Contemp Clin Trials. 2008;29(3):396-409. [pmid: 17997364].
74 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
75 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
76 Shea S. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
77 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
78 Stevens J, Kelleher KJ, Gardner W, et al. Trial of computerized screening for adolescent behavioral concerns. Pediatrics. 2008;121(6):1099-105. [pmid: 18519478].
79 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
80 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
81 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166(15):1620-5. [pmid: 16908795].
82 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
83 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
84 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006;30(4):397-405.
85 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
86 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
87 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008;36(2):241-5.
88 Tuil WS, Verhaak CM, Braat DD, de Vries Robbe PF, Kremer JA. Empowering patients undergoing in vitro fertilization by providing Internet access to medical data. Fertil Steril. 2007;88(2):361-8. [pmid: 17416366].
89 Wakefield BJ, Bylund CL, Holman JE, et al. Nurse and patient communication profiles in a home-based telehealth intervention for heart failure management. Patient Education and Counseling. 2008;71(2):285-92. [pmid: 18337049].
90 Williams GC, Lynch M, Glasgow RE. Computer-assisted intervention improves patient-centered diabetes care by increasing autonomy support. Health Psychology : Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(6):728-34.
91 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231-43. [pmid: 16899804].
92 Winzelberg AJ, Eppstein D, Eldredge KL, et al. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol. 2000;68(2):346-50. [pmid: 10780136].
93 Woods KF, Kutlar A, Johnson JA, et al. Sickle cell telemedicine and standard clinical encounters: A comparison of patient satisfaction. Telemedicine Journal. 1999;5(4):349-56. [pmid: 10908450].
94 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: A randomized controlled evaluation. Health Promotion International. 2007;22(2):122-8. [pmid: 17355994].
95 Yeh Y-T, Liu C-T, Wu S-J, Lee TI. Assessment of user satisfaction with an internet-based integrated patient education system for diabetes management. 2008 10th IEEE Intl. Conf. on e-Health Networking, Applications and Service, HEALTHCOM 2008. July 07, 2008 – July 09, 2008. Singapore, Singapore. Inst. of Elec. and Elec. Eng. Computer Society. 2008:85-9.

### Evidence Table 17 References

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991].
2 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
3 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
4 Benhamou PY, Melki V, Boizel R, et al. One-year efficacy and safety of Web-based follow-up using cellular phone in type 1 diabetic patients under insulin pump therapy: the PumpNet study. Diabetes & Metabolism. 2007;33(3):220-6. [pmid: 17395516].
5 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
6 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111(3):368-77. [pmid: 15363881].
7 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. 2003;60(19):1976-81. [pmid: 14531243].
8 Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: a randomized controlled trial. Journal of Zhejiang University. Science. B. 2008;9(1):34-8. [pmid: 18196610].
9 Clark RA, Yallop JJ, Piterman L, et al. Adherence, adaptation and acceptance of elderly chronic heart failure patients to receiving healthcare via telephone-monitoring. European Journal of Heart Failure : Journal of the Working Group on Heart Failure of the European Society of Cardiology. 2007;9(11):1104-11.
10 Col NF, Ngo L, Fortin JM, Goldberg RJ, O’Connor AM. Can computerized decision support help patients make complex treatment decisions? A randomized controlled trial of an individualized menopause decision aid. Med Decis Making. 2007;27(5):585-98. [pmid: 17873260].
11 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. 2008;17(3):182-99. [pmid: 18617707].
12 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
13 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
14 East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc AMIA Symp. 1999:251-5. [pmid: 10566359].
15 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
16 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
17 Finch T, Mort M, May C, Mair F. Telecare: perspectives on the changing role of patients and citizens. J Telemed Telecare. 2005;11(Suppl 1):51-3. [pmid: 16035993].
18 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
19 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
20 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
21 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: Results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
22 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
23 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
24 Glazebrook C, Garrud P, Avery A, Coupland C, Williams H. Impact of a multimedia intervention “Skinsafe” on patients’ knowledge and protective behaviors. Preventive Medicine. 2006;42(6):449-54. [pmid: 16580059].
25 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
26 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
27 Gray JE, Safran C, Davis RB, et al. Baby CareLink: using the internet and telemedicine to improve care for high-risk infants. Pediatrics. 2000;106(6):1318-24. [pmid: 11099583].
28 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
29 Hassol A, Walker JM, Kidder D, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
30 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
31 Helzer JE, Rose GL, Badger GJ, et al. Using interactive voice response to enhance brief alcohol intervention in primary care settings. Journal of Studies on Alcohol and Drugs. 2008;69(2):251-8. [pmid: 18299766].
32 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
33 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
34 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-68. [pmid: 17603828].
35 Japuntich SJ, Zehner ME, Smith SS, et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res. 2006;8(Suppl 1):S59-67. [pmid: 17491172].
36 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
37 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
38 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemedicine Journal and E-Health. 2004;10:S, 26-s-34.
39 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. [pmid: 12612228].
40 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp. 2002:410-4. [pmid: 12463857].
41 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
42 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410-7. [pmid: 15500594].
43 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
44 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
45 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav. 2006;9(5):603-7. [pmid: 17034328].
46 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
47 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
48 Matheny ME, Gandhi TK, Orav EJ, et al. Impact of an automated test results management system on patients’ satisfaction about test result communication. Arch Intern Med. 2007;167(20):2233-9. [pmid: 17998497].
49 Marceau LD, Link C, Jamison RN, Carolan S. Electronic diaries as a tool to improve pain management: is there any evidence?. Pain Med. 2007;8(Suppl 3):S101-9. [pmid: 17877520].
50 Marcus BH, Napolitano MA, King AC, et al. Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychology : Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(4):401-9.
51 Marks IM, Kenwright M, McDonough M, Whittaker M, Mataix-Cols D. Saving clinicians’ time by delegating routine aspects of therapy to a computer: a randomized controlled trial in phobia/panic disorder. Psychological Medicine. 2004;34(1):9-17. [pmid: 14971623].
52 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
53 McDonald EM, Solomon B, Shields W, et al. Evaluation of kiosk-based tailoring to promote household safety behaviors in an urban pediatric primary care practice. Patient Education and Counseling. 2005;58(2):168-81. [pmid: 16009293].
54 Montgomery AA, Fahey T, Peters TJ, MacIntosh C, Sharp DJ. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
55 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
56 Napolitano MA, Fotheringham M, Tate D, et al. Evaluation of an Internet-based physical activity intervention: A preliminary investigation. Annals of Behavioral Medicine. 2003;25(2):92-9. [pmid: 12704010].
57 Neumann T, Neuner B, Weiss-Gerlach E, et al. The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. The Journal of Trauma. 2006;61(4):805-14. [pmid: 17033544].
58 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
59 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
60 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
61 Patten CA, Croghan IT, Meis TM, et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns. 2006;64(1–3):249-58. [pmid: 16616449].
62 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
63 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
64 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
65 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
66 Rinfret S, Lussier MT, Peirce A, et al. The impact of a multidisciplinary information technology-supported program on blood pressure control in primary care. Circulation. Cardiovascular Quality and Outcomes. 2009;2(3):170-7. [pmid: 20031834].
67 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
68 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
69 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
70 Santamore WP, Homko CJ, Kashem A, McConnell TR, Menapace FJ, Bove AA. Accuracy of blood pressure measurements transmitted through a telemedicine system in underserved populations. Telemed J E Health. 2008;14(4):333-8. [pmid: 18570561].
71 Saver BG, Gustafson D, Taylor TR, et al. A tale of two studies: The importance of setting, subjects and context in two randomized, controlled trials of a web-based decision support for perimenopausal and postmenopausal health decisions. Patient Education and Counseling. 2007;66(2):211-22. [pmid: 17317080].
72 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
73 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
74 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
75 Sevick MA, Zickmund S, Korytkowski M, et al. Design, feasibility, and acceptability of an intervention using personal digital assistant-based self-monitoring in managing type 2 diabetes. Contemp Clin Trials. 2008;29(3):396-409. [pmid: 17997364].
76 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
77 Stevens J, Kelleher KJ, Gardner W, et al. Trial of computerized screening for adolescent behavioral concerns. Pediatrics. 2008;121(6):1099-105. [pmid: 18519478].
78 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
79 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
80 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med. 2006;166(15):1620-5. [pmid: 16908795].
81 Taylor B, Dinh M, Kwok R, Dinh D, Chu M, Tang E. Electronic interface for emergency department management of asthma: a randomized control trial of clinician performance. Emerg Med Australas. 2008;20(1):38-44. [pmid: 18062784].
82 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
83 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
84 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
85 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008;36(2):241-5.
86 Tuil WS, Verhaak CM, Braat DD, de Vries Robbe PF, Kremer JA. Empowering patients undergoing in vitro fertilization by providing Internet access to medical data. Fertil Steril. 2007;88(2):361-8. [pmid: 17416366].
87 Wakefield BJ, Bylund CL, Holman JE, et al. Nurse and patient communication profiles in a home-based telehealth intervention for heart failure management. Patient Education and Counseling. 2008;71(2):285-92. [pmid: 18337049].
88 Williamson DA, Walden HM, White MA, et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 2006;14(7):1231-43. [pmid: 16899804].
89 Williams GC, Lynch M, Glasgow RE. Computer-assisted intervention improves patient-centered diabetes care by increasing autonomy support. Health Psychology : Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(6):728-34.
90 Winzelberg AJ, Eppstein D, Eldredge KL, et al. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol. 2000;68(2):346-50. [pmid: 10780136].
91 Woods KF, Kutlar A, Johnson JA, et al. Sickle cell telemedicine and standard clinical encounters: A comparison of patient satisfaction. Telemedicine Journal. 1999;5(4):349-56. [pmid: 10908450].
92 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: A randomized controlled evaluation. Health Promotion International. 2007;22(2):122-8. [pmid: 17355994].

### Evidence Table 18 Reference List

1 Benhamou PY, Melki V, Boizel R, et al. One-year efficacy and safety of Web-based follow-up using cellular phone in type 1 diabetic patients under insulin pump therapy: the PumpNet study. Diabetes & Metabolism. 2007;33(3):220-6. [pmid: 17395516].
2 Glasgow RE, Nutting PA, Toobert DJ, et al. Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illness. 2006;2(1):27-38. [pmid: 17175680].
3 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
4 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
5 Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. J Telemed Telecare. 2006;12(Suppl 1):13-5. [pmid: 16884565].
6 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
7 Laffel LM, Hsu WC, McGill JB, Meneghini L, Volkening LK. Continued use of an integrated meter with electronic logbook maintains improvements in glycemic control beyond a randomized, controlled trial. Diabetes Technol Ther. 2007;9(3):254-64. [pmid: 17561796].
8 Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
9 Sevick MA, Zickmund S, Korytkowski M, et al. Design, feasibility, and acceptability of an intervention using personal digital assistant-based self-monitoring in managing type 2 diabetes. Contemp Clin Trials. 2008;29(3):396-409. [pmid: 17997364].
10 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
11 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
12 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006;30(4):397-405.
13 Williams GC, Lynch M, Glasgow RE. Computer-assisted intervention improves patient-centered diabetes care by increasing autonomy support. Health Psychology : Official Journal of the Division of Health Psychology, American Psychological Association. 2007;26(6):728-34.

### Evidence Table 19 Reference List

1 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. 2008;17(3):182-99. [pmid: 18617707].
2 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
3 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Services Quarterly. 2003;22(1):1-20. [pmid: 12749524].
4 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
5 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
6 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].

### Evidence Table 20 Reference List

1 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
2 Gaertner J, Elsner F, Pollmann-Dahmen K, Radbruch L, Sabatowski R. Electronic pain diary: a randomized crossover study. J Pain Symptom Manage. 2004;28(3):259-67. [pmid: 15336338].
3 Glazebrook C, Garrud P, Avery A, Coupland C, Williams H. Impact of a multimedia intervention “Skinsafe” on patients’ knowledge and protective behaviors. Preventive Medicine. 2006;42(6):449-54. [pmid: 16580059].
4 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
5 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
6 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].

### Evidence Table 21 Reference List

1 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
2 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
3 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
4 Rinfret S, Lussier MT, Peirce A, et al. The impact of a multidisciplinary information technology-supported program on blood pressure control in primary care. Circulation. Cardiovascular Quality and Outcomes. 2009;2(3):170-7. [pmid: 20031834].
5 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
6 Santamore WP, Homko CJ, Kashem A, McConnell TR, Menapace FJ, Bove AA. Accuracy of blood pressure measurements transmitted through a telemedicine system in underserved populations. Telemed J E Health. 2008;14(4):333-8. [pmid: 18570561].

### Evidence Table 22 Reference List

1 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
2 Beale I, Marin-Bowling V, Guthrie N, Kato P. Young cancer patients’ perceptions of a video game used to promote self care. International Electronic Journal of Health Education. 2006;9:202-12.
3 Chu A, Huber J, Mastel-Smith B, Cesario S. “Partnering with Seniors for Better Health”: computer use and Internet health information retrieval among older adults in a low socioeconomic community”. Journal of the Medical Library Association : JMLA. 2009;97(1):12-20. [pmid: 19159002].
4 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
5 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
6 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
7 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: Results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
8 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
9 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
10 Kaufman D, Pevzner J, Hilliman C, et al. Technology topics. Redesigning a telehealth diabetes management program for a digital divide seniors population. Home Health Care Management & Practice. 2006;18(3):223-34.
11 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemedicine Journal and E-Health. 2004;10:S, 26-s-34.
12 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
13 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
14 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
15 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
16 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
17 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
18 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
19 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
20 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
21 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
22 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
23 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
24 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
25 Trief P, Morin P, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31.
26 Wakefield BJ, Bylund CL, Holman JE, et al. Nurse and patient communication profiles in a home-based telehealth intervention for heart failure management. Patient Education and Counseling. 2008;71(2):285-92. [pmid: 18337049].

### Evidence Table 23 Reference List

1 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
2 Beale I, Marin-Bowling V, Guthrie N, Kato P. Young cancer patients’ perceptions of a video game used to promote self care. International Electronic Journal of Health Education. 2006;9:202-12.
3 Chu A, Huber J, Mastel-Smith B, Cesario S. “Partnering with Seniors for Better Health”: computer use and Internet health information retrieval among older adults in a low socioeconomic community”. Journal of the Medical Library Association : JMLA. 2009;97(1):12-20. [pmid: 19159002].
4 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
5 Feldman PH, Murtaugh CM, Pezzin LE, McDonald MV, Peng TR. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695].
6 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
7 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: Results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
8 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
9 Hassol A, Walker JM, Kidder D, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
10 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
11 Kaufman D, Pevzner J, Hilliman C, et al. Technology topics. Redesigning a telehealth diabetes management program for a digital divide seniors population. Home Health Care Management & Practice. 2006;18(3):223-34.
12 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemedicine Journal and E-Health. 2004;10:S, 26-s-34.
13 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
14 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
15 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
16 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
17 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
18 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
19 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
20 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
21 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
22 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
23 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
24 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
25 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
26 Trief P, Morin P, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31.
27 Wakefield BJ, Bylund CL, Holman JE, et al. Nurse and patient communication profiles in a home-based telehealth intervention for heart failure management. Patient Education and Counseling. 2008;71(2):285-92. [pmid: 18337049].

### Evidence Table 24 Reference List

1 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
2 Chu A, Huber J, Mastel-Smith B, Cesario S. “Partnering with Seniors for Better Health”: computer use and Internet health information retrieval among older adults in a low socioeconomic community”. Journal of the Medical Library Association : JMLA. 2009;97(1):12-20. [pmid: 19159002].
3 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
4 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
5 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-73. [pmid: 11078048].
6 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: Results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
7 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
8 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
9 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
10 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
11 McDonald MV, Pezzin LE, Feldman PH, Murtaugh CM, Peng TR. Can just-in-time, evidence-based “reminders” improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750].
12 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
13 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
14 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
15 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
16 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
17 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
18 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
19 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].
20 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
21 Wakefield BJ, Bylund CL, Holman JE, et al. Nurse and patient communication profiles in a home-based telehealth intervention for heart failure management. Patient Education and Counseling. 2008;71(2):285-92. [pmid: 18337049].

### Evidence Table 25 Reference List

1 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
2 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
3 Taenzer P, Bultz BD, Carlson LE, et al. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [pmid: 10871716].

### Evidence Table 26 References

1 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
2 Chan EC, Vernon SW. Implementing an intervention to promote colon cancer screening through e-mail over the Internet: lessons learned from a pilot study. Medical Care. 2008;46(9 Suppl 1):S117-22. [pmid: 18725823].
3 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
4 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
5 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
6 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
7 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
8 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005;7(4):221-9. [pmid: 15834239].
9 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
10 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
11 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemedicine Journal and E-Health. 2004;10:S, 26-s-34.
12 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
13 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
14 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
15 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
16 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
17 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
18 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
19 Scherr D, Kastner P, Kollmann A, et al. Effect of home-based telemonitoring using mobile phone technology on the outcome of heart failure patients after an episode of acute decompensation: randomized controlled trial. Journal of Medical Internet Research. 2009;11(3):e34. [pmid: 19687005].
20 Saver BG, Gustafson D, Taylor TR, et al. A tale of two studies: The importance of setting, subjects and context in two randomized, controlled trials of a web-based decision support for perimenopausal and postmenopausal health decisions. Patient Education and Counseling. 2007;66(2):211-22. [pmid: 17317080].
21 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
22 Schifferdecker KE, Reed VA, Homa K. A training intervention to improve information management in primary care. Fam Med. 2008;40(6):423-32. [pmid: 18773781].
23 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
24 Sciamanna CN, Nicholson RA, Lofland JH, Manocchia M, Mui S, Hartman CW. Effects of a website designed to improve the management of migraines. Headache: The Journal of Head and Face Pain. 2006;46(1):92-100.
25 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemedicine Journal and E-Health. 2002;8(3):313-21. [pmid: 12419025].

### Evidence Table 27 Reference List

1 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
2 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
3 Chan EC, Vernon SW. Implementing an intervention to promote colon cancer screening through e-mail over the Internet: lessons learned from a pilot study. Medical Care. 2008;46(9 Suppl 1):S117-22. [pmid: 18725823].
4 Chu A, Huber J, Mastel-Smith B, Cesario S. “Partnering with Seniors for Better Health”: computer use and Internet health information retrieval among older adults in a low socioeconomic community”. Journal of the Medical Library Association : JMLA. 2009;97(1):12-20. [pmid: 19159002].
5 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
6 Dobke MK, Bhavsar D, Gosman A, De Neve J, De Neve B. Pilot trial of telemedicine as a decision aid for patients with chronic wounds. Telemed J E Health. 2008;14(3):245-9. [pmid: 18570547].
7 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
8 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
9 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
10 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
11 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
12 Sciamanna CN, Nicholson RA, Lofland JH, Manocchia M, Mui S, Hartman CW. Effects of a website designed to improve the management of migraines. Headache: The Journal of Head and Face Pain. 2006;46(1):92-100.
13 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemedicine Journal and E-Health. 2002;8(3):313-21. [pmid: 12419025].

### Evidence Table 28 Reference List

1 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
2 Barnabei VM, O’Connor JJ, Nimphius NM, Vierkant RA, Eaker ED. The effects of a web-based tool on patient-provider communication and satisfaction with hormone therapy: a randomized evaluation. J Womens Health (Larchmt). 2008;17(1):147-58. [pmid: 18240991].
3 Chan EC, Vernon SW. Implementing an intervention to promote colon cancer screening through e-mail over the Internet: lessons learned from a pilot study. Medical Care. 2008;46(9 Suppl 1):S117-22. [pmid: 18725823].
4 Chu A, Huber J, Mastel-Smith B, Cesario S. “Partnering with Seniors for Better Health”: computer use and Internet health information retrieval among older adults in a low socioeconomic community”. Journal of the Medical Library Association : JMLA. 2009;97(1):12-20. [pmid: 19159002].
5 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
6 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
7 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
8 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
9 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005;7(4):221-9. [pmid: 15834239].
10 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
11 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
12 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
13 Kuppermann M, Norton ME, Gates E, et al. Computerized prenatal genetic testing decision-assisting tool: a randomized controlled trial. Obstet Gynecol. 2009;113(1):53-63. [pmid: 19104360].
14 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-71. [pmid: 17063127].
15 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
16 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
17 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].
18 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
19 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
20 Saver BG, Gustafson D, Taylor TR, et al. A tale of two studies: The importance of setting, subjects and context in two randomized, controlled trials of a web-based decision support for perimenopausal and postmenopausal health decisions. Patient Education and Counseling. 2007;66(2):211-22. [pmid: 17317080].
21 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns. 2007;67(1–2):100-7. [pmid: 17400413].
22 Schifferdecker KE, Reed VA, Homa K. A training intervention to improve information management in primary care. Fam Med. 2008;40(6):423-32. [pmid: 18773781].
23 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
24 Sciamanna CN, Nicholson RA, Lofland JH, Manocchia M, Mui S, Hartman CW. Effects of a website designed to improve the management of migraines. Headache: The Journal of Head and Face Pain. 2006;46(1):92-100.
25 Whited JD, Hall RP, Foy ME, et al. Teledermatology’s impact on time to intervention among referrals to a dermatology consult service. Telemedicine Journal and E-Health. 2002;8(3):313-21. [pmid: 12419025].

### Evidence Table 29 Reference List

1 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].

### Evidence Table 30 Reference List

1 Fretheim A, Oxman AD, Havelsrud K, Treweek S, Kristoffersen DT, Bjorndal A. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
2 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
3 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
4 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805].
5 McCrossan B, Morgan G, Grant B, Sands A, Craig B, Casey F. Assisting the transition from hospital to home for children with major congenital heart disease by telemedicine: a feasibility study and initial results. Medical Informatics and the Internet in Medicine. 2007;32(4):297-304. [pmid: 18072006].

### Evidence Table 31 Reference List

1 Chan EC, Vernon SW. Implementing an intervention to promote colon cancer screening through e-mail over the Internet: lessons learned from a pilot study. Medical Care. 2008;46(9 Suppl 1):S117-22. [pmid: 18725823].
2 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
3 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.

### Evidence Table 32 Reference List

1 Abdullah M, Theobald DE, Butler D, et al. Access to communication technologies in a sample of cancer patients: an urban and rural survey. BMC Cancer. 2005;5:18. [pmid: 15717933].
2 Abraham C, Rosenthal DA. Merging home and health via contemporary care delivery: program management insights on a home telehealth project. Comput Inform Nurs. 2008;26(5):273-81. [pmid: 18769182].
3 Ammenwerth E, Buchauer A, Bludau B, Haux R. Mobile information and communication tools in the hospital. Int J Med Inform. 2000;57(1):21-40. [pmid: 10708253].
4 Andreassen HK, Trondsen M, Kummervold PE, Gammon D, Hjortdahl P. Patients who use e-mediated communication with their doctor: new constructions of trust in the patient-doctor relationship. Qual Health Res. 2006;16(2):238-48. [pmid: 16394212].
5 Ash JS, Gorman PN, Lavelle M, et al. A cross-site qualitative study of physician order entry. J Am Med Inform Assoc. 2003;10(2):188-200. [pmid: 12595408].
6 Audet AM, Doty MM, Peugh J, Shamasdin J, Zapert K, Schoenbaum S. Information technologies: when will they make it into physicians’ black bags?. MedGenMed. 2004;6(4):2. [pmid: 15775829].
7 Avery AJ, Savelyich BS, Sheikh A, Morris CJ, Bowler I, Teasdale S. Improving general practice computer systems for patient safety: qualitative study of key stakeholders. Qual Saf Health Care. 2007;16(1):28-33. [pmid: 17301200].
8 Barak A, Bloch N. Factors Related to Perceived Helpfulness in Supporting Highly Distressed Individuals through an Online Support Chat. CyberPsychology & Behavior. 2006;9(1):60-8. [pmid: 16497119].
9 Bar-Lev S, Harrison MI. Negotiating time scripts during implementation of an electronic medical record. Health Care Manage Rev. 2006;31(1):11-7. [pmid: 16493268].
10 Beale I, Marin-Bowling V, Guthrie N, Kato P. Young cancer patients’ perceptions of a video game used to promote self care. International Electronic Journal of Health Education. 2006;9:202-12.
11 Benaroia M, Elinson R, Zarnke K. Patient-directed intelligent and interactive computer medical history-gathering systems: A utility and feasibility study in the emergency department. International Journal of Medical Informatics. 2007;76(4):283-8. [pmid: 16473548].
12 Bernhardt JM, Lariscy RAW, Parrott RL, Silk KJ, Felter EM. Perceived barriers to Internet-based health communication on human genetics. Journal of Health Communication. 2002;7(4):325-40. [pmid: 12356290].
13 Bernheim AM, Schaer BA, Kaufmann C, et al. Early clinical experience with CardioCard - a credit card-sized electronic patient record. Swiss Med Wkly. 2006;136(33–34):539-43. [pmid: 16983596].
14 Blanchfield BB, Grant RW, Estey GA, Chueh HC, Gazelle GS, Meigs JB. Cost of an informatics-based diabetes management program. Int J Technol Assess Health Care. 2006;22(2):249-54. [pmid: 16571201].
15 Bobrie G, Postel-Vinay N, Delonca J, Corvol P. Self-measurement and self-titration in hypertension: a pilot telemedicine study. Am J Hypertens. 2007;20(12):1314-20. [pmid: 18047923].
16 Bowns IR, Collins K, Walters SJ, McDonagh AJ. Telemedicine in dermatology: a randomised controlled trial. Health Technol Assess. 2006;10(43):iii-iv. ix. xi. 1. 39. [pmid: 17049140].
17 Bratton RL. Patient and physician satisfaction with telemedicine for monitoring vital signs. Journal of Telemedicine and Telecare. Place of Publication: London, UK. Country of Publication: UK. R. Soc. Med. Press Ltd. 2001:72-3.
18 Brebner JA, Brebner EM, Ruddick-Bracken H. Experience-based guidelines for the implementation of telemedicine services. J Telemed Telecare. 2005;11(Suppl 1):3-5. [pmid: 16035975].
19 Brooks RG, Menachemi N. Physicians’ use of email with patients: factors influencing electronic communication and adherence to best practices. J Med Internet Res. 2006;8(1):e2. [pmid: 16585026].
20 Campbell EM, Sittig DF, Ash JS, Guappone KP, Dykstra RH. Types of unintended consequences related to computerized provider order entry. J Am Med Inform Assoc. 2006;13(5):547-56. [pmid: 16799128].
21 Carroll C, Marsden P, Soden P, Naylor E, New J, Dornan T. Involving users in the design and usability evaluation of a clinical decision support system. Comput Methods Programs Biomed. 2002;69(2):123-35. [pmid: 12100792].
22 Carroll AE, Christakis DA. Pediatricians’ use of and attitudes about personal digital assistants. Pediatrics. 2004;113(2):238-42. [pmid: 14754932].
23 Carroll AE, Marrero DG, Downs SM. The HealthPia GlucoPack Diabetes phone: a usability study. Diabetes Technol Ther. 2007;9(2):158-64. [pmid: 17425441].
24 Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: a randomized controlled trial. Journal of Zhejiang University. Science. B. 2008;9(1):34-8. [pmid: 18196610].
25 Chinman M, Hassell J, Magnabosco J, Nowlin-Finch N, Marusak S, Young AS. The feasibility of computerized patient self-assessment at mental health clinics. Adm Policy Ment Health. 2007;34(4):401-9. [pmid: 17453332].
26 Christensen T, Grimsmo A. Instant availability of patient records, but diminished availability of patient information: a multi-method study of GP’s use of electronic patient records. BMC Med Inform Decis Mak. 2008;8:12. [pmid: 18373858].
27 Chu A, Huber J, Mastel-Smith B, Cesario S. “Partnering with Seniors for Better Health”: computer use and Internet health information retrieval among older adults in a low socioeconomic community”. Journal of the Medical Library Association : JMLA. 2009;97(1):12-20. [pmid: 19159002].
28 Citerio G, Stocchetti N, Cormio M, Beretta L. Neuro-Link, a computer-assisted database for head injury in intensive care. Acta Neurochir (Wien). 2000;142(7):769-76. [pmid: 10955671].
29 Crosson JC, Stroebel C, Scott JG, Stello B, Crabtree BF. Implementing an electronic medical record in a family medicine practice: communication, decision making, and conflict. Ann Fam Med. 2005;3(4):307-11. [pmid: 16046562].
30 Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self-management tools for asthma--patients’ opinions and quality of data in a randomized crossover study. Stud Health Technol Inform. 2007;127:178-89. [pmid: 17901611].
31 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. 2008;17(3):182-99. [pmid: 18617707].
32 Day M, Demiris G, Oliver DP, Courtney K, Hensel B. Exploring underutilization of videophones in hospice settings. Telemedicine and E-Health. 2007;13(1):25-31. [pmid: 17309351].
33 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
34 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
35 Demakis JG, Beauchamp C, Cull WL, et al. Improving residents’ compliance with standards of ambulatory care: results from the VA Cooperative Study on Computerized Reminders. JAMA. 2000;284(11):1411-6. [pmid: 10989404].
36 Demiris G, Edison K, Schopp LH. Shaping the future: needs and expectations of telehealth professionals. Telemedicine Journal and E-Health. 2004;10:S, 60-3.
37 Deutscher D, Hart DL, Dickstein R, Horn SD, Gutvirtz M. Implementing an integrated electronic outcomes and electronic health record process to create a foundation for clinical practice improvement. Phys Ther. 2008;88(2):270-85. [pmid: 18042656].
38 Dombkowski KJ, Leung SW, Clark SJ. Provider attitudes regarding use of an immunization information system to identify children with asthma for influenza vaccination. J Public Health Manag Pract. 2007;13(6):567-71. [pmid: 17984709].
39 Earnest MA, Ross SE, Wittevrongel L, Moore LA, Lin CT. Use of a patient-accessible electronic medical record in a practice for congestive heart failure: patient and physician experiences. J Am Med Inform Assoc. 2004;11(5):410-7. [pmid: 15187074].
40 Eminovic N, Wyatt JC, Tarpey AM, Murray G, Ingrams GJ. First evaluation of the NHS Direct Online Clinical Enquiry Service: A Nurse-led Web Chat Triage Service for the Public. Journal of Medical Internet Research. 2004;6(2).
41 Ertmer A, Uckert F. User acceptance of and satisfaction with a personal electronic health record. Stud Health Technol Inform. 2005;116:861-6. [pmid: 16160366].
42 Farmer A, Gibson O, Hayton P, et al. A real-time, mobile phone-based telemedicine system to support young adults with type 1 diabetes. Inform Prim Care. 2005;13(3):171-7. [pmid: 16259856].
43 Feil EG, Glasgow RE, Boles S, McKay HG. Who participates in internet-based self-management programs? A study among novice computer users in a primary care setting. 2000;26(5):806-11.
44 Feldman PH, McDonald MV. Conducting translation research in the home care setting: lessons from a just-in-time reminder study. Worldviews Evid Based Nurs. 2004;1(1):49-59. [pmid: 17147758].
45 Finch T, Mort M, May C, Mair F. Telecare: perspectives on the changing role of patients and citizens. J Telemed Telecare. 2005;11(Suppl 1):51-3. [pmid: 16035993].
46 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
47 Gagnon MP, Cloutier A, Fortin JP. Quebec population and telehealth: a survey on knowledge and perceptions. Telemed J E Health. 2004;10(1):3-12. [pmid: 15104910].
48 Gagnon MP, Lamothe L, Fortin JP, et al. Telehealth adoption in hospitals: an organisational perspective. J Health Organ Manag. 2005;19(1):32-56. [pmid: 15938601].
49 Garcia-Sanchez R. The patient’s perspective of computerised records: a questionnaire survey in primary care. Inform Prim Care. 2008;16(2):93-9. [pmid: 18713525].
50 Gardiner C, Williams K, Mackie IJ, Machin SJ, Cohen H. Can oral anticoagulation be managed using telemedicine and patient self-testing? A pilot study. Clin Lab Haematol. 2006;28(2):122-5. [pmid: 16630217].
51 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: Results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
52 Glazebrook C, Garrud P, Avery A, Coupland C, Williams H. Impact of a multimedia intervention “Skinsafe” on patients’ knowledge and protective behaviors. Preventive Medicine. 2006;42(6):449-54. [pmid: 16580059].
53 Goddard J, Alty A, Gillies A. A case study in mental health informatics: barriers and attitudes to information support for integrated care pathways. ITIN. 2001;13(3):12-5.
54 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
55 Gonzalez-Heydrich J, DeMaso DR, Irwin C, Steingard RJ, Kohane IS, Beardslee WR. Implementation of an electronic medical record system in a pediatric psychopharmacology program. Int J Med Inform. 2000;57(2–3):109-16. [pmid: 10961567].
56 Graham ID, Logan J, Bennett CL, et al. Physicians’ intentions and use of three patient decision aids. BMC Med Inform Decis Mak. 2007;7:20. [pmid: 17617908].
57 Griffiths L, Blignault I, Yellowlees P. Telemedicine as a means of delivering cognitive-behavioural therapy to rural and remote mental health clients. Journal of Telemedicine and Telecare. 2006;12(3):136-40. [pmid: 16638234].
58 Grossman JM, Bodenheimer TS, McKenzie K. Hospital-physician portals: the role of competition in driving clinical data exchange. Health Aff (Millwood). 2006;25(6):1629-36. [pmid: 17102188].
59 Grundmeier R, Johnson K. Housestaff attitudes toward computer-based clinical decision support. Proc AMIA Symp. 1999:266-70. [pmid: 10566362].
60 Gustafson DH, McTavish FM, Stengle W, et al. Use and Impact of eHealth System by Low-income Women With Breast Cancer. J Health Commun. 2005;10(Suppl 1):195-218. [pmid: 16377608].
61 Hailey D, Bulger T, Stayberg S, Urness D. The reality of applying an assessment guideline to a telemedicine mental health programme. J Telemed Telecare. 2003;9(6):344-8. discussion 348–9. [pmid: 14680519].
62 Halamka J, Aranow M, Ascenzo C, et al. E-Prescribing collaboration in Massachusetts: early experiences from regional prescribing projects. J Am Med Inform Assoc. 2006;13(3):239-44. [pmid: 16501174].
63 Han YY, Carcillo JA, Venkataraman ST, et al. Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system. Pediatrics. 2005;116(6):1506-12. [pmid: 16322178].
64 Harper DM, Moncur MM, Harper WH, Burke GC, Rasmussen CA, Mumford MC. The technical performance and clinical feasibility of telecolposcopy. J Fam Pract. 2000;49(7):623-7. [pmid: 10923572].
65 Hassol A, Walker JM, Kidder D, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
66 Hess R, Bryce CL, Paone S, et al. Exploring challenges and potentials of personal health records in diabetes self-management: implementation and initial assessment. Telemed J E Health. 2007;13(5):509-17. [pmid: 17999613].
67 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
68 Hibbert D, Mair FS, May CR, et al. Health professionals’ responses to the introduction of a home telehealth service. Journal of Telemedicine and Telecare. 2004;10(4):226-30. [pmid: 15273033].
69 Hillman JM, Given RS. Hospital implementation of computerized provider order entry systems: results from the 2003 leapfrog group quality and safety survey. J Healthc Inf Manag. 2005;19(4):55-65. [pmid: 16266033].
70 Hilty DM, Yellowlees PM, Cobb HC, Neufeld JD, Bourgeois JA. Use of Secure e-Mail and Telephone: Psychiatric Consultations to Accelerate Rural Health Service Delivery. Telemedicine and E-Health. 2006;12(4):490-5. [pmid: 16942422].
71 Hobbs J, Wald J, Jagannath YS, et al. Opportunities to enhance patient and physician e-mail contact. Int J Med Inform. 2003;70(1):1-9. [pmid: 12706177].
72 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
73 Hopp F Whitten P Subramanian U Woodbridge P Mackert M Lowery J Perspectives from the Veterans health administration about opportunities and barriers in telemedicine Journal of Telemedicine and Telecare 2006 12 8Z404 9
74 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
75 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
76 John R, Buschman P, Chaszar M, Honig J, Mendonca E, Bakken S. Development and evaluation of a PDA-based decision support system for pediatric depression screening. Stud Health Technol Inform. 2007;129(Pt 2):1382-6. [pmid: 17911940].
77 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
78 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
79 Kaufman D, Pevzner J, Hilliman C, et al. Technology topics. Redesigning a telehealth diabetes management program for a digital divide seniors population. Home Health Care Management & Practice. 2006;18(3):223-34.
80 Keeffe B, Subramanian U, Tierney WM, et al. Provider response to computer-based care suggestions for chronic heart failure. Med Care. 2005;43(5):461-5. [pmid: 15838410].
81 Kerr C, Murray E, Burns J, et al. Applying user-generated quality criteria to develop an Internet intervention for patients with heart disease. J Telemed Telecare. 2008;14(3):124-7. [pmid: 18430276].
82 Keselman A, Slaughter L, Smith CA, et al. Towards consumer-friendly PHRs: patients’ experience with reviewing their health records. AMIA Annu Symp Proc. 2007:399-403. [pmid: 18693866].
83 Kim MI, Johnson KB. Personal health records: evaluation of functionality and utility. J Am Med Inform Assoc. 2002;9(2):171-80. [pmid: 11861632].
84 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemedicine Journal and E-Health. 2004;10:S, 26-s-34.
85 King G, Richards H, Godden D. Adoption of telemedicine in Scottish remote and rural general practices: A qualitative study. Journal of Telemedicine and Telecare. 2007;13(8):382-6. [pmid: 18078547].
86 Kittler AF, Carlson GL, Harris C, et al. Primary care physician attitudes towards using a secure web-based portal designed to facilitate electronic communication with patients. Inform Prim Care. 2004;12(3):129-38. [pmid: 15606985].
87 Kleiner KD, Akers R, Burke BL, Werner EJ. Parent and physician attitudes regarding electronic communication in pediatric practices. Pediatrics. 2002;109(5):740-4. [pmid: 11986430].
88 Kreuter MW, Black WJ, Friend L, et al. Use of Computer Kiosks for Breast Cancer Education in Five Community Settings. Health Education & Behavior. 2006;33(5):625-42. [pmid: 16923835].
89 Krousel-Wood MA, Re RN, Abdoh A, et al. Patient and physician satisfaction in a clinical study of telemedicine in a hypertensive patient population. Journal of Telemedicine and Telecare. 2001;7(4):206-11. [pmid: 11506755].
90 Lahdenpera TS, Kyngas HA. Patients’ views about information technology in the treatment of hypertension. J Telemed Telecare. 2000;6(2):108-13. [pmid: 10824379].
91 Larcher B, Arisi E, Berloffa F, et al. Analysis of user-satisfaction with the use of a teleconsultation system in oncology. Med Inform Internet Med. 2003;28(2):73-84. [pmid: 14692585].
92 Lavanya J, Goh KW, Leow YH, et al. Distributed personal health information management system for dermatology at the homes for senior citizens. Conf Proc IEEE Eng Med Biol Soc. 2006;1:6312-5. [pmid: 17945953].
93 Lee TT, Yeh CH, Ho LH. Application of a computerized nursing care plan system in one hospital: experiences of ICU nurses in Taiwan. J Adv Nurs. 2002;39(1):61-7. [pmid: 12074752].
94 Levick D, Lukens HF, Stillman PL. You’ve led the horse to water, now how do you get him to drink: managing change and increasing utilization of computerized provider order entry. J Healthc Inf Manag. 2005;19(1):70-5. [pmid: 15682679].
95 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
96 Likourezos A, Chalfin DB, Murphy DG, Sommer B, Darcy K, Davidson SJ. Physician and nurse satisfaction with an Electronic Medical Record system. J Emerg Med. 2004;27(4):419-24. [pmid: 15498630].
97 Lindenauer PK, Ling D, Pekow PS, et al. Physician characteristics, attitudes, and use of computerized order entry. J Hosp Med. 2006;1(4):221-30. [pmid: 17219503].
98 Linder JA, Schnipper JL, Tsurikova R, Melnikas AJ, Volk LA, Middleton B. Barriers to electronic health record use during patient visits. AMIA Annu Symp Proc. 2006:499-503. [pmid: 17238391].
99 Lobach DF, Willis JM, Macri JM, Simo J, Anstrom KJ. Perceptions of Medicaid beneficiaries regarding the usefulness of accessing personal health information and services through a patient Internet portal. AMIA Annu Symp Proc. 2006:509-13. [pmid: 17238393].
100 Lober WB, Zierler B, Herbaugh A, et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc. 2006:514-8. [pmid: 17238394].
101 Lyons SS, Tripp-Reimer T, Sorofman BA, et al. VA QUERI informatics paper: information technology for clinical guideline implementation: perceptions of multidisciplinary stakeholders. J Am Med Inform Assoc. 2005;12(1):64-71. [pmid: 15492035].
102 Madaras-Kelly KJ, Hannah EL, Bateman K, Samore MH. Experience with a clinical decision support system in community pharmacies to recommend narrow-spectrum antimicrobials, nonantimicrobial prescriptions, and OTC products to decrease broad-spectrum antimicrobial use. J Manag Care Pharm. 2006;12(5):390-7. [pmid: 16792446].
103 Magnus M, Herwehe J, Andrews L, et al. Evaluating health information technology: provider satisfaction with an HIV-specific, electronic clinical management and reporting system. AIDS Patient Care & STDs. 2009;23(2):85-91. [pmid: 19133750].
104 Wang Maisie, Lau C, Matsen FAI, Kim Yongmin. Personal health information management system and its application in referral management. IEEE Transactions on Information Technology in Biomedicine. 2004;8(3):287-97. [pmid: 15484434].
105 Mangunkusumo RT, Brug J, Duisterhout JS, de Koning HJ, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Education Research. 2007;22(1):1-13. [pmid: 16714366].
106 Marceau LD, Link C, Jamison RN, Carolan S. Electronic diaries as a tool to improve pain management: is there any evidence?. Pain Med. 2007;8(Suppl 3):S101-9. [pmid: 17877520].
107 Margalit RS, Roter D, Dunevant MA, Larson S, Reis S. Electronic medical record use and physician-patient communication: an observational study of Israeli primary care encounters. Patient Educ Couns. 2006;61(1):134-41. [pmid: 16533682].
108 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
109 Masucci MM, Homko C, Santamore WP, et al. Cardiovascular disease prevention for underserved patients using the Internet: bridging the digital divide. Telemed J E Health. 2006;12(1):58-65. [pmid: 16478414].
110 Masys D, Baker D, Butros A, Cowles KE. Giving patients access to their medical records via the internet: the PCASSO experience. J Am Med Inform Assoc. 2002;9(2):181-91. [pmid: 11861633].
111 Maviglia SM, Zielstorff RD, Paterno M, Teich JM, Bates DW, Kuperman GJ. Automating complex guidelines for chronic disease: lessons learned. J Am Med Inform Assoc. 2003;10(2):154-65. [pmid: 12595405].
112 May JR. The electronic medical record: a valuable partner. J Med Pract Manage. 2005;21(2):100-2. [pmid: 16302440].
113 Mayo-Smith MF, Agrawal A. Factors associated with improved completion of computerized clinical reminders across a large healthcare system. Int J Med Inform. 2007;76(10):710-6. [pmid: 16935025].
114 McCowan C, Neville RG, Ricketts IW, Warner FC, Hoskins G, Thomas GE. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
115 McDonald CJ. Computerization can create safety hazards: a bar-coding near miss. Ann Intern Med. 2006;144(7):510-6. [pmid: 16585665].
116 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
117 McManus B. A move to electronic patient records in the community: a qualitative case study of a clinical data collection system, problems caused by inattention to users and human error. Top Health Inf Manage. 2000;20(4):23-37. [pmid: 10977140].
118 Mikulich VJ, Liu YC, Steinfeldt J, Schriger DL. Implementation of clinical guidelines through an electronic medical record: physician usage, satisfaction and assessment. Int J Med Inform. 2001;63(3):169-78. [pmid: 11502431].
119 Molenaar S, Sprangers M, Oort F, et al. Exploring the black box of a decision aid: what information do patients select from an interactive Cd-Rom on treatment options in breast cancer?. Patient Educ Couns. 2007;65(1):122-30. [pmid: 16945498].
120 Munir S, Boaden R. Patient empowerment and the electronic health record. Stud Health Technol Inform. 2001;84(Pt 1):663-5. [pmid: 11604820].
121 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
122 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
123 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
124 Pagliari C, Clark D, Hunter K, et al. DARTS 2000 online diabetes management system: formative evaluation in clinical practice. J Eval Clin Pract. 2003;9(4):391-400. [pmid: 14758961].
125 Paperny DM, Hedberg VA. Computer-assisted health counselor visits: a low-cost model for comprehensive adolescent preventive services (Brief record). Archives of Pediatrics and Adolescent Medicine. 1999;153(1):63-7. [pmid: 9895001].
126 Patt MR, Houston TK, Jenckes MW, Sands DZ, Ford DE. Doctors who are using e-mail with their patients: a qualitative exploration. Journal of Medical Internet Research. 2003;5(2).
127 Patterson ES, Nguyen AD, Halloran JP, Asch SM. Human factors barriers to the effective use of ten HIV clinical reminders. J Am Med Inform Assoc. 2004;11(1):50-9. [pmid: 14527974].
128 Patterson ES, Doebbeling BN, Fung CH, Militello L, Anders S, Asch SM. Identifying barriers to the effective use of clinical reminders: bootstrapping multiple methods. J Biomed Inform. 2005;38(3):189-99. [pmid: 15896692].
129 Paul DL, Pearlson KE, McDaniel RR Jr. Assessing technological barriers to telemedicine: technology-management implications. IEEE Transactions on Engineering Management. 1999;46(3):279-88.
130 Pelletier-Fleury N, Lanoe JL, Philippe C, Gagnadoux F, Rakotonanahary D, Fleury B. Economic studies and ‘technical’ evaluation of telemedicine: the case of telemonitored polysomnography. Health Policy. 1999;49(3):179-94. [pmid: 10827296].
131 Persell S, Denecke-Dattalo T, Dunham D, Baker D. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194].
132 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
133 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
134 Pillai A, Thomas SS, Garg M. The electronic immediate discharge document: experience from the South West of Scotland. Inform Prim Care. 2004;12(2):67-73. [pmid: 15319058].
135 Pinna GD, Maestri R, Andrews D, et al. Home telemonitoring of vital signs and cardiorespiratory signals in heart failure patients: system architecture and feasibility of the HHH model. Int J Cardiol. 2007;120(3):371-9. [pmid: 17189654].
136 Pizziferri L, Kittler AF, Volk LA, et al. Primary care physician time utilization before and after implementation of an electronic health record: a time-motion study. J Biomed Inform. 2005;38(3):176-88. [pmid: 15896691].
137 Poon EG, Blumenthal D, Jaggi T, Honour MM, Bates DW, Kaushal R. Overcoming the barriers to the implementing computerized physician order entry systems in US hospitals: perspectives from senior management. AMIA Annu Symp Proc. 2003;975.
138 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
139 Raebel MA, Chester EA, Newsom EE, et al. Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy. 2006;26(5):619-26. [pmid: 16637791].
140 Rahimpour M, Lovell NH, Celler BG, McCormick J. Patients’ perceptions of a home telecare system. International Journal of Medical Informatics. 2008;77(7):486-98. [pmid: 18023610].
141 Ralston JD, Rutter CM, Carrell D, Hecht J, Rubanowice D, Simon GE. Patient use of secure electronic messaging within a shared medical record: a cross-sectional study. J Gen Intern Med. 2009;24(3):349-55. [pmid: 19137379].
142 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
143 Rousseau N, McColl E, Newton J, Grimshaw J, Eccles M. Practice based, longitudinal, qualitative interview study of computerised evidence based guidelines in primary care. BMJ. 2003;326(7384):314. [pmid: 12574046].
144 Rubin MA, Bateman K, Donnelly S, et al. Use of a personal digital assistant for managing antibiotic prescribing for outpatient respiratory tract infections in rural communities. J Am Med Inform Assoc. 2006;13(6):627-34. [pmid: 16929045].
145 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
146 Ruland CM. A survey about the usefulness of computerized systems to support illness management in clinical practice. Int J Med Inform. 2004;73(11–12):797-805. [pmid: 15491930].
147 Saigh O, Triola MM, Link RN. Brief report: Failure of an electronic medical record tool to improve pain assessment documentation. J Gen Intern Med. 2006;21(2):185-8. [pmid: 16606379].
148 Saleem JJ, Patterson ES, Militello L, Render ML, Orshansky G, Asch SM. Exploring barriers and facilitators to the use of computerized clinical reminders. J Am Med Inform Assoc. 2005;12(4):438-47. [pmid: 15802482].
149 Samoutis G, Soteriades ES, Kounalakis DK, Zachariadou T, Philalithis A, Lionis C. Implementation of an electronic medical record system in previously computer-naive primary care centres: a pilot study from Cyprus. Inform Prim Care. 2007;15(4):207-16. [pmid: 18237477].
150 Schabetsberger T, Ammenwerth E, Breu R, et al. E-health approach to link-up actors in the health care system of Austria. Stud Health Technol Inform. 2006;124:415-20. [pmid: 17108555].
151 Schifferdecker KE, Reed VA, Homa K. A training intervention to improve information management in primary care. Fam Med. 2008;40(6):423-32. [pmid: 18773781].
152 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
153 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
154 Sequist TD, Cullen T, Hays H, Taualii MM, Simon SR, Bates DW. Implementation and use of an electronic health record within the Indian Health Service. J Am Med Inform Assoc. 2007;14(2):191-7. [pmid: 17213495].
155 Sevick MA, Zickmund S, Korytkowski M, et al. Design, feasibility, and acceptability of an intervention using personal digital assistant-based self-monitoring in managing type 2 diabetes. Contemp Clin Trials. 2008;29(3):396-409. [pmid: 17997364].
156 Shea S. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
157 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
158 Shore JH, Brooks E, Savin D, Orton H, Grigsby J, Manson SM. Acceptability of telepsychiatry in American Indians. Telemedicine and E-Health. 2008;14(5):461-6. [pmid: 18578681].
159 Shu K, Boyle D, Spurr C, et al. Comparison of time spent writing orders on paper with computerized physician order entry. Stud Health Technol Inform. 2001;84(Pt 2):1207-11. [pmid: 11604922].
160 Sicotte C, Denis JL, Lehoux P. The computer based patient record: a strategic issue in process innovation. J Med Syst. 1998;22(6):431-43. [pmid: 9871877].
161 Sicotte C, Pare G, Moreault MP, Lemay A, Valiquette L, Barkun J. Replacing an inpatient electronic medical record. Lessons learned from user satisfaction with the former system. Methods Inf Med. 2009;48(1):92-100. [pmid: 19151889].
162 Simon SR, Kaushal R, Cleary PD, et al. Physicians and electronic health records: a statewide survey. Arch Intern Med. 2007;167(5):507-12. [pmid: 17353500].
163 Simon SR, McCarthy ML, Kaushal R, et al. Electronic health records: which practices have them, and how are clinicians using them?. J Eval Clin Pract. 2008;14(1):43-7. [pmid: 18211642].
164 Sittig DF, Krall MA, Dykstra RH, Russell A, Chin HL. A survey of factors affecting clinician acceptance of clinical decision support. BMC Med Inform Decis Mak. 2006;6:6. [pmid: 16451720].
165 Smith K, Smith V, Krugman M, Oman K. Evaluating the impact of computerized clinical documentation. Comput Inform Nurs. 2005;23(3):132-8. [pmid: 15900170].
166 Smith GE, Lunde AM, Hathaway JC, Vickers KS. Telehealth home monitoring of solitary persons with mild dementia. American Journal of Alzheimer’s Disease and Other Dementias. 2007;22(1):20-6.
167 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
168 Tan EL, Stark H, Lowinger JS, Ringland C, Ward R, Pearson SA. Information sources used by New South Wales cancer clinicians: a qualitative study. Intern Med J. 2006;36(11):711-7. [pmid: 17040357].
169 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
170 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
171 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
172 Trief P, Morin P, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31.
173 Trivedi MH, Kern JK, Marcee A, et al. Development and implementation of computerized clinical guidelines: barriers and solutions. Methods Inf Med. 2002;41(5):435-42. [pmid: 12501817].
174 Trivedi MH, Daly EJ, Kern JK, Grannemann BD, Sunderajan P, Claassen CA. Barriers to implementation of a computerized decision support system for depression: an observational report on lessons learned in “real world” clinical settings. BMC Med Inform Decis Mak. 2009;9:6. [pmid: 19159458].
175 Tsang MW, Mok M, Kam G, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. Journal of Telemedicine and Telecare. 2001;7(1):47-50. [pmid: 11265938].
176 Tudiver F, Wolff LT, Morin PC, et al. Primary care providers’ perceptions of home diabetes telemedicine care in the IDEATel project. J Rural Health. 2007;23(1):55-61. [pmid: 17300479].
177 Tufano JT, Ralston JD, Martin DP. Providers’ experience with an organizational redesign initiative to promote patient-centered access: a qualitative study. J Gen Intern Med. 2008;23(11):1778-83. [pmid: 18769981].
178 Valdes I, Kibbe DC, Tolleson G, Kunik ME, Petersen LA. Barriers to proliferation of electronic medical records. Inform Prim Care. 2004;12(1):3-9. [pmid: 15140347].
179 van den Berg MH, van der Giesen FJ, van Zeben D, van Groenendael JH, Seys PE, Vliet Vlieland TP. Implementation of a physical activity intervention for people with rheumatoid arthritis: a case study. Musculoskeletal Care. 2008;6(2):69-85. [pmid: 18302159].
180 Van Den Brink JL, Moorman PW, De Boer MF, Pruyn JFA, Verwoerd CDA, Van Bemmel JH. Involving the patient: A prospective study on use, appreciation and effectiveness of an information system in head and neck cancer care. Supporting Communication in Health Care: International Journal of Medical Informatics. 2005;74(10):839-49.
181 van Wijk MA, van der Lei J, Mosseveld M, Bohnen AM, van Bemmel JH. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
182 Vanmeerbeek M. Exploitation of electronic medical records data in primary health care. Resistances and solutions. Study in eight Walloon health care centres. Stud Health Technol Inform. 2004;110:42-8. [pmid: 15853250].
183 Varonen H, Kortteisto T, Kaila M. What may help or hinder the implementation of computerized decision support systems (CDSSs): a focus group study with physicians. Fam Pract. 2008;25(3):162-7. [pmid: 18504253].
184 Velikova G, Brown JM, Smith AB, Selby PJ. Computer-based quality of life questionnaires may contribute to doctor-patient interactions in oncology. Br J Cancer. 2002;86(1):51-9. [pmid: 11857011].
185 Wade SL, Wolfe CR, Brown TM, Pestian JP. Can a Web-based family problem-solving intervention work for children with traumatic brain injury?. Rehabilitation Psychology. 2005;50(4):337-45.
186 Wang SJ, Middleton B, Prosser LA, et al. A cost-benefit analysis of electronic medical records in primary care. Am J Med. 2003;114(5):397-403. [pmid: 12714130].
187 Wang CJ, Patel MH, Schueth AJ, et al. Perceptions of Standards-based Electronic Prescribing Systems as Implemented in Outpatient Primary Care: A Physician Survey. J Am Med Inform Assoc. 2009.
188 Weingart SN, Rind D, Tofias Z, Sands DZ. Who uses the patient internet portal? The PatientSite experience. J Am Med Inform Assoc. 2006;13(1):91-5. [pmid: 16221943].
189 Weiss JB, Lorenzi NM. Online communication and support for cancer patients: a relationship-centric design framework. AMIA Annu Symp Proc. 2005:799-803. [pmid: 16779150].
190 West VL, Milio N. Organizational and environmental factors affecting the utilization of telemedicine in rural home healthcare. Home Health Care Serv Q. 2004;23(4):49-67. [pmid: 15778152].
191 Wilbright WA, Haun DE, Romano T, Krutzfeldt T, Fontenot CE, Nolan TE. Computer use in an urban university hospital: technology ahead of literacy. Comput Inform Nurs. 2006;24(1):37-43. [pmid: 16436911].
192 Winkelman WJ, Leonard KJ, Rossos PG. Patient-perceived usefulness of online electronic medical records: employing grounded theory in the development of information and communication technologies for use by patients living with chronic illness. J Am Med Inform Assoc. 2005;12(3):306-14. [pmid: 15684128].
193 Woods KF, Kutlar A, Johnson JA, et al. Sickle cell telemedicine and standard clinical encounters: A comparison of patient satisfaction. Telemedicine Journal. 1999;5(4):349-56. [pmid: 10908450].

### Evidence Table 33 Reference List

1 Abdullah M, Theobald DE, Butler D, et al. Access to communication technologies in a sample of cancer patients: an urban and rural survey. BMC Cancer. 2005;5:18. [pmid: 15717933].
2 Abraham C, Rosenthal DA. Merging home and health via contemporary care delivery: program management insights on a home telehealth project. Comput Inform Nurs. 2008;26(5):273-81. [pmid: 18769182].
3 Ammenwerth E, Buchauer A, Bludau B, Haux R. Mobile information and communication tools in the hospital. Int J Med Inform. 2000;57(1):21-40. [pmid: 10708253].
4 Andreassen HK, Trondsen M, Kummervold PE, Gammon D, Hjortdahl P. Patients who use e-mediated communication with their doctor: new constructions of trust in the patient-doctor relationship. Qual Health Res. 2006;16(2):238-48. [pmid: 16394212].
5 Ash JS, Gorman PN, Lavelle M, et al. A cross-site qualitative study of physician order entry. J Am Med Inform Assoc. 2003;10(2):188-200. [pmid: 12595408].
6 Audet AM, Doty MM, Peugh J, Shamasdin J, Zapert K, Schoenbaum S. Information technologies: when will they make it into physicians’ black bags?. MedGenMed. 2004;6(4):2. [pmid: 15775829].
7 Avery AJ, Savelyich BS, Sheikh A, Morris CJ, Bowler I, Teasdale S. Improving general practice computer systems for patient safety: qualitative study of key stakeholders. Qual Saf Health Care. 2007;16(1):28-33. [pmid: 17301200].
8 Barak A, Bloch N. Factors Related to Perceived Helpfulness in Supporting Highly Distressed Individuals through an Online Support Chat. CyberPsychology & Behavior. 2006;9(1):60-8. [pmid: 16497119].
9 Bar-Lev S, Harrison MI. Negotiating time scripts during implementation of an electronic medical record. Health Care Manage Rev. 2006;31(1):11-7. [pmid: 16493268].
10 Beale I, Marin-Bowling V, Guthrie N, Kato P. Young cancer patients’ perceptions of a video game used to promote self care. International Electronic Journal of Health Education. 2006;9:202-12.
11 Benaroia M, Elinson R, Zarnke K. Patient-directed intelligent and interactive computer medical history-gathering systems: A utility and feasibility study in the emergency department. International Journal of Medical Informatics. 2007;76(4):283-8. [pmid: 16473548].
12 Bernhardt JM, Lariscy RAW, Parrott RL, Silk KJ, Felter EM. Perceived barriers to Internet-based health communication on human genetics. Journal of Health Communication. 2002;7(4):325-40. [pmid: 12356290].
13 Bernheim AM, Schaer BA, Kaufmann C, et al. Early clinical experience with CardioCard - a credit card-sized electronic patient record. Swiss Med Wkly. 2006;136(33–34):539-43. [pmid: 16983596].
14 Blanchfield BB, Grant RW, Estey GA, Chueh HC, Gazelle GS, Meigs JB. Cost of an informatics-based diabetes management program. Int J Technol Assess Health Care. 2006;22(2):249-54. [pmid: 16571201].
15 Bobrie G, Postel-Vinay N, Delonca J, Corvol P. Self-measurement and self-titration in hypertension: a pilot telemedicine study. Am J Hypertens. 2007;20(12):1314-20. [pmid: 18047923].
16 Bowns IR, Collins K, Walters SJ, McDonagh AJ. Telemedicine in dermatology: a randomised controlled trial. Health Technol Assess. 2006;10(43):iii-iv. ix. xi. 1. 39. [pmid: 17049140].
17 Bratton RL. Patient and physician satisfaction with telemedicine for monitoring vital signs. Journal of Telemedicine and Telecare. Place of Publication: London, UK. Country of Publication: UK. R. Soc. Med. Press Ltd. 2001:72-3.
18 Brebner JA, Brebner EM, Ruddick-Bracken H. Experience-based guidelines for the implementation of telemedicine services. J Telemed Telecare. 2005;11(Suppl 1):3-5. [pmid: 16035975].
19 Brooks RG, Menachemi N. Physicians’ use of email with patients: factors influencing electronic communication and adherence to best practices. J Med Internet Res. 2006;8(1):e2. [pmid: 16585026].
20 Campbell EM, Sittig DF, Ash JS, Guappone KP, Dykstra RH. Types of unintended consequences related to computerized provider order entry. J Am Med Inform Assoc. 2006;13(5):547-56. [pmid: 16799128].
21 Carroll C, Marsden P, Soden P, Naylor E, New J, Dornan T. Involving users in the design and usability evaluation of a clinical decision support system. Comput Methods Programs Biomed. 2002;69(2):123-35. [pmid: 12100792].
22 Carroll AE, Christakis DA. Pediatricians’ use of and attitudes about personal digital assistants. Pediatrics. 2004;113(2):238-42. [pmid: 14754932].
23 Carroll AE, Marrero DG, Downs SM. The HealthPia GlucoPack Diabetes phone: a usability study. Diabetes Technol Ther. 2007;9(2):158-64. [pmid: 17425441].
24 Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: a randomized controlled trial. Journal of Zhejiang University. Science. B. 2008;9(1):34-8. [pmid: 18196610].
25 Chinman M, Hassell J, Magnabosco J, Nowlin-Finch N, Marusak S, Young AS. The feasibility of computerized patient self-assessment at mental health clinics. Adm Policy Ment Health. 2007;34(4):401-9. [pmid: 17453332].
26 Christensen T, Grimsmo A. Instant availability of patient records, but diminished availability of patient information: a multi-method study of GP’s use of electronic patient records. BMC Med Inform Decis Mak. 2008;8:12. [pmid: 18373858].
27 Chu A, Huber J, Mastel-Smith B, Cesario S. “Partnering with Seniors for Better Health”: computer use and Internet health information retrieval among older adults in a low socioeconomic community”. Journal of the Medical Library Association : JMLA. 2009;97(1):12-20. [pmid: 19159002].
28 Citerio G, Stocchetti N, Cormio M, Beretta L. Neuro-Link, a computer-assisted database for head injury in intensive care. Acta Neurochir (Wien). 2000;142(7):769-76. [pmid: 10955671].
29 Crosson JC, Stroebel C, Scott JG, Stello B, Crabtree BF. Implementing an electronic medical record in a family medicine practice: communication, decision making, and conflict. Ann Fam Med. 2005;3(4):307-11. [pmid: 16046562].
30 Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self-management tools for asthma--patients’ opinions and quality of data in a randomized crossover study. Stud Health Technol Inform. 2007;127:178-89. [pmid: 17901611].
31 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. 2008;17(3):182-99. [pmid: 18617707].
32 Day M, Demiris G, Oliver DP, Courtney K, Hensel B. Exploring underutilization of videophones in hospice settings. Telemedicine and E-Health. 2007;13(1):25-31. [pmid: 17309351].
33 de Toledo P, Jimenez S, del Pozo F, Roca J, Alonso A, Hernandez C. Telemedicine experience for chronic care in COPD. IEEE Trans Inf Technol Biomed. 2006;10(3):567-73. [pmid: 16871726].
34 Delichatsios H, Friedman R, Glanz K, et al. Randomized trial of a “talking computer” to improve adults’ eating habits. American Journal of Health Promotion. 2001;15(4):215-24. [pmid: 11349340].
35 Demakis JG, Beauchamp C, Cull WL, et al. Improving residents’ compliance with standards of ambulatory care: results from the VA Cooperative Study on Computerized Reminders. JAMA. 2000;284(11):1411-6. [pmid: 10989404].
36 Demiris G, Edison K, Schopp LH. Shaping the future: needs and expectations of telehealth professionals. Telemedicine Journal and E-Health. 2004;10:S, 60-3.
37 Deutscher D, Hart DL, Dickstein R, Horn SD, Gutvirtz M. Implementing an integrated electronic outcomes and electronic health record process to create a foundation for clinical practice improvement. Phys Ther. 2008;88(2):270-85. [pmid: 18042656].
38 Dombkowski KJ, Leung SW, Clark SJ. Provider attitudes regarding use of an immunization information system to identify children with asthma for influenza vaccination. J Public Health Manag Pract. 2007;13(6):567-71. [pmid: 17984709].
39 Earnest MA, Ross SE, Wittevrongel L, Moore LA, Lin CT. Use of a patient-accessible electronic medical record in a practice for congestive heart failure: patient and physician experiences. J Am Med Inform Assoc. 2004;11(5):410-7. [pmid: 15187074].
40 Eminovic N, Wyatt JC, Tarpey AM, Murray G, Ingrams GJ. First evaluation of the NHS Direct Online Clinical Enquiry Service: A Nurse-led Web Chat Triage Service for the Public. Journal of Medical Internet Research. 2004;6(2).
41 Ertmer A, Uckert F. User acceptance of and satisfaction with a personal electronic health record. Stud Health Technol Inform. 2005;116:861-6. [pmid: 16160366].
42 Farmer A, Gibson O, Hayton P, et al. A real-time, mobile phone-based telemedicine system to support young adults with type 1 diabetes. Inform Prim Care. 2005;13(3):171-7. [pmid: 16259856].
43 Feil EG, Glasgow RE, Boles S, McKay HG. Who participates in internet-based self-management programs? A study among novice computer users in a primary care setting. 2000;26(5):806-11.
44 Feldman PH, McDonald MV. Conducting translation research in the home care setting: lessons from a just-in-time reminder study. Worldviews Evid Based Nurs. 2004;1(1):49-59. [pmid: 17147758].
45 Finch T, Mort M, May C, Mair F. Telecare: perspectives on the changing role of patients and citizens. J Telemed Telecare. 2005;11(Suppl 1):51-3. [pmid: 16035993].
46 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
47 Gagnon MP, Cloutier A, Fortin JP. Quebec population and telehealth: a survey on knowledge and perceptions. Telemed J E Health. 2004;10(1):3-12. [pmid: 15104910].
48 Gagnon MP, Lamothe L, Fortin JP, et al. Telehealth adoption in hospitals: an organisational perspective. J Health Organ Manag. 2005;19(1):32-56. [pmid: 15938601].
49 Garcia-Sanchez R. The patient’s perspective of computerised records: a questionnaire survey in primary care. Inform Prim Care. 2008;16(2):93-9. [pmid: 18713525].
50 Gardiner C, Williams K, Mackie IJ, Machin SJ, Cohen H. Can oral anticoagulation be managed using telemedicine and patient self-testing? A pilot study. Clin Lab Haematol. 2006;28(2):122-5. [pmid: 16630217].
51 Gielen AC, McKenzie LB, McDonald EM, et al. Using a computer kiosk to promote child safety: Results of a randomized, controlled trial in an urban pediatric emergency department. Pediatrics. 2007;120(2):330-9. [pmid: 17671059].
52 Glazebrook C, Garrud P, Avery A, Coupland C, Williams H. Impact of a multimedia intervention “Skinsafe” on patients’ knowledge and protective behaviors. Preventive Medicine. 2006;42(6):449-54. [pmid: 16580059].
53 Goddard J, Alty A, Gillies A. A case study in mental health informatics: barriers and attitudes to information support for integrated care pathways. ITIN. 2001;13(3):12-5.
54 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69(2):163-77. [pmid: 12100795].
55 Gonzalez-Heydrich J, DeMaso DR, Irwin C, Steingard RJ, Kohane IS, Beardslee WR. Implementation of an electronic medical record system in a pediatric psychopharmacology program. Int J Med Inform. 2000;57(2–3):109-16. [pmid: 10961567].
56 Graham ID, Logan J, Bennett CL, et al. Physicians’ intentions and use of three patient decision aids. BMC Med Inform Decis Mak. 2007;7:20. [pmid: 17617908].
57 Griffiths L, Blignault I, Yellowlees P. Telemedicine as a means of delivering cognitive-behavioural therapy to rural and remote mental health clients. Journal of Telemedicine and Telecare. 2006;12(3):136-40. [pmid: 16638234].
58 Grossman JM, Bodenheimer TS, McKenzie K. Hospital-physician portals: the role of competition in driving clinical data exchange. Health Aff (Millwood). 2006;25(6):1629-36. [pmid: 17102188].
59 Grundmeier R, Johnson K. Housestaff attitudes toward computer-based clinical decision support. Proc AMIA Symp. 1999:266-70. [pmid: 10566362].
60 Gustafson DH, McTavish FM, Stengle W, et al. Use and Impact of eHealth System by Low-income Women With Breast Cancer. J Health Commun. 2005;10(Suppl 1):195-218. [pmid: 16377608].
61 Hailey D, Bulger T, Stayberg S, Urness D. The reality of applying an assessment guideline to a telemedicine mental health programme. J Telemed Telecare. 2003;9(6):344-8. discussion 348–9. [pmid: 14680519].
62 Halamka J, Aranow M, Ascenzo C, et al. E-Prescribing collaboration in Massachusetts: early experiences from regional prescribing projects. J Am Med Inform Assoc. 2006;13(3):239-44. [pmid: 16501174].
63 Han YY, Carcillo JA, Venkataraman ST, et al. Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system. Pediatrics. 2005;116(6):1506-12. [pmid: 16322178].
64 Harper DM, Moncur MM, Harper WH, Burke GC, Rasmussen CA, Mumford MC. The technical performance and clinical feasibility of telecolposcopy. J Fam Pract. 2000;49(7):623-7. [pmid: 10923572].
65 Hassol A, Walker JM, Kidder D, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
66 Hess R, Bryce CL, Paone S, et al. Exploring challenges and potentials of personal health records in diabetes self-management: implementation and initial assessment. Telemed J E Health. 2007;13(5):509-17. [pmid: 17999613].
67 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
68 Hibbert D, Mair FS, May CR, et al. Health professionals’ responses to the introduction of a home telehealth service. Journal of Telemedicine and Telecare. 2004;10(4):226-30. [pmid: 15273033].
69 Hillman JM, Given RS. Hospital implementation of computerized provider order entry systems: results from the 2003 leapfrog group quality and safety survey. J Healthc Inf Manag. 2005;19(4):55-65. [pmid: 16266033].
70 Hilty DM, Yellowlees PM, Cobb HC, Neufeld JD, Bourgeois JA. Use of Secure e-Mail and Telephone: Psychiatric Consultations to Accelerate Rural Health Service Delivery. Telemedicine and E-Health. 2006;12(4):490-5. [pmid: 16942422].
71 Hobbs J, Wald J, Jagannath YS, et al. Opportunities to enhance patient and physician e-mail contact. Int J Med Inform. 2003;70(1):1-9. [pmid: 12706177].
72 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. 2007;9(3):297-306. [pmid: 17561800].
73 Hopp F, Whitten P, Subramanian U, Woodbridge P, Mackert M, Lowery J. Perspectives from the Veterans health administration about opportunities and barriers in telemedicine. Journal of Telemedicine and Telecare. 2006;12(8):404-9. [pmid: 17227606].
74 Hunter CM, Peterson AL, Alvarez LM, et al. Weight management using the internet a randomized controlled trial. Am J Prev Med. 2008;34(2):119-26. [pmid: 18201641].
75 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
76 John R, Buschman P, Chaszar M, Honig J, Mendonca E, Bakken S. Development and evaluation of a PDA-based decision support system for pediatric depression screening. Stud Health Technol Inform. 2007;129(Pt 2):1382-6. [pmid: 17911940].
77 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-7. [pmid: 10550090].
78 Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891].
79 Kaufman D, Pevzner J, Hilliman C, et al. Technology topics. Redesigning a telehealth diabetes management program for a digital divide seniors population. Home Health Care Management & Practice. 2006;18(3):223-34.
80 Keeffe B, Subramanian U, Tierney WM, et al. Provider response to computer-based care suggestions for chronic heart failure. Med Care. 2005;43(5):461-5. [pmid: 15838410].
81 Kerr C, Murray E, Burns J, et al. Applying user-generated quality criteria to develop an Internet intervention for patients with heart disease. J Telemed Telecare. 2008;14(3):124-7. [pmid: 18430276].
82 Keselman A, Slaughter L, Smith CA, et al. Towards consumer-friendly PHRs: patients’ experience with reviewing their health records. AMIA Annu Symp Proc. 2007:399-403. [pmid: 18693866].
83 Kim MI, Johnson KB. Personal health records: evaluation of functionality and utility. J Am Med Inform Assoc. 2002;9(2):171-80. [pmid: 11861632].
84 Kim HM, Lowery JC, Hamill JB, Wilkins EG. Patient Attitudes Toward a Web-based System for Monitoring Chronic Wounds. Telemedicine Journal and E-Health. 2004;10:S, 26-s-34.
85 Kittler AF, Carlson GL, Harris C, et al. Primary care physician attitudes towards using a secure web-based portal designed to facilitate electronic communication with patients. Inform Prim Care. 2004;12(3):129-38. [pmid: 15606985].
86 Kleiner KD, Akers R, Burke BL, Werner EJ. Parent and physician attitudes regarding electronic communication in pediatric practices. Pediatrics. 2002;109(5):740-4. [pmid: 11986430].
87 Kreuter MW, Black WJ, Friend L, et al. Use of Computer Kiosks for Breast Cancer Education in Five Community Settings. Health Education & Behavior. 2006;33(5):625-42. [pmid: 16923835].
88 Krousel-Wood MA, Re RN, Abdoh A, et al. Patient and physician satisfaction in a clinical study of telemedicine in a hypertensive patient population. Journal of Telemedicine and Telecare. 2001;7(4):206-11. [pmid: 11506755].
89 Lahdenpera TS, Kyngas HA. Patients’ views about information technology in the treatment of hypertension. J Telemed Telecare. 2000;6(2):108-13. [pmid: 10824379].
90 Larcher B, Arisi E, Berloffa F, et al. Analysis of user-satisfaction with the use of a teleconsultation system in oncology. Med Inform Internet Med. 2003;28(2):73-84. [pmid: 14692585].
91 Lavanya J, Goh KW, Leow YH, et al. Distributed personal health information management system for dermatology at the homes for senior citizens. Conf Proc IEEE Eng Med Biol Soc. 2006;1:6312-5. [pmid: 17945953].
92 Lee TT, Yeh CH, Ho LH. Application of a computerized nursing care plan system in one hospital: experiences of ICU nurses in Taiwan. J Adv Nurs. 2002;39(1):61-7. [pmid: 12074752].
93 Levick D, Lukens HF, Stillman PL. You’ve led the horse to water, now how do you get him to drink: managing change and increasing utilization of computerized provider order entry. J Healthc Inf Manag. 2005;19(1):70-5. [pmid: 15682679].
94 Liaw ST, Radford AJ, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician. 1998;27(Suppl 1):S39-43. [pmid: 9503735].
95 Likourezos A, Chalfin DB, Murphy DG, Sommer B, Darcy K, Davidson SJ. Physician and nurse satisfaction with an Electronic Medical Record system. J Emerg Med. 2004;27(4):419-24. [pmid: 15498630].
96 Lindenauer PK, Ling D, Pekow PS, et al. Physician characteristics, attitudes, and use of computerized order entry. J Hosp Med. 2006;1(4):221-30. [pmid: 17219503].
97 Linder JA, Schnipper JL, Tsurikova R, Melnikas AJ, Volk LA, Middleton B. Barriers to electronic health record use during patient visits. AMIA Annu Symp Proc. 2006:499-503. [pmid: 17238391].
98 Lobach DF, Willis JM, Macri JM, Simo J, Anstrom KJ. Perceptions of Medicaid beneficiaries regarding the usefulness of accessing personal health information and services through a patient Internet portal. AMIA Annu Symp Proc. 2006:509-13. [pmid: 17238393].
99 Lober WB, Zierler B, Herbaugh A, et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc. 2006:514-8. [pmid: 17238394].
100 Lyons SS, Tripp-Reimer T, Sorofman BA, et al. VA QUERI informatics paper: information technology for clinical guideline implementation: perceptions of multidisciplinary stakeholders. J Am Med Inform Assoc. 2005;12(1):64-71. [pmid: 15492035].
101 Madaras-Kelly KJ, Hannah EL, Bateman K, Samore MH. Experience with a clinical decision support system in community pharmacies to recommend narrow-spectrum antimicrobials, nonantimicrobial prescriptions, and OTC products to decrease broad-spectrum antimicrobial use. J Manag Care Pharm. 2006;12(5):390-7. [pmid: 16792446].
102 Magnus M, Herwehe J, Andrews L, et al. Evaluating health information technology: provider satisfaction with an HIV-specific, electronic clinical management and reporting system. AIDS Patient Care & STDs. 2009;23(2):85-91. [pmid: 19133750].
103 Wang Maisie, Lau C, Matsen FAI, Kim Yongmin. Personal health information management system and its application in referral management. IEEE Transactions on Information Technology in Biomedicine. 2004;8(3):287-97. [pmid: 15484434].
104 Mangunkusumo RT, Brug J, Duisterhout JS, de Koning HJ, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Education Research. 2007;22(1):1-13. [pmid: 16714366].
105 Marceau LD, Link C, Jamison RN, Carolan S. Electronic diaries as a tool to improve pain management: is there any evidence?. Pain Med. 2007;8(Suppl 3):S101-9. [pmid: 17877520].
106 Margalit RS, Roter D, Dunevant MA, Larson S, Reis S. Electronic medical record use and physician-patient communication: an observational study of Israeli primary care encounters. Patient Educ Couns. 2006;61(1):134-41. [pmid: 16533682].
107 Maslin A, Baum M, Walker J, A’Hern R, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. NT Research. 1998;3(6):444-55.
108 Masucci MM, Homko C, Santamore WP, et al. Cardiovascular disease prevention for underserved patients using the Internet: bridging the digital divide. Telemed J E Health. 2006;12(1):58-65. [pmid: 16478414].
109 Masys D, Baker D, Butros A, Cowles KE. Giving patients access to their medical records via the internet: the PCASSO experience. J Am Med Inform Assoc. 2002;9(2):181-91. [pmid: 11861633].
110 Maviglia SM, Zielstorff RD, Paterno M, Teich JM, Bates DW, Kuperman GJ. Automating complex guidelines for chronic disease: lessons learned. J Am Med Inform Assoc. 2003;10(2):154-65. [pmid: 12595405].
111 May JR. The electronic medical record: a valuable partner. J Med Pract Manage. 2005;21(2):100-2. [pmid: 16302440].
112 Mayo-Smith MF, Agrawal A. Factors associated with improved completion of computerized clinical reminders across a large healthcare system. Int J Med Inform. 2007;76(10):710-6. [pmid: 16935025].
113 McCowan C, Neville RG, Ricketts IW, Warner FC, Hoskins G, Thomas GE. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
114 McDonald CJ. Computerization can create safety hazards: a bar-coding near miss. Ann Intern Med. 2006;144(7):510-6. [pmid: 16585665].
115 McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020].
116 McManus B. A move to electronic patient records in the community: a qualitative case study of a clinical data collection system, problems caused by inattention to users and human error. Top Health Inf Manage. 2000;20(4):23-37. [pmid: 10977140].
117 Mikulich VJ, Liu YC, Steinfeldt J, Schriger DL. Implementation of clinical guidelines through an electronic medical record: physician usage, satisfaction and assessment. Int J Med Inform. 2001;63(3):169-78. [pmid: 11502431].
118 Molenaar S, Sprangers M, Oort F, et al. Exploring the black box of a decision aid: what information do patients select from an interactive Cd-Rom on treatment options in breast cancer?. Patient Educ Couns. 2007;65(1):122-30. [pmid: 16945498].
119 Munir S, Boaden R. Patient empowerment and the electronic health record. Stud Health Technol Inform. 2001;84(Pt 1):663-5. [pmid: 11604820].
120 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res. 2008;10(2):e9. [pmid: 18417444].
121 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
122 Ojima M, Hanioka T, Kuboniwa M, Nagata H, Shizukuishi S. Development of Web-based intervention system for periodontal health: a pilot study in the workplace. Medical Informatics and the Internet in Medicine. 2003;28(4):291-8. [pmid: 14668131].
123 Pagliari C, Clark D, Hunter K, et al. DARTS 2000 online diabetes management system: formative evaluation in clinical practice. J Eval Clin Pract. 2003;9(4):391-400. [pmid: 14758961].
124 Paperny DM, Hedberg VA. Computer-assisted health counselor visits: a low-cost model for comprehensive adolescent preventive services (Brief record). Archives of Pediatrics and Adolescent Medicine. 1999;153(1):63-7. [pmid: 9895001].
125 Patt MR, Houston TK, Jenckes MW, Sands DZ, Ford DE. Doctors who are using e-mail with their patients: a qualitative exploration. Journal of Medical Internet Research. 2003;5(2).
126 Patterson ES, Nguyen AD, Halloran JP, Asch SM. Human factors barriers to the effective use of ten HIV clinical reminders. J Am Med Inform Assoc. 2004;11(1):50-9. [pmid: 14527974].
127 Patterson ES, Doebbeling BN, Fung CH, Militello L, Anders S, Asch SM. Identifying barriers to the effective use of clinical reminders: bootstrapping multiple methods. J Biomed Inform. 2005;38(3):189-99. [pmid: 15896692].
128 Paul DL, Pearlson KE, McDaniel RR Jr. Assessing technological barriers to telemedicine: technology-management implications. IEEE Transactions on Engineering Management. 1999;46(3):279-88.
129 Pelletier-Fleury N, Lanoe JL, Philippe C, Gagnadoux F, Rakotonanahary D, Fleury B. Economic studies and ‘technical’ evaluation of telemedicine: the case of telemonitored polysomnography. Health Policy. 1999;49(3):179-94. [pmid: 10827296].
130 Persell S, Denecke-Dattalo T, Dunham D, Baker D. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194].
131 Peters DH, Kohli M, Mascarenhas M, Rao K. Can computers improve patient care by primary health care workers in India?. International Journal for Quality in Health Care. 2006;18(6):437-45. [pmid: 17041232].
132 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: A randomized, controlled trial. Medical Care. 2000;38(2):218-30. [pmid: 10659695].
133 Pillai A, Thomas SS, Garg M. The electronic immediate discharge document: experience from the South West of Scotland. Inform Prim Care. 2004;12(2):67-73. [pmid: 15319058].
134 Pinna GD, Maestri R, Andrews D, et al. Home telemonitoring of vital signs and cardiorespiratory signals in heart failure patients: system architecture and feasibility of the HHH model. Int J Cardiol. 2007;120(3):371-9. [pmid: 17189654].
135 Pizziferri L, Kittler AF, Volk LA, et al. Primary care physician time utilization before and after implementation of an electronic health record: a time-motion study. J Biomed Inform. 2005;38(3):176-88. [pmid: 15896691].
136 Poon EG, Blumenthal D, Jaggi T, Honour MM, Bates DW, Kaushal R. Overcoming the barriers to the implementing computerized physician order entry systems in US hospitals: perspectives from senior management. AMIA Annu Symp Proc. 2003;975.
137 Priebe S, McCabe R, Bullenkamp J, et al. Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007;191:420-6. [pmid: 17978322].
138 Raebel MA, Chester EA, Newsom EE, et al. Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy. 2006;26(5):619-26. [pmid: 16637791].
139 Rahimpour M, Lovell NH, Celler BG, McCormick J. Patients’ perceptions of a home telecare system. International Journal of Medical Informatics. 2008;77(7):486-98. [pmid: 18023610].
140 Ralston JD, Rutter CM, Carrell D, Hecht J, Rubanowice D, Simon GE. Patient use of secure electronic messaging within a shared medical record: a cross-sectional study. J Gen Intern Med. 2009;24(3):349-55. [pmid: 19137379].
141 Rothert K, Strecher VJ, Doyle LA, et al. Web-based Weight Management Programs in an Integrated Health Care Setting: A Randomized, Controlled Trial. Obesity. 2006;14(2):266-72. [pmid: 16571852].
142 Rousseau N, McColl E, Newton J, Grimshaw J, Eccles M. Practice based, longitudinal, qualitative interview study of computerised evidence based guidelines in primary care. BMJ. 2003;326(7384):314. [pmid: 12574046].
143 Rubin MA, Bateman K, Donnelly S, et al. Use of a personal digital assistant for managing antibiotic prescribing for outpatient respiratory tract infections in rural communities. J Am Med Inform Assoc. 2006;13(6):627-34. [pmid: 16929045].
144 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association : JAMIA. 2003;10(6):573-9. [pmid: 12925545].
145 Ruland CM. A survey about the usefulness of computerized systems to support illness management in clinical practice. Int J Med Inform. 2004;73(11–12):797-805. [pmid: 15491930].
146 Saigh O, Triola MM, Link RN. Brief report: Failure of an electronic medical record tool to improve pain assessment documentation. J Gen Intern Med. 2006;21(2):185-8. [pmid: 16606379].
147 Saleem JJ, Patterson ES, Militello L, Render ML, Orshansky G, Asch SM. Exploring barriers and facilitators to the use of computerized clinical reminders. J Am Med Inform Assoc. 2005;12(4):438-47. [pmid: 15802482].
148 Samoutis G, Soteriades ES, Kounalakis DK, Zachariadou T, Philalithis A, Lionis C. Implementation of an electronic medical record system in previously computer-naive primary care centres: a pilot study from Cyprus. Inform Prim Care. 2007;15(4):207-16. [pmid: 18237477].
149 Schabetsberger T, Ammenwerth E, Breu R, et al. E-health approach to link-up actors in the health care system of Austria. Stud Health Technol Inform. 2006;124:415-20. [pmid: 17108555].
150 Schifferdecker KE, Reed VA, Homa K. A training intervention to improve information management in primary care. Fam Med. 2008;40(6):423-32. [pmid: 18773781].
151 Schumann A, John U, Ulbricht S, Rüge J, Bischof G, Meyer C. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. International Journal of Medical Informatics. 2008;77(11):715-22. [pmid: 18417417].
152 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
153 Sequist TD, Cullen T, Hays H, Taualii MM, Simon SR, Bates DW. Implementation and use of an electronic health record within the Indian Health Service. J Am Med Inform Assoc. 2007;14(2):191-7. [pmid: 17213495].
154 Sevick MA, Zickmund S, Korytkowski M, et al. Design, feasibility, and acceptability of an intervention using personal digital assistant-based self-monitoring in managing type 2 diabetes. Contemp Clin Trials. 2008;29(3):396-409. [pmid: 17997364].
155 Shea S. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
156 Shiffman RN, Freudigman M, Brandt CA, Liaw Y, Navedo DD. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 Pt 1):767-73. [pmid: 10742318].
157 Shore JH, Brooks E, Savin D, Orton H, Grigsby J, Manson SM. Acceptability of telepsychiatry in American Indians. Telemedicine and E-Health. 2008;14(5):461-6. [pmid: 18578681].
158 Shu K, Boyle D, Spurr C, et al. Comparison of time spent writing orders on paper with computerized physician order entry. Stud Health Technol Inform. 2001;84(Pt 2):1207-11. [pmid: 11604922].
159 Sicotte C, Denis JL, Lehoux P. The computer based patient record: a strategic issue in process innovation. J Med Syst. 1998;22(6):431-43. [pmid: 9871877].
160 Sicotte C, Pare G, Moreault MP, Lemay A, Valiquette L, Barkun J. Replacing an inpatient electronic medical record. Lessons learned from user satisfaction with the former system. Methods Inf Med. 2009;48(1):92-100. [pmid: 19151889].
161 Simon SR, Kaushal R, Cleary PD, et al. Physicians and electronic health records: a statewide survey. Arch Intern Med. 2007;167(5):507-12. [pmid: 17353500].
162 Simon SR, McCarthy ML, Kaushal R, et al. Electronic health records: which practices have them, and how are clinicians using them?. J Eval Clin Pract. 2008;14(1):43-7. [pmid: 18211642].
163 Sittig DF, Krall MA, Dykstra RH, Russell A, Chin HL. A survey of factors affecting clinician acceptance of clinical decision support. BMC Med Inform Decis Mak. 2006;6:6. [pmid: 16451720].
164 Smith K, Smith V, Krugman M, Oman K. Evaluating the impact of computerized clinical documentation. Comput Inform Nurs. 2005;23(3):132-8. [pmid: 15900170].
165 Smith GE, Lunde AM, Hathaway JC, Vickers KS. Telehealth home monitoring of solitary persons with mild dementia. American Journal of Alzheimer’s Disease and Other Dementias. 2007;22(1):20-6.
166 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ : Canadian Medical Association Journal = Journal De L’Association Medicale Canadienne. 2003;169(6):549-56.
167 Tan EL, Stark H, Lowinger JS, Ringland C, Ward R, Pearson SA. Information sources used by New South Wales cancer clinicians: a qualitative study. Intern Med J. 2006;36(11):711-7. [pmid: 17040357].
168 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
169 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
170 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
171 Trief P, Morin P, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31.
172 Trivedi MH, Kern JK, Marcee A, et al. Development and implementation of computerized clinical guidelines: barriers and solutions. Methods Inf Med. 2002;41(5):435-42. [pmid: 12501817].
173 Trivedi MH, Daly EJ, Kern JK, Grannemann BD, Sunderajan P, Claassen CA. Barriers to implementation of a computerized decision support system for depression: an observational report on lessons learned in “real world” clinical settings. BMC Med Inform Decis Mak. 2009;9:6. [pmid: 19159458].
174 Tsang MW, Mok M, Kam G, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. Journal of Telemedicine and Telecare. 2001;7(1):47-50. [pmid: 11265938].
175 Tudiver F, Wolff LT, Morin PC, et al. Primary care providers’ perceptions of home diabetes telemedicine care in the IDEATel project. J Rural Health. 2007;23(1):55-61. [pmid: 17300479].
176 Tufano JT, Ralston JD, Martin DP. Providers’ experience with an organizational redesign initiative to promote patient-centered access: a qualitative study. J Gen Intern Med. 2008;23(11):1778-83. [pmid: 18769981].
177 Valdes I, Kibbe DC, Tolleson G, Kunik ME, Petersen LA. Barriers to proliferation of electronic medical records. Inform Prim Care. 2004;12(1):3-9. [pmid: 15140347].
178 van den Berg MH, van der Giesen FJ, van Zeben D, van Groenendael JH, Seys PE, Vliet Vlieland TP. Implementation of a physical activity intervention for people with rheumatoid arthritis: a case study. Musculoskeletal Care. 2008;6(2):69-85. [pmid: 18302159].
179 Van Den Brink JL, Moorman PW, De Boer MF, Pruyn JFA, Verwoerd CDA, Van Bemmel JH. Involving the patient: A prospective study on use, appreciation and effectiveness of an information system in head and neck cancer care. Supporting Communication in Health Care: International Journal of Medical Informatics. 2005;74(10):839-49.
180 van Wijk MA, van der Lei J, Mosseveld M, Bohnen AM, van Bemmel JH. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
181 Vanmeerbeek M. Exploitation of electronic medical records data in primary health care. Resistances and solutions. Study in eight Walloon health care centres. Stud Health Technol Inform. 2004;110:42-8. [pmid: 15853250].
182 Varonen H, Kortteisto T, Kaila M. What may help or hinder the implementation of computerized decision support systems (CDSSs): a focus group study with physicians. Fam Pract. 2008;25(3):162-7. [pmid: 18504253].
183 Velikova G, Brown JM, Smith AB, Selby PJ. Computer-based quality of life questionnaires may contribute to doctor-patient interactions in oncology. Br J Cancer. 2002;86(1):51-9. [pmid: 11857011].
184 Wade SL, Wolfe CR, Brown TM, Pestian JP. Can a Web-based family problem-solving intervention work for children with traumatic brain injury?. Rehabilitation Psychology. 2005;50(4):337-45.
185 Wang SJ, Middleton B, Prosser LA, et al. A cost-benefit analysis of electronic medical records in primary care. Am J Med. 2003;114(5):397-403. [pmid: 12714130].
186 Wang CJ, Patel MH, Schueth AJ, et al. Perceptions of Standards-based Electronic Prescribing Systems as Implemented in Outpatient Primary Care: A Physician Survey. J Am Med Inform Assoc. 2009.
187 Weingart SN, Rind D, Tofias Z, Sands DZ. Who uses the patient internet portal? The PatientSite experience. J Am Med Inform Assoc. 2006;13(1):91-5. [pmid: 16221943].
188 Weiss JB, Lorenzi NM. Online communication and support for cancer patients: a relationship-centric design framework. AMIA Annu Symp Proc. 2005:799-803. [pmid: 16779150].
189 West VL, Milio N. Organizational and environmental factors affecting the utilization of telemedicine in rural home healthcare. Home Health Care Serv Q. 2004;23(4):49-67. [pmid: 15778152].
190 Wilbright WA, Haun DE, Romano T, Krutzfeldt T, Fontenot CE, Nolan TE. Computer use in an urban university hospital: technology ahead of literacy. Comput Inform Nurs. 2006;24(1):37-43. [pmid: 16436911].
191 Winkelman WJ, Leonard KJ, Rossos PG. Patient-perceived usefulness of online electronic medical records: employing grounded theory in the development of information and communication technologies for use by patients living with chronic illness. J Am Med Inform Assoc. 2005;12(3):306-14. [pmid: 15684128].
192 Woods KF, Kutlar A, Johnson JA, et al. Sickle cell telemedicine and standard clinical encounters: A comparison of patient satisfaction. Telemedicine Journal. 1999;5(4):349-56. [pmid: 10908450].