# Excluded Articles

List of “other” reasons
1. Abstract of interest
2. AMIA abstract
3. Case report
4. Case study, no data
5. CHI article - no physician
6. Combination of automated and manual methods to condense 891,770 problem statements
7. Commentary
8. Commentary/pop-press article
9. Computer Synoptic Operative Report
10. Conference abstract, no data
11. Describe the design and analysis issues within complex cluster RCT
12. Description of new call system implemented in 2 hospitals.
13. Descriptive article
14. Design/concept article
15. Discussion
16. Discussion
17. Dissertation
18. Editorial
19. Feature article
20. Features paper
21. Health information privacy laws
22. Historical review
23. Interview article
24. Interviews on perceived benefits--not actual--no real useful info here
25. Legal issues and telemedicine
26. No clinician involvement
27. No control group
28. No data
29. No extractable data
30. No physician
31. No physician involvement
32. No results, just description
33. Not a study
34. Not a study- software description
35. Not actually a study of use of an HIT app
36. Pilot study
37. Pilot study, one subject
38. Protocol
39. Protocol guideline
40. Purely a discussion piece
41. Refereed papers
42. Retrospective study
43. Software development
44. Software development report
45. Software implementation report
46. Software integration
47. Software development and integration
48. Study description; no final data
49. Study design
50. Study plan, no results are presented
51. Success story- no particular results
52. This is a discussion of what physicians think are good and bad points of emrs, it is not a BFD article
53. This is about an anonymous reporting system
54. Usability evaluation
55. Workshop

Adachi Y, Sato C, Yamatsu K, et al. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther. 2007;45(3):459-70. [pmid: 16713991]. Does not address patient-centered care
Adams EJ. Physicians turn to net-based resources to improve patient care. Medicine on the Net. 2003;9(9):1. No original data
Agrawal A, Mayo-Smith MF. Adherence to computerized clinical reminders in a large healthcare delivery network. Stud Health Technol Inform. 2004;107(Pt 1):111-4. [pmid: 15360785]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Aiello Bowles EJ, Tuzzio L, Wiese CJ, et al. Understanding high-quality cancer care: a summary of expert perspectives. Cancer. 2008;112(4):934-42. [pmid: 18181099]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Alexander GL, Rantz M, Flesner M, et al. Clinical information systems in nursing homes: an evaluation of initial implementation strategies. Comput Inform Nurs. 2007;25(4):189-97. [pmid: 17625399]. Methods discussion, of development article Other*
Allaert FA, Le Teuff G, Quantin C, et al. The legal acknowledgement of the electronic signature: a key for a secure direct access of patients to their computerised medical record. 2004:73239-242. No original data
Allan J, Englebright J. Patient-centered documentation: an effective and efficient use of clinical information systems. J Nurs Adm. 2000;30(2):90-5. [pmid: 10689400]. No original data
Allwood I, Holt TA. The South Warwickshire NHS Care Records Service Demonstrator Project: lessons for the National Programme for IT. Inform Prim Care. 2005;13(4):257-62. [pmid: 16510022]. Does not address patient-centered care Other*
Almond M, Gordon K, Jones Kent, et al. The effect of the controlled entry of electronic prescribing and medicines administration on the quality of prescribing, safety and success of administration on an acute medical ward. British Journal of Healthcare Computing & Information Management. 2002;19(2):41. Other
Ammenwerth E, Iller C, Mahler C. IT-adoption and the interaction of task, technology and individuals: a fit framework and a case study. BMC Med Inform Decis Mak. 2006:63. Does not address patient-centered care
Andersen SE. Implementing a new drug record system: a qualitative study of difficulties perceived by physicians and nurses. Qual Saf Health Care. 2002;11(1):19-24. [pmid: 12078363]. Does not address health IT Does not address patient-centered care
Anderson AS, Klemm P. The Internet: friend or foe when providing patient education. Clin J Oncol Nurs. 2008;12(1):55-63. [pmid: 18258575]. No original data
Anderson JG. Social, ethical and legal barriers to e-health. Int J Med Inform. 2007;76(5–6):480-3. [pmid: 17064955]. Does not address patient-centered care No original data
Andriole KP, Avrin DE, Yin L, et al. PACS databases and enrichment of the folder manager concept. J Digit Imaging. 2000;13(1):3-12. [pmid: 10696595]. Other*
Antiles S, Couris J, Schweitzer A, et al. Project planning, training, measurement and sustainment: the successful implementation of voice recognition. Radiol Manage. 2000;22(1):18-31. quiz 32–6. [pmid: 10787759]. Does not address patient-centered care No original data
Asonuma M. Issues facing system vendors as we approach the 21st century and expected roles--implementing a hospital information system providing greater patient satisfaction. Stud Health Technol Inform. 98;52(Pt 1). suppl 23–7. Methods discussion, of development article
Bachhuber T, Bugryn D. Programs that work! Heartworks at home. Home Healthcare Nurse Manager. 99;3(2):17-23. No original data
Bakken S, Chen E, Choi J, et al. Mobile decision support for advanced practice nurses. Stud Health Technol Inform. 2006:1221002. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Bal R, Mastboom F, Spiers HP, et al. The product and process of referral: optimizing general practitioner-medical specialist interaction through information technology. Int J Med Inform. Suppl 1. 2007;76:S28-34. [pmid: 16784886]. Methods discussion, of development article Other*
Baldwin KB. Evaluating quality of primary care using the electronic medical record. J Healthc Qual. 2006;28(6):40-7. [pmid: 17514864]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Baldwin LP, Clarke M, Eldabi T, et al. Telemedicine and its role in improving communication in healthcare. Logistics Information Management. 2002;15(4):309-319. No original data Methods discussion, of development article
Balka E, Whitehouse S. Whose work practice? Situating an electronic triage system within a complex system. Stud Health Technol Inform. 2007:13059-74. No original data
Bani-Issa W. Teaching beliefs and practices and the use of electronic health records in nursing education: A collective case study. 2005. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Barahona P, Azevedo F, Veloso M, et al. Computerising a guideline for the management of diabetes. 2001:64275-284. Methods discussion, of development article Other*
Barbell AS, Sublett P. Reducing medication errors with IT and process change. Journal of AHIMA. 2001;72(10):68-70. No original data Other*
Barnes CS, Tsui C, Caudle J, et al. Increasing patient empowerment and improving diabetes care by utilizing a computer-based patient “roadmap”. AMIA Annu Symp Proc. 2006:852. [pmid: 17238472]. Other
Barnett Tracey E, Chumbler Neale R, Vogel W, et al. The cost-utility of a care coordination/home telehealth programme for veterans with diabetes. Journal of Telemedicine and Telecare. 2007;13(6):318-321. [pmid: 17785029]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Barrett MJ. The evolving computerized medical record. Healthc Inform. 2000;17(5):85-8. 90. 92. 3. [pmid: 11142900]. No original data
Bassinder J, Bali RK, Naguib R. Knowledge management and electronic care records: Incorporating social, legal and ethical issues. Stud Health Technol Inform. 2006:121221-7. No original data Other*
Bates DW, Cohen M, Leape LL, et al. Reducing the frequency of errors in medicine using information technology. J Am Med Inform Assoc. 2001;8(4):299-308. [pmid: 11418536]. Methods discussion, of development article
Bates DW, Leape LL, Cullen DJ, et al. Effect of computerized physician order entry and a team intervention on prevention of serious medication errors. JAMA. 98;280(15):1311-6. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Bates DW. Physicians and ambulatory electronic health records. Health Aff (Millwood). 2005;24(5):1180-9. [pmid: 16162561]. Methods discussion, of development article
Elizabeth Baxley, Thomas Campbell. Electronic health records in academic family medicine practices: A tale of progress and opportunity. Annals of Family Medicine. 2008;6(1):87-88. [pmid: 18195322]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data
Beale IL, Marin-Bowling VM, Guthrie N, et al. Young cancer patients’ perceptions of a video game used to promote self care. International Electronic Journal of Health Education. 2006:9202-212. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Beebe M, Juhl C. Implementing a computerised patient record system in a large medical centre using the Self-Care Model to guide informatics practice.: Implementing a computerised patient record system in a large medical centre using the Self-Care Model to guide informatics practice. 2000:111-121. No original data Other*
Beliakov G, Warren J. Fuzzy logic for decision support in chronic care. Artif Intell Med. 2001;21(1–3):209-13. [pmid: 11154887]. Does not address patient-centered care No original data
Benazzo M, Lanza L, Mullace M, et al. A computerized database for head and neck cancer registry. Tumori. 99;85(6):449-53. Does not address patient-centered care Methods discussion, of development article
Bendixen Roxanna M, Levy Charles E, Olive Emory S, et al. Cost effectiveness of a telerehabilitation program to support chronically ill and disabled elders in their homes. Telemedicine and e-Health. 2009;15(1):31-38. [pmid: 19199845]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Benedetti R, Flock B, Pedersen S, et al. Improved clinical outcomes for fee-for-service physician practices participating in a diabetes care collaborative. Jt Comm J Qual Saf. 2004;30(4):187-94. [pmid: 15085784]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Benger JR, Noble SM, Coast J, et al. The safety and effectiveness of minor injuries telemedicine. Emergency medicine journal : EMJ. 2004;21(4):438-45. [pmid: 15208226]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Bennett NL, Casebeer LL, Zheng S, et al. Information-seeking behaviors and reflective practice. J Contin Educ Health Prof. 2006;26(2):120-7. [pmid: 16802313]. Does not address health IT Does not address patient-centered care
Bereznicki BJ, Peterson GM, Jackson SL, et al. Data-mining of medication records to improve asthma management. Med J Aust. 2008;189(1):21-5. [pmid: 18601636]. Other*
Bernhardt JM. Tailoring messages and design in a Web-based skin cancer prevention intervention. International Electronic Journal of Health Education. 2001:4290-297. Does not address patient-centered care Other*
Bindels R, de Clercq PA, Winkens RA, et al. A test ordering system with automated reminders for primary care based on practice guidelines. Int J Med Inform. 2000;58:59219-33. Does not address patient-centered care Methods discussion, of development article
Binioris S, Tsirintani M, Sapountzi-Krepia D, et al. Health professionals’ acceptance as a paragon for development and implementation of integrated Patient Care Information Systems. ICUs & Nursing Web Journal. 2001;(7):1-11. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data
Blaya JA, Shin SS, Yagui MJ, et al. A web-based laboratory information system to improve quality of care of tuberculosis patients in Peru: functional requirements, implementation and usage statistics. BMC Med Inform Decis Mak. 2007:733. Methods discussion, of development article Other*
Bochicchio GV, Smit PA, Moore R, et al. Pilot study of a web-based antibiotic decision management guide. J Am Coll Surg. 2006;202(3):459-67. [pmid: 16500251]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Bochicchio GV, Smit PA, Moore R, et al. Pilot study of a web-based antibiotic decision management guide. J Am Coll Surg. 2006;202(3):459-67. [pmid: 16500251]. Other*
Boisen E, Bygholm A, Cavan D, et al. Copability, coping, and learning as focal concepts in the evaluation of computerised diabetes disease management. Int J Med Inform. 2003;70(2–3):353-63. [pmid: 12909188]. Does not address patient-centered care Methods discussion, of development article
Bolton MB. Electronic-prescribing quality improvement through health care technology. Manag Care Interface. 2007;20(5):17. [pmid: 17626586]. No original data
Boudreau RM, McNally C, Rensing EM, et al. Improving the timeliness of written patient notification of mammography results by mammography centers. Breast J. 2004;10(1):10-9. [pmid: 14717754]. Does not address health IT
Bovbjerg VE, Olchanski V, Zimberg SE, et al. Internet-based monitoring and benchmarking in ambulatory surgery centers. Jt Comm J Qual Improv. 2000;26(8):450-65. [pmid: 10934636]. Does not address patient-centered care Methods discussion, of development article
Boyd L, Archer F. Developing a web-based education program for people with asthma in rural and remote areas. Journal of Emergency Primary Health Care. 2007;5(4):12. Methods discussion, of development article
Boyle Raymond G, Solberg Leif I, Asche Stephen E, et al. Offering telephone counseling to smokers using pharmacotherapy. Nicotine & Tobacco Research. 2005:7S19-s27. Does not address health IT
Boyle Raymond G, Solberg Leif I, Asche Stephen E, et al. Proactive recruitment of health plan smokers into telephone counseling. Nicotine & Tobacco Research. 2007;9(5):581-589. [pmid: 17454714]. Does not address health IT
Bratton RL. Patient and physician satisfaction with telemedicine for monitoring vital signs. 2001:772-73. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Breil B, Semjonow A, Dugas M. HIS-based electronic documentation can significantly reduce the time from biopsy to final report for prostate tumours and supports quality management as well as clinical research. BMC Med Inform Decis Mak. 2009:95. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Brender J, Ammenwerth E, Nykdnen P, et al. Factors influencing success and failure of health informatics systems - a pilot Delphi study. Methods of Information in Medicine. 2006;45(1):125-136. [pmid: 16482383]. Does not address patient-centered care Other*
Brennan S, Spours A. Barriers to the successful and timely implementation of electronic prescribing and medicines administration. British Journal of Healthcare Computing & Information Management. 2000;17(8):22-25. Methods discussion, of development article Other*
Brennan S, Spours A. Electronic prescribing and medicines administration: are we overcoming the barriers to success?. British Journal of Healthcare Computing & Information Management. 2003;20(4):19-22. Methods discussion, of development article Other*
Breslow MJ, Rosenfeld BA, Doerfler M, et al. Effect of a multiple-site intensive care unit telemedicine program on clinical and economic outcomes: an alternative paradigm for intensivist staffing (Structured abstract). Critical Care Medicine. 2004;32(1):31-38. [pmid: 14707557]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Breslow MJ. ICU telemedicine. Organization and communication. Crit Care Clin. 2000;16(4):707-22. x. xi. [pmid: 11070813]. Methods discussion, of development article Other*
Brokel JM, Harrison MI. Redesigning care processes using an electronic health record: a system’s experience. Jt Comm J Qual Patient Saf. 2009;35(2):82-92. [pmid: 19241728]. Other*
Brown SH, Miller RA, Camp HN, et al. Empirical derivation of an electronic clinically useful problem statement system. Ann Intern Med. 99;131(2):117-26. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Brunicardi BO. Financial analysis of savings from telemedicine in Ohio”s prison system (Brief record). Telemedicine Journal. 98;4(1):49-54. Does not address patient-centered care Methods discussion, of development article
Bullard MJ, Meurer DP, Colman I, et al. Supporting clinical practice at the bedside using wireless technology. Acad Emerg Med. 2004;11(11):1186-92. [pmid: 15528583]. Does not address patient-centered care
Bullas S, Bryant J. Successful systems sustaining change. Stud Health Technol Inform. 2007;129(Pt 2):1199-203. [pmid: 17911905]. No original data Other*
Burke JP, Pestotnik SL. Antibiotic use and microbial resistance in intensive care units: impact of computer-assisted decision support. J Chemother. 99;11(6):530-5. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Burrington-Brown J, Hjort B, Washington L. Health data access, use, and control. J AHIMA. 2007;78(5):63-6. [pmid: 17552326]. No original data Other*
Buscher HP, Engler Ch, Fuhrer A, et al. HepatoConsult: a knowledge-based second opinion and documentation system. Artif Intell Med. 2002;24(3):205-16. [pmid: 11879990]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Buzaglo Joanne S, Millard Jennifer L, Ridgway Caroline G, et al. An Internet method to assess cancer patient information needs and enhance doctor-patient communication: A pilot study. Journal of Cancer Education. 2007;22(4):233-240. [pmid: 18067435]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Byrne CM. Impact of prospective computerized clinical decision support information and targeted assistance on nursing home resident outcomes. 2005. Decision Making. Other*
Caceres C, Gomez EJ, Garcia F, et al. A Home Integral Telecare System for HIV/AIDS Patients. Stud Health Technol Inform. 2005:11423-9. Methods discussion, of development article Other*
Caceres C, Gomez EJ, Garcia F, et al. An integral care telemedicine system for HIV/AIDS patients. Int J Med Inform. 2006;75(9):638-42. [pmid: 16759900]. Methods discussion, of development article Other*
Campbell E, Peterkin D, Abbott R, et al. Encouraging underscreened women to have cervical cancer screening: the effectiveness of a computer strategy. Prev Med. 97;26(6):801-7. Study published before 1998
Capitated physicians benefit from efficiency gains with electronic records. Capitation Manag Rep. 2005;12(6):67-9. [pmid: 16190113]. No original data
Caputi P, Jayasuriya R, Rawstorne P, et al. Researching the implementation of a patient care information system: does Murphy”s law apply?: Researching the implementation of a patient care information system: does Murphy”s law apply?. 2000:122-129. Does not address patient-centered care
Carpenter Janet S, lSusan Rawl, Jennifer Porter, et al. Oncology outpatient and provider responses to a computerized symptom assessment system. Oncology Nursing Forum. 2008;35(4):661-669. [pmid: 18591170]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data Other*
Carter E. Marketing GÇ£smartGÇ¥ medical innovation: physicians’ attitudes and intentions. International Journal of Pharmaceutical and Healthcare Marketing. 2008;2(4):307-320. Does not address health IT Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Carter PI. Telemedicine in Minnesota. A primer for physicians. Minn Med. 2001;84(8):42-5. [pmid: 11523454]. No original data
Cavalleri M, Morstabilini R, Reni G. Integrating telemonitoring with clinical information systems: a case study. Conf Proc IEEE Eng Med Biol Soc. 2005:1573-6. Methods discussion, of development article Other*
Celi LA, Hassan E, Marquardt C, et al. The eICU: it’s not just telemedicine. Crit Care Med. 2001;29(8 Suppl):N183-9. [pmid: 11496041]. Methods discussion, of development article
Chan AS, Shankar RD, Coleman RW, et al. Leveraging point-of-care clinician feedback to study barriers to guideline adherence. AMIA Annu Symp Proc. 2005:915. [pmid: 16779202]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Chan EC, Vernon SW. Implementing an intervention to promote colon cancer screening through e-mail over the Internet: lessons learned from a pilot study. Medical care. 2008;46(9 Suppl 1):S117-22. [pmid: 18725823]. Other*
Chang CH. Patient-reported outcomes measurement and management with innovative methodologies and technologies. Qual Life Res. Suppl. 2007;16:1157-66. [pmid: 17616839]. No original data
Chang YJ, Tsai CY, Yeh ML, et al. Assessing the impact of user interface to the usability of a clinical decision support system. AMIA Annu Symp Proc. 2003:808. [pmid: 14728313]. Does not address patient-centered care Other*
Charalambakis D, Samiotakis Y, Sasson L. Computerised coordinated care system in the RISE project. Stud Health Technol Inform. 2000:57130-6. No original data
Charles BL. Telemedicine can lower costs and improve access. Healthc Financ Manage. 2000;54(4):66-9. [pmid: 10915354]. No original data
Chen ES, Bakken S, Currie LM, et al. An automated approach to studying health resource and infobutton use. Stud Health Technol Inform. 2006:122273-8. Does not address patient-centered care Other*
Betty Chewning, Pat Mosena, Dale Wilson, et al. Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Education and Counseling. 99;38(3):227-239. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Chiang MF, Starren JB. Software engineering risk factors in the implementation of a small electronic medical record system: the problem of scalability. Proc AMIA Symp. 2002:145-9. [pmid: 12463804]. Does not address patient-centered care Other*
Chiauzzi E, Brevard J, Thurn C, et al. MyStudentBody-Stress: an online stress management intervention for college students. J Health Commun. 2008;13(6):555-72. [pmid: 18726812]. Does not address patient-centered care Other*
Christensen T, Grimsmo A. Instant availability of patient records, but diminished availability of patient information: a multi-method study of GP’s use of electronic patient records. BMC Med Inform Decis Mak. 2008:812. Does not address patient-centered care
Chu S, Cesnik B. A three-tier clinical information systems design model. Int J Med Inform. 2000;57(2–3):91-107. [pmid: 10961566]. Does not address patient-centered care No original data
Chu S. Computerised clinical pathway management systems and the implications. Collegian. 2001;8(2):19-24. [pmid: 15484616]. No original data
Cimino JJ, Patel VL, Kushniruk AW. The patient clinical information system (PatCIS): technical solutions for and experience with giving patients access to their electronic medical records. Int J Med Inform. 2002;68(1–3):113-27. [pmid: 12467796]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Claflin N. Computerized interdisciplinary assessment. J Healthc Qual. 2000;22(2):25-33. [pmid: 10847863]. Methods discussion, of development article
Clark R. Trends influencing the cost of care and patient safety. Decision-making in five key areas can improve clinical and economic performance. Health Manag Technol. 20. 2006;27(7):18-1. [pmid: 16886476]. Other*
Classen DC, Kanhouwa M, Will D, et al. The patient safety institute demonstration project: a model for implementing a local health information infrastructure. J Healthc Inf Manag. 2005;19(4):75-86. [pmid: 16266036]. No original data Methods discussion, of development article
Cohn RJ, Goodenough B. Health professionals’ attitudes to videoconferencing in paediatric health-care. Journal of Telemedicine and Telecare. 2002;8(5):274-282. [pmid: 12396856]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Coiera E, Magrabi F, Westbrook JI, et al. Protocol for the Quick Clinical study: a randomised controlled trial to assess the impact of an online evidence retrieval system on decision-making in general practice. BMC Med Inform Decis Mak. 2006:633. Other*
Collins S, Currie L, Patel V, et al. Multitasking by clinicians in the context of CPOE and CIS use. Stud Health Technol Inform. 2007;129(Pt 2):958-62. [pmid: 17911857]. Does not address patient-centered care
Colombet I, Bura-Riviere A, Chatila R, et al. Personalized versus non-personalized computerized decision support system to increase therapeutic quality control of oral anticoagulant therapy: an alternating time series analysis. BMC Health Serv Res. 2004;4(1):27. [pmid: 15456515]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Colpaert K, Claus B, Somers A, et al. Impact of computerized physician order entry on medication prescription errors in the intensive care unit: a controlled cross-sectional trial. Crit Care. 2006;10(1):R21. [pmid: 16469126]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Comprehensive management, clinical software produce “paperless” office. Patient Focus Care Satisf. 98;6(3):29-32. No original data Methods discussion, of development article
Computerized system alerts docs to costs. ED Manag. 99;11(9):100-2. No original data Other*
Connolly DM, Pedlar D, MacKnight C, et al. Guidelines for stage-based supports in Alzheimer”s care: the FAST-ACT. Functional Assessment Staging Tool-Action Checklist. J Gerontol Nurs. 2000;26(11):34-45. [pmid: 11883620]. Does not address health IT
Cook SF, Visscher WA, Hobbs CL, et al. Project IMPACT: results from a pilot validity study of a new observational database. Crit Care Med. 2002;30(12):2765-70. [pmid: 12483071]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data
Coopmans VC, Biddle C. CRNA performance using a handheld, computerized, decision-making aid during critical events in a simulated environment: a methodologic inquiry. AANA J. 2008;76(1):29-35. [pmid: 18323317]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Copenhaver J, Webster C. Enhancing practice efficiency by examining patterns of care: top ten lists data mined from a private pediatric practice. J Med Pract Manage. 2001;17(2):109-11. [pmid: 11680135]. Does not address patient-centered care No original data
Couchman GR, Forjuoh SN, Rascoe TG, et al. E-mail communications in primary care: what are patients’ expectations for specific test results?. International Journal of Medical Informatics. 2005;74(1):21-30. [pmid: 15626633]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Coughlan J, Eatock J, Eldabi T. Evaluating telemedicine: a focus on patient pathways. Int J Technol Assess Health Care. 2006;22(1):136-42. [pmid: 16673690]. No original data Other*
Cowdery Joan E, Suggs L, Parker Suzanne, et al. Application of a Web-Based Tailored Health Risk Assessment in a Work-Site Population. Health Promotion Practice. 2007;8(1):88-95. [pmid: 16980572]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Crolla DA. Health care without walls responding to telehealth”s emerging legal issues. Health Law Can. 98;19(1):1-19. Does not address health IT Does not address patient-centered care Other*
Crosson JC, Ohman-Strickland PA, Hahn KA, et al. Electronic medical records and diabetes quality of care: results from a sample of family medicine practices. Ann Fam Med. 2007;5(3):209-15. [pmid: 17548848]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self-management tools for asthma--patients’ opinions and quality of data in a randomized crossover study. Stud Health Technol Inform. 2007:127178-89. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Cummings J, Krsek C, Vermoch K, et al. Intensive care unit telemedicine: review and consensus recommendations. Am J Med Qual. 2007;22(4):239-50. [pmid: 17656728]. No original data
Currell R, Urquhart C, Wainwright P, et al. Telemedicine versus face to face patient care: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2000;(2):CD002098. [pmid: 10796678]. No original data
Dackiewicz D, Bergsneider C, Piraino D. Impact of digital radiography on clinical workflow and patient satisfaction. J Digit Imaging. 2000;13(2 Suppl 1):200-1. [pmid: 10847400]. Does not address patient-centered care
Dale J, Williams S, Foster T, et al. Safety of telephone consultation for “non-serious” emergency ambulance service patients. Qual Saf Health Care. 2004;13(5):363-73. [pmid: 15465940]. Other*
Daley MF, Barrow J, Pearson K, et al. Identification and recall of children with chronic medical conditions for influenza vaccination. Pediatrics. 2004;113(1 Pt 1):e26-33. [pmid: 14702491]. Does not address health IT Study is NOT an RCT AND does not address barriers, facilitators or drivers
Daly HL. Telemedicine: the invisible legal barriers to the health care of the future. Ann Health Law. 2000:973-106. inside cover. No original data
Daly JM, Buckwalter K, Maas M. Written and computerized care plans. Organizational processes and effect on patient outcomes. Journal of gerontological nursing. 2002;28(9):14-23. [pmid: 12240516]. Does not address patient-centered care
Dantu R, Oosterwijk H, Kolan P, et al. Securing medical networks. Network Security. 2007;2007(6):13-16. Does not address patient-centered care No original data
Dayton CS, Ferguson JS, Hornick DB, et al. Evaluation of an Internet-based decision-support system for applying the ATS/CDC guidelines for tuberculosis preventive therapy. Med Decis Making. 2000;20(1):1-6. [pmid: 10638531]. Methods discussion, of development article
DeLenardo C. Web-based tools steer patient-focused care: portal technology empowers patients to track and improve outcomes. Holistic Nursing Practice. 2005;19(2):90-92. Other*
George Demiris, Oliver Debra R, Fleming Parker, et al. Hospice staff attitudes towards telehospice. American Journal of Hospice & Palliative Medicine. 2004;21(5):343-347. [pmid: 15510570]. Does not address patient-centered care
Deodhar J. Improving neonatal care at a primary health care facility in rural India with the help of level III urban NICU using telemedicine (Brief record). Neonatal Intensive Care. 2002;15(3):21-22. Does not address patient-centered care Methods discussion, of development article
Devineni T, Blanchard EB. A randomized controlled trial of an internet-based treatment for chronic headache. Behav Res Ther. 2005;43(3):277-92. [pmid: 15680926]. Does not address patient-centered care Other*
Devitt N, Murphy J. A survey of the information management and technology training needs of doctors in an acute NHS trust in the United Kingdom. Health Info Libr J. 2004;21(3):164-72. [pmid: 15318914]. Does not address patient-centered care No original data
Dinneen SF, Bjornsen SS, Bryant SC, et al. Towards an optimal model for community-based diabetes care: design and baseline data from the Mayo Health System Diabetes Translation Project. J Eval Clin Pract. 2000;6(4):421-9. [pmid: 11133125]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Do N, Marinkovich A, Koisch J, et al. Electronic access to care system: improving patient’s access to clinical information through an Interactive Voice Response (IVR) system and Web portal. AMIA Annu Symp Proc. 2003:830. [pmid: 14728335]. No original data Methods discussion, of development article
Doarn Charles R, Debbie Justis, Chaudhri Muhammad S, et al. Integration of Telemedicine Practice Into Correctional Medicine: An Evolving Standard. Journal of Correctional Health Care. 2005;11(3):253-270. No original data
Docimo AB, Pronovost PJ, Davis RO, et al. Using the online and offline change model to improve efficiency for fast-track patients in an emergency department. Jt Comm J Qual Improv. 2000;26(9):503-14. [pmid: 10983291]. Does not address health IT Does not address patient-centered care
Doebbeling BN, Vaughn TE, McCoy KD, et al. Informatics implementation in the Veterans Health Administration (VHA) healthcare system to improve quality of care. AMIA Annu Symp Proc. 2006:204-8. [pmid: 17238332]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Dorr DA, Rowan B, Weed M, et al. Physicians’ attitudes regarding patient access to electronic medical records. AMIA Annu Symp Proc. 2003:832. [pmid: 14728337]. Does not address patient-centered care Other*
Persephone Doupi, Van Der, Johan Lei. Design and implementation considerations for a personalized patient education system in burn care. MIE 2003: International Journal of Medical Informatics. 2005;74(2–4):151-157. No original data Methods discussion, of development article
Dowie R, Mistry H, Young TA, et al. Telemedicine in pediatric and perinatal cardiology: economic evaluation of a service in English hospitals. Int J Technol Assess Health Care. 2007;23(1):116-25. [pmid: 17234025]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Driving forward the use of electronic and patient health records. Contemporary OB/GYN. 2008;53(5):26. No original data Other*
Dunn S, Willis E, Pal S, et al. Using nursing information systems to enhance quality service across multiple service providers. Aust Health Rev. 2004;27(1):103-10. [pmid: 15362302]. Does not address patient-centered care
Dunton GF, Robertson TP. A tailored Internet-plus-email intervention for increasing physical activity among ethnically-diverse women. Preventive medicine. 2008;47(6):605-11. [pmid: 18977243]. Does not address patient-centered care Other*
Dykes PC, Acevedo K, Boldrighini J, et al. Clinical practice guideline adherence before and after implementation of the HEARTFELT (HEART Failure Effectiveness & Leadership Team) intervention. J Cardiovasc Nurs. 2005;20(5):306-14. [pmid: 16141775]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Eccles M, Grimshaw J, Steen N, et al. The design and analysis of a randomized controlled trial to evaluate computerized decision support in primary care: the COGENT study. Fam Pract. 2000;17(2):180-6. [pmid: 10758083]. Does not address health IT Other*
Eccles M, Hawthorne G, Whitty P, et al. A randomised controlled trial of a patient based Diabetes Recall and Management System: the DREAM trial: a study protocol. BMC Health Serv Res. 2002;2(1):5. [pmid: 11914161]. Methods discussion, of development article Other*
Eccles M, Steen N, Grimshaw J, et al. Effect of audit and feedback, and reminder messages on primary-care radiology referrals: a randomised trial. Lancet. 2001;357(9266):1406-9. [pmid: 11356439]. Does not address health IT Does not address patient-centered care
Edhemovic I, Temple WJ, de Gara CJ, et al. The computer synoptic operative report--a leap forward in the science of surgery. Ann Surg Oncol. 2004;11(10):941-7. [pmid: 15466354]. Does not address patient-centered care Other*
Edwards Paula J, Moloney Kevin P, Jacko Julie A, et al. Evaluating usability of a commercial electronic health record: A case study. International Journal of Human-Computer Studies. 2008;66(10):718-728. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
E-feedback results in better care and hygiene. Nursing Standard. 2007;22(2):7. No original data Other*
Ehrenberger HE. Cancer clinical trial patients in the information age: a pilot study. Cancer Pract. 2001;9(4):191-7. [pmid: 11879310]. Does not address health IT Methods discussion, of development article
Electronic prescribing creating new types of errors. Contemporary OB/GYN. 2005;50(3):24. No original data
Electronic records improve quality of care. ITIN. 2003;15(2):5-6. No original data
Nina Eminovic, Wyatt Jeremy C, Tarpey Aideen M, et al. First evaluation of the NHS Direct Online Clinical Enquiry Service: A Nurse-led Web Chat Triage Service for the Public. Journal of Medical Internet Research. 2004. Other*
Emmons KM, Wong M, Puleo E, et al. Tailored computer-based cancer risk communication: correcting colorectal cancer risk perception. Journal of health communication. 2004;9(2):127-41. [pmid: 15204824]. Does not address patient-centered care Other*
Maria Engstr+¦m, Ragny Lindqvist, Birgitta Ljunggren, et al. Relatives’ opinions of IT support, perceptions of irritations and life satisfaction in dementia care. Journal of Telemedicine and Telecare. 2006;12(5):246-250. [pmid: 16848937]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Esser PE, Goossens RH. A framework for the design of user-centred teleconsulting systems. J Telemed Telecare. 2009;15(1):32-9. [pmid: 19139218]. No original data Other*
Evans RS, Pestotnik SL, Classen DC, et al. A computer-assisted management program for antibiotics and other antiinfective agents (Structured abstract). New England Journal of Medicine. 98;338(4):232-238. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Eversman WG, Pavlicek W, Zavalkovskiy B, et al. Performance and function of a desktop viewer at Mayo Clinic Scottsdale. J Digit Imaging. 2000;13(2 Suppl 1):147-52. [pmid: 10847386]. Does not address patient-centered care Methods discussion, of development article
Eysenbach G, Diepgen TL. Responses to unsolicited patient e-mail requests for medical advice on the World Wide Web. JAMA. 98;280(15):1333-5. Does not address patient-centered care
Ezenkwele UA, Sites FD, Shofer FS, et al. A randomized study of electronic mail versus telephone follow-up after emergency department visit. The Journal of emergency medicine. 2003;24(2):125-30. [pmid: 12609640]. Does not address patient-centered care Other*
Fackler J. The future of electronic medical records--part I. Mo Med. 2006;103(2):119-23. [pmid: 16703707]. No original data
Field MJ, Grigsby J. Telemedicine and remote patient monitoring. JAMA. 2002;288(4):423-5. [pmid: 12132953]. No original data Methods discussion, of development article
Fiks AG, Grundmeier RW, Biggs LM, et al. Impact of clinical alerts within an electronic health record on routine childhood immunization in an urban pediatric population. Pediatrics. 2007;120(4):707-14. [pmid: 17908756]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Filardo G, Nicewander D, Hamilton C, et al. A hospital-randomized controlled trial of an educational quality improvement intervention in rural and small community hospitals in Texas following implementation of information technology. Am J Med Qual. 2007;22(6):418-27. [pmid: 18006422]. Methods discussion, of development article Other*
Finkelstein J, O’Connor G, Friedmann RH. Development and implementation of the home asthma telemonitoring (HAT) system to facilitate asthma self-care. Stud Health Technol Inform. 2001;84(Pt 1):810-4. [pmid: 11604847]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Sarah Flicker, Eudice Goldberg, Stanley Read, et al. HIV-Positive Youth’s Perspectives on the Internet and eHealth. Journal of Medical Internet Research. 2004:6. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Flottorp S, Oxman AD. Identifying barriers and tailoring interventions to improve the management of urinary tract infections and sore throat: a pragmatic study using qualitative methods. BMC Health Serv Res. 2003;3(1):3. [pmid: 12622873]. Does not address health IT Methods discussion, of development article
Fogarty GB, Cassumbhoy R, Martin JM, et al. Technique for axillary radiotherapy using computer-assisted planning for high-risk skin cancer. Australas Radiol. 2007;51(3):267-75. [pmid: 17504320]. Does not address health IT Does not address patient-centered care
Ford EW, Short JC. The impact of health system membership on patient safety initiatives. Health Care Manage Rev. 2008;33(1):13-20. [pmid: 18091440]. Does not address health IT Does not address patient-centered care
Fournier D, Gosselin D, Rioux N. The challenges of implementing an electronic medical record system in a long-term care facility. Geriatr Nurs. 2006;27(1):28-30. [pmid: 16528841]. Methods discussion, of development article Other*
Franklin VL, Greene A, Waller A, et al. Patients’ engagement with “Sweet Talk” - a text messaging support system for young people with diabetes. J Med Internet Res. 2008;10(2):e20. [pmid: 18653444]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Fransen J, Twisk JW, Creemers MC, et al. Design and analysis of a randomized controlled trial testing the effects of clinical decision support on the management of rheumatoid arthritis. Arthritis Rheum. 2004;51(1):124-7. [pmid: 14872465]. No original data Methods discussion, of development article
Frase-Blunt M. Telemedicine: across the miles and right next door. Hosp Top. 98;76(2):9-13. No original data Other*
Fretheim A, Aaserud M, Oxman AD. Rational prescribing in primary care (RaPP): economic evaluation of an intervention to improve professional practice. PLoS Med. 2006;3(6):e216. [pmid: 16737349]. Does not address health IT
Friedman Charles P, Elstein Arthur S, Wolf Fredric M, et al. Enhancement of clinicians’ diagnostic reasoning by computer-based consultation: A multisite study of 2 systems. JAMA: Journal of the American Medical Association. 99;282(19):1851-1856. Does not address patient-centered care
Fuller KN. In search of intelligent life in the documentation universe: a hospital”s journey to developing an interdisciplinary computer-based documentation system. Comput Inform Nurs. 2006;24(1):6-9. [pmid: 16436905]. No original data Methods discussion, of development article
Furukawa MF, Ketcham JD, Rimsza ME. Physician practice revenues and use of information technology in patient care. Med Care. 2007;45(2):168-76. [pmid: 17224780]. Does not address patient-centered care Other*
Gadzhanova S, Iankov II, Warren JR, et al. Developing high-specificity anti-hypertensive alerts by therapeutic state analysis of electronic prescribing records. J Am Med Inform Assoc. 2007;14(1):100-9. [pmid: 17068356]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article Other*
Gagnon MP, Godin G, Gagne C, et al. An adaptation of the theory of interpersonal behaviour to the study of telemedicine adoption by physicians. Int J Med Inform. 2003;71(2–3):103-15. [pmid: 14519403]. Does not address patient-centered care Methods discussion, of development article
Marie-Pierre Gagnon, Lise Lamothe, Marilynne Hebert, et al. Telehomecare for vulnerable populations: The evaluation of new models of care. Telemedicine Journal and e-Health. 2006;12(3):324-331. [pmid: 16796500]. No original data
Galt KA, Rich EC, Young WW, et al. Impact of hand-held technologies on medication errors in primary care. Topics in Health Information Management. 2002;23(2):71-81. Does not address patient-centered care
Gamble B. Barriers to the implementation of clinical systems. ElectronicHealthcare. 2003;2(3):23-26. No original data Methods discussion, of development article Other*
Gambling T, Long AF. Exploring patient perceptions of movement through the stages of change model within a diabetes tele-care intervention. Journal of health psychology. 2006;11(1):117-28. [pmid: 16314385]. Does not address health IT Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Garland HT, Cavanaugh BJ, Evans CS, et al. The web browser as a unifying agent for radiology and the health care enterprise. J Digit Imaging. 2000;13(2 Suppl 1):145-6. [pmid: 10847385]. Does not address patient-centered care Methods discussion, of development article
Garrison GM, Bernard ME, Rasmussen NH. 21st-century health care: the effect of computer use by physicians on patient satisfaction at a family medicine clinic. Fam Med. 2002;34(5):362-8. [pmid: 12038718]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Victoria Garshnek, Hassell L, Harrison. Overview and status of the AKAMAI Telemedicine Evaluation Initiative. 99;156. No original data Other*
Garza M. E-medicine offers benefits and legal risks. OB-GYN Malpractice Prevention. 2000;7(6):41-46. No original data Other*
Gell G. Safe, controllable technology?. [patient centered health record]. International Journal of Medical Informatics. 2002;66(1):69-73. [pmid: 12453560]. No original data
Gerbert B, Bronstone A, Maurer T, et al. Decision support software to help primary care physicians triage skin cancer: a pilot study. Arch Dermatol. 2000;136(2):187-92. [pmid: 10677094]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Gilman G, Lutzi CA, Daniels BK, et al. The architecture of a mobile outreach echocardiography service. J Am Soc Echocardiogr. 2006;19(12):1526-8. [pmid: 17138039]. Does not address patient-centered care Methods discussion, of development article
Godard B, Marshall J, Laberge C, et al. Strategies for consulting with the community: the cases of four large-scale genetic databases. Sci Eng Ethics. 2004;10(3):457-77. [pmid: 15362702]. Does not address health IT Does not address patient-centered care
Goessens BM, Visseren FL, de Nooijer J, et al. A pilot-study to identify the feasibility of an Internet-based coaching programme for changing the vascular risk profile of high-risk patients. Patient Educ Couns. 2008;73(1):67-72. [pmid: 18639410]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Goins RT, Kategile U, Dudley KC. Telemedicine, rural elderly, and policy issues. J Aging Soc Policy. 2001;13(4):53-71. [pmid: 12418382]. Does not address patient-centered care No original data
Goldberg HS, Morales A, Gottlieb L, et al. Reinventing patient-centered computing for the twenty-first century. Stud Health Technol Inform. 2001;84(Pt 2):1455-8. [pmid: 11604967]. No original data Methods discussion, of development article
Goldberg IV. Electronic medical records and patient privacy. Health Care Manag (Frederick). 2000;18(3):63-9. [pmid: 10915343]. No original data
Golder DT, Brennan KA. Practicing dentistry in the age of telemedicine. J Am Dent Assoc. 2000;131(6):734-44. [pmid: 10860325]. No original data
Goldstein D. Medical Internet. Using IT to enhance patient safety. Managed Care Interface. 2002;15(12):46-47. [pmid: 12530295]. No original data
Goldstein MK, Hoffman BB, Coleman RW, et al. Patient safety in guideline-based decision support for hypertension management: ATHENA DSS. Proc AMIA Symp. 2001:214-8. [pmid: 11825183]. No original data Other*
Gondolf EW. Implementation of case management for batterer program participants. Violence Against Women. 2008;14(2):208-25. [pmid: 18212341]. Does not address health IT
Goroll AH, Simon SR, Tripathi M, et al. Community-wide implementation of health information technology: the Massachusetts eHealth Collaborative experience. J Am Med Inform Assoc. 2009;16(1):132-9. [pmid: 18952937]. Does not address patient-centered care
Gortzis L, Kalogeropoulos A, Alexopoulos D, et al. Optimizing the interventional cardiology facility: services integration in routine workflow. Methods Inf Med. 2007;46(3):344-51. [pmid: 17492121]. Does not address patient-centered care
Gosling AS, Westbrook JI, Spencer R. Nurses’ use of online clinical evidence. J Adv Nurs. 2004;47(2):201-11. [pmid: 15196194]. Does not address patient-centered care
Graham G, Nugent L, Strouse K. Information every where: how the EHR transformed care at VHA. J AHIMA. 2003;74(3):20-4. [pmid: 12914345]. Does not address patient-centered care No original data
Graham MJ, Currie LM, Allen M, et al. Characterizing information needs and cognitive processes during CIS use. AMIA Annu Symp Proc. 2003:852. [pmid: 14728357]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Grant RW, Meigs JB. Overcoming barriers to evidence-based diabetes care. Curr Diabetes Rev. 2006;2(2):261-9. [pmid: 18220631]. Does not address health IT No original data Methods discussion, of development article
Graschew G, Roelofs TA, Rakowsky S, et al. Virtual hospital and digital medicine--why is the GRID needed. Stud Health Technol Inform. 2006:120295-304. No original data Methods discussion, of development article
Gray NJ, Klein JD, Cantrill JA, et al. Adolescent girls’ use of the Internet for health information: issues beyond access. J Med Syst. 2002;26(6):545-53. [pmid: 12385536]. Does not address health IT No original data
Green BB, Ralston JD, Fishman PA, et al. Electronic communications and home blood pressure monitoring (e-BP) study: design, delivery, and evaluation framework. Contemporary clinical trials. 2008;29(3):376-95. [pmid: 17974502]. Other*
Greenfield S. Medication error reduction and the use of PDA technology. J Nurs Educ. 2007;46(3):127-31. [pmid: 17396552]. Does not address patient-centered care Other*
Grimson W, Jung B, van Mulligen EM, et al. Extensions to the HISA standard--the SynEx computing environment. Methods Inf Med. 2002;41(5):401-10. [pmid: 12501812]. No original data Methods discussion, of development article
Groves RH, Holcomb BW, Smith ML. Intensive care telemedicine: evaluating a model for proactive remote monitoring and intervention in the critical care setting. Stud Health Technol Inform. 2008:131131-46. No original data
Sergio Guill+_n, Arredondo MT, Traver V, et al. User satisfaction with home telecare based on broadband communication. Journal of Telemedicine and Telecare. 2002;8(2):81-90. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Guillen S, Arredondo MT, Traver V, et al. Multimedia telehomecare system using standard TV set. IEEE Trans Biomed Eng. 2002;49(12):1431-7. [pmid: 12542238]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Guo B, Documet J, Lee J, et al. Experiences with a prototype tracking and verification system implemented within an imaging center. Acad Radiol. 2007;14(3):270-8. [pmid: 17307659]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Hadjinikolaou L, Cohen A, Glenville B, et al. The effect of a ‘fast-track’ unit on the performance of a cardiothoracic department. Ann R Coll Surg Engl. 2000;82(1):53-8. [pmid: 10700770]. Does not address patient-centered care
Hagland M. Performance improvement: EMR nirvana. Part I: the landscape. Healthc Inform. 2007;24(5):20-2. [pmid: 17518233]. No original data Other*
Hailey D, Ohinmaa A, Roine R. Limitations in the routine use of telepsychiatry. J Telemed Telecare. 2009;15(1):28-31. [pmid: 19139217]. Does not address patient-centered care No original data
Hannan TJ, Rotich JK, Odero WW, et al. The Mosoriot medical record system: design and initial implementation of an outpatient electronic record system in rural Kenya. Int J Med Inform. 2000;60(1):21-8. [pmid: 10974639]. Does not address patient-centered care No original data
Hardin WD. Clinical information systems. Semin Pediatr Surg. 2000;9(1):35-9. [pmid: 10688384]. No original data Other*
Harris RE, Williams DA, McLean SA, et al. Characterization and consequences of pain variability in individuals with fibromyalgia. Arthritis Rheum. 2005;52(11):3670-4. [pmid: 16258905]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Harrison JP, Palacio C. The role of clinical information systems in health care quality improvement. Health Care Manag (Frederick). 2006;25(3):206-12. [pmid: 16905990]. No original data
Hart A, Jones A, Henwood F, et al. Public health. Use of client held records in the maternity services. British Journal of Midwifery. 2003;11(11):668. Does not address health IT No original data
Hartmann CW, Sciamanna CN, Blanch DC, et al. A website to improve asthma care by suggesting patient questions for physicians: qualitative analysis of user experiences. J Med Internet Res. 2007;9(1):e3. [pmid: 17478412]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Hasson D, Anderberg UM, Theorell T, et al. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers [ISRCTN54254861]. BMC public health. 2005:578. Does not address patient-centered care
Hayes WS, Tohme WG, Komo D, et al. A telemedicine consultative service for the evaluation of patients with urolithiasis. Urology. 98;51(1):39-43. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Hertzberg J. Computerized patient records: current and future opportunities. J Med Pract Manage. 2000;15(5):250-5. [pmid: 10915517]. No original data
Hetlevik I, Holmen J, Kruger O. Implementing clinical guidelines in the treatment of hypertension in general practice. Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care. 99;17(1):35-40. Does not address patient-centered care
Higgins JV. Telemedicine speeds up on information superhighway. Mich Med. 99;98(12):32-8. No original data Other*
Hillestad R, Bigelow J, Bower A, et al. Can electronic medical record systems transform health care? Potential health benefits, savings, and costs (Brief record). Health Affairs. 2005;24(5):1103-1117. [pmid: 16162551]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data
Hilty Donald M, Nesbitt Thomas S, Kuenneth Christina A, et al. Rural versus suburban primary care needs, utilization, and satisfaction with telepsychiatric consultation. Journal of Rural Health. 2007;23(2):163-165. [pmid: 17397373]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Hirsch IB, Goldberg HI, Ellsworth A, et al. A multifaceted intervention in support of diabetes treatment guidelines: a cont trial. Diabetes Res Clin Pract. 2002;58(1):27-36. [pmid: 12161054]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Hjelm NM. Benefits and drawbacks of telemedicine. Journal of Telemedicine and Telecare. 2005;11(2):60-70. [pmid: 15829049]. No original data
Hodge JG, Gostin LO, Jacobson PD. Legal issues concerning electronic health information: privacy, quality, and liability. JAMA. 99;282(15):1466-71. Methods discussion, of development article Other*
Honeyman JC, Smith D, Velocci VV. Effects of a large-scale deployment of soft-copy devices for picture archiving and communication systems viewing. J Digit Imaging. 2000;13(2 Suppl 1):204-5. [pmid: 10847402]. Methods discussion, of development article
Hsieh TC, Kuperman GJ, Jaggi T, et al. Characteristics and consequences of drug allergy alert overrides in a computerized physician order entry system. J Am Med Inform Assoc. 2004;11(6):482-91. [pmid: 15298998]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Dyfrig Hughes. When drugs don’t work: Economic assessment of enhancing compliance with interventions supported by electronic monitoring devices. PharmacoEconomics. 2007;25(8):621-635. [pmid: 17640105]. No original data
Hunt DL, Haynes RB, Hayward RSA, et al. Patient-specific evidence-based care recommendations for diabetes mellitus: development and initial clinic experience with a computerized decision support system. International Journal of Medical Informatics. 98-;51(2):127-135. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Hurling R, Catt M, Boni MD, et al. Using internet and mobile phone technology to deliver an automated physical activity program: randomized controlled trial. J Med Internet Res. 2007;9(2):e7. [pmid: 17478409]. Does not address patient-centered care Other*
Ilag LL, Martin CL, Tabaei BP, et al. Improving diabetes processes of care in managed care. Diabetes Care. 2003;26(10):2722-7. [pmid: 14514570]. No original data
Imhoff M. Cost benefit of medical IT (Brief record). Journal fur Anasthesie und Intensivbehandlung. 2002;9(1):78-80. No original data
Jaana M, Pare G, Sicotte C. Information technology capacities assessment tool in hospitals: instrument development and validation. Int J Technol Assess Health Care. 2009;25(1):97-106. [pmid: 19126257]. Does not address patient-centered care Other*
Jack D, Boian R, Merians AS, et al. Virtual reality-enhanced stroke rehabilitation. IEEE Trans Neural Syst Rehabil Eng. 2001;9(3):308-18. [pmid: 11561668]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Jahn K, Gartig-Daugs A, Nagel E. Electronic health records within integrated care in Germany. Telemed J E Health. 2005;11(2):146-50. [pmid: 15857255]. No original data
Javitt JC, Rebitzer JB, Reisman L. Information technology and medical missteps: evidence from a randomized trial. J Health Econ. 2008;27(3):585-602. [pmid: 18199511]. Does not address patient-centered care
Johnston B, Wheeler L, Deuser J, et al. Outcomes of the Kaiser Permanente Tele-Home Health Research Project. Archives of family medicine. 2000;9(1):40-5. [pmid: 10664641]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Johnstone HM. Quality outcomes of nursing tele-visits. 2000. Other*
Jones TM. Patient participation in EHR benefits. Health Manag Technol. 2003;24(10):64-63. [pmid: 14535127]. No original data
Joseph Amelia M. Care Coordination and Telehealth Technology in Promoting Self-Management Among Chronically Ill Patients. Telemedicine and e-Health. 2006;12(2):156-159. [pmid: 16620170]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Joyce P, Levan D, Peth T. Telehealth--A P4P tool for quality based reimbursement: its impact on quality care and customer service. Caring. 2006;25(9):44-5. 47. 8. [pmid: 17022323]. No original data
Judge J, Field TS, DeFlorio M, et al. Prescribers’ responses to alerts during medication ordering in the long term care setting. J Am Med Inform Assoc. 2006;13(4):385-90. [pmid: 16622171]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Kalmeijer MD, Holtzer W, van Dongen R, et al. Implementation of a computerized physician medication order entry system at the Academic Medical Centre in Amsterdam. Pharm World Sci. 2003;25(3):88-93. [pmid: 12840960]. No original data
Kane B, Sands DZ. Guidelines for the clinical use of electronic mail with patients. The AMIA Internet Working Group, Task Force on Guidelines for the Use of Clinic-Patient Electronic Mail. J Am Med Inform Assoc. 98;5(1):104-11. Methods discussion, of development article
Kasje WN, Denig P, De Graeff PA, et al. Physicians’ views on joint treatment guidelines for primary and secondary care. Int J Qual Health Care. 2004;16(3):229-36. [pmid: 15150154]. Does not address health IT
Kato K, Shimamoto K, Ishigaki T, et al. An experimental teleradiology transmission system using a high-speed ATM backbone network. J Telemed Telecare. 2000;6(2):114-8. [pmid: 10824380]. Does not address patient-centered care
Katz RC, Wertz RT. The efficacy of computer-provided reading treatment for chronic aphasic adults. J Speech Lang Hear Res. 97;40(3):493-507. Study published before 1999
Kazley AS, Ozcan YA. Organizational and environmental determinants of hospital EMR adoption: a national study. J Med Syst. 2007;31(5):375-84. [pmid: 17918691]. Does not address patient-centered care
Ketchell DS, St Anna L, Kauff D, et al. PrimeAnswers: A practical interface for answering primary care questions. J Am Med Inform Assoc. 2005;12(5):537-45. [pmid: 15905488]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article Other*
Kho A, Dexter P, Warvel J, et al. Computerized reminders to improve isolation rates of patients with drug-resistant infections: design and preliminary results. AMIA Annu Symp Proc. 2005:390-4. [pmid: 16779068]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Kildea S, Barclay L, Brodie P. Maternity care in the bush: using the Internet to provide educational resources to isolated practitioners. Rural Remote Health. 2006;6(3):559. [pmid: 16822171]. Does not address patient-centered care
Kim EH, Stolyar A, Lober WB, et al. Usage patterns of a personal health record by elderly and disabled users. AMIA Annu Symp Proc. 2007:409-13. [pmid: 18693868]. Other
Kim E, Mayani A, Modi S, et al. Evaluation of patient-centered electronic health record to overcome digital divide. 2005:7. VOLS1091-1094. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Kim GR, Chen AR, Arceci RJ, et al. Error reduction in pediatric chemotherapy: computerized order entry and failure modes and effects analysis. Arch Pediatr Adolesc Med. 2006;160(5):495-8. [pmid: 16651491]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
King Abby C, Ahn David K, Oliveira Brian M, et al. Promoting physical activity through hand-held computer technology. American Journal of Preventive Medicine. 2008;34(2):138-142. [pmid: 18201644]. Does not address patient-centered care
Kirigia JM, Seddoh A, Gatwiri D, et al. E-health: determinants, opportunities, challenges and the way forward for countries in the WHO African Region. BMC Public Health. 2005:5137. Does not address patient-centered care
Kitahata MM, Dillingham PW, Chaiyakunapruk N, et al. Electronic human immunodeficiency virus (HIV) clinical reminder system improves adherence to practice guidelines among the University of Washington HIV Study Cohort. Clin Infect Dis. 2003;36(6):803-11. [pmid: 12627367]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Knaup P, Pilz J, Thalheimer M. Can temporary paper-based patient records sensibly complete an electronic patient record. Stud Health Technol Inform. 2006:124207-12. Does not address patient-centered care
Knottnerus JA. Role of the electronic patient record in the development of general practice in The Netherlands. Methods Inf Med. 99;38(4–5):350-4. No original data Methods discussion, of development article
Kroeze W, Oenema A, Campbell M, et al. The efficacy of Web-based and print-delivered computer-tailored interventions to reduce fat intake: results of a randomized, controlled trial. J Nutr Educ Behav. 2008;40(4):226-36. [pmid: 18565463]. Does not address patient-centered care Other*
Kuiken TA, Amir H, Scheidt RA. Computerized biofeedback knee goniometer: acceptance and effect on exercise behavior in post-total knee arthroplasty rehabilitation. Arch Phys Med Rehabil. 2004;85(6):1026-30. [pmid: 15179662]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Kukafka R, Lussier YA, Eng P, et al. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp. 2002:410-4. [pmid: 12463857]. Other*
Kypri K, Langley JD, Saunders JB, et al. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. 2008;168(5):530-6. [pmid: 18332300]. Does not address patient-centered care Other*
Lafata JE, Baker AM, Divine GW, et al. The use of computerized birthday greeting reminders in the management of diabetes. J Gen Intern Med. 2002;17(7):521-30. [pmid: 12133142]. Does not address health IT
Lai TY, Larson EL, Rockoff ML, et al. User acceptance of HIV TIDES--Tailored Interventions for Management of Depressive Symptoms in persons living with HIV/AIDS. J Am Med Inform Assoc. 2008;15(2):217-26. [pmid: 18096915]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Larcher B, Berloffa F, Demichelis F, et al. An evaluation of the use of and user satisfaction with a teleconsultation system in oncology practice. J Telemed Telecare. 2002;8(Suppl):228-30. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Leatt P, Shea C, Studer M, et al. IT solutions for patient safety--best practices for successful implementation in healthcare. Healthc Q. 2006;9(1):94-104. [pmid: 16548440]. No original data
LeGrow G, Brandman D. Technology-driven care coordination: using health IT to support provider pay-for-performance. AHIP Cover. 58. 2006;47(1):56-60. [pmid: 16566493]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data
Lehoux P, Sicotte C, Lacroix A. Theory of use behind telehealth applications. Stud Health Technol Inform. 99:6429-38. Does not address patient-centered care No original data Other*
Lenz R, Blaser R, Beyer M, et al. IT support for clinical pathways--lessons learned. Int J Med Inform. Suppl 3. 2007;76:S397-402. [pmid: 17567529]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Leung GM, Yeung RYT, Lai TYY, et al. Physicians’ perceptions towards the impact of and willingness to pay for clinical computerization in Hong Kong. International Journal of Medical Informatics. 2004;73(5):403-414. [pmid: 15171982]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Deborah Levine, Jacqueline McCright, Loren Dobkin, et al. SEXINFO: A sexual health text messaging service for San Francisco youth. American Journal of Public Health. 2008;98(3):393-395. [pmid: 18235068]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data Other*
Li J, Jester JV, Cavanagh HD, et al. On-line 3-dimensional confocal imaging in vivo. Invest Ophthalmol Vis Sci. 2000;41(10):2945-53. [pmid: 10967049]. Does not address patient-centered care
Liddy C, Dusseault JJ, Dahrouge S, et al. Telehomecare for patients with multiple chronic illnesses: Pilot study. Can Fam Physician. 2008;54(1):58-65. [pmid: 18208957]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Lieberman DZ. Determinants of satisfaction with an automated alcohol evaluation program. Cyberpsychol Behav. 2003;6(6):677-82. [pmid: 14756935]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Lipman T. The doctor, his patient, and the computerized evidence-based guideline. J Eval Clin Pract. 2004;10(2):163-76. [pmid: 15189383]. No original data
Litvin CB, Ornstein SM, Anthony WE, et al. Quality improvement using electronic medical records: a case study of a high-performing practice. Top Health Inf Manage. 2001;22(2):59-64. [pmid: 11761793]. No original data Other*
Liu SA, Chiu YT, Lin WD, et al. Using information technology to reduce the inappropriate use of surgical prophylactic antibiotic. Eur Arch Otorhinolaryngol. 2008;265(9):1109-12. [pmid: 18246363]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Lium JT, Tjora A, Faxvaag A. No paper, but the same routines: a qualitative exploration of experiences in two Norwegian hospitals deprived of the paper based medical record. BMC Med Inform Decis Mak. 2008:82. Does not address patient-centered care
Loader Brian D, Mike Hardey, Leigh Keeble. Health informatics for older people: A review of ICT facilitated integrated care for older people. International Journal of Social Welfare. 2008;17(1):46-53. No original data
Long AJ, Chang P, Li YC, et al. The use of a CPOE log for the analysis of physicians’ behavior when responding to drug-duplication reminders. Int J Med Inform. 2008;77(8):499-506. [pmid: 18182321]. Other*
Lorig KR, Ritter PL, Laurent DD, et al. The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum. 2008;59(7):1009-17. [pmid: 18576310]. Does not address patient-centered care Other*
Lowes R. Switching from paper to computerized charts. Med Econ. 99;76(10):157-60. 165. 6. 169 passim. No original data Other*
Lowry J. The development of a telemedicine system for a centralized maxillofacial unit serving four towns. 2001:758-59. Does not address patient-centered care Other*
Maass G, Cortezzo M. Computerizing incident reporting at a community hospital. Jt Comm J Qual Improv. 2000;26(6):361-73. [pmid: 10840668]. Does not address patient-centered care Methods discussion, of development article
Maass G, Cortezzo M. Computerizing incident reporting at a community hospital. Jt Comm J Qual Improv. 2000;26(6):361-73. [pmid: 10840668]. Other*
Magnus M, Herwehe J, Proescholdbell RJ, et al. Guidelines for effective integration of information technology in the care of HIV-infected populations. J Public Health Manag Pract. 2007;13(1):39-48. [pmid: 17149099]. Does not address patient-centered care No original data
Magrabi F, Vickland V, Coiera E, et al. Online evidence in general practice -- trial of the QuickClinical evidence retrieval system. 2003:10-11. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Magrabi F, Westbrook JI, Coiera EW. What factors are associated with the integration of evidence retrieval technology into routine general practice settings. Int J Med Inform. 2007;76(10):701-9. [pmid: 16893677]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Maliff RP, Launders J. Using technology assessment as the picture archiving and communication system spreads outside radiology to the enterprise. J Digit Imaging. 2000;13(2 Suppl 1):114-6. [pmid: 10847377]. Does not address patient-centered care Methods discussion, of development article
Marang-van de, Mheen PJ, Stadlander MC, et al. Adverse outcomes in surgical patients: implementation of a nationwide reporting system. Qual Saf Health Care. 2006;15(5):320-4. [pmid: 17074866]. Does not address patient-centered care Other*
March S, Spence SH, Donovan CL. The Efficacy of an Internet-Based Cognitive-Behavioral Therapy Intervention for Child Anxiety Disorders. J Pediatr Psychol. 2008. Does not address patient-centered care Other*
Marcy TW, Skelly J, Shiffman RN, et al. Facilitating adherence to the tobacco use treatment guideline with computer-mediated decision support systems: physician and clinic office manager perspectives. Prev Med. 2005;41(2):479-87. [pmid: 15917044]. Does not address patient-centered care
Markwell DC. Messages for communication of electronic health care records in diabetic care. Diabetes Nutr Metab. 2000;13(4):210-4. [pmid: 10961488]. Does not address patient-centered care No original data
Marquez LO, Stewart H. Improving medical imaging report turnaround times: the role of technolgy. Radiol Manage. 2005;27(2):26-31. [pmid: 15898577]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Martin JB. Effectiveness, efficiency, and the value of IT. J Healthc Inf Manag. 2003;17(2):20-1. [pmid: 12698907]. No original data
Peter Martin, Nicole Draghic, Wiesmann William P. Remote access to medical specialists: Home Care Interactive Patient Management system. Proceedings of the 1999 Biomedical Diagnostic, Guidance, and Surgical-Assist Systems. January 26,1999 – January 27,1999. Proceedings of SPIE - The International Society for Optical Engineering. 99:3595101-108. Does not address health IT Methods discussion, of development article
Martin WE, Miller SC, Welch LC, et al. Improving access to hospice: the Physician Feedback and Reminders to Improve Access to Hospice (PFRIAH) study. Med Health R I. 2007;90(12):388-90. [pmid: 18314830]. Does not address health IT Does not address patient-centered care
Maslin AM, Baum M, Walker JS, et al. Using an interactive video disk in breast cancer patient support. Nurs Times. 98;94(44):52-5. Does not address health IT Other*
May JR. The electronic medical record: a valuable partner. J Med Pract Manage. 2005;21(2):100-2. [pmid: 16302440]. No original data
McAlearney AS, Chisolm DJ, Schweikhart S, et al. The story behind the story: physician skepticism about relying on clinical information technologies to reduce medical errors. Int J Med Inform. 2007;76(11–12):836-42. [pmid: 17112779]. Does not address patient-centered care
McCall K, Keen J, Farrer K, et al. Perceptions of the use of a remote monitoring system in patients receiving palliative care at home. International Journal of Palliative Nursing. 2008;14(9):426. [pmid: 19060793]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
McDermott RA, Schmidt BA, Sinha A, et al. Improving diabetes care in the primary healthcare setting: a randomised cluster trial in remote Indigenous communities. Med J Aust. 2001;174(10):497-502. [pmid: 11419768]. Does not address health IT
McEnery KW, Suitor CT, Hildebrand S, et al. Radiologist’s clinical information review workstation interfaced with digital dictation system. J Digit Imaging. 2000;13(2 Suppl 1):45-8. [pmid: 10847361]. Methods discussion, of development article
McKay HG, King D, Eakin EG, et al. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes care. 2001;24(8):1328-34. [pmid: 11473065]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
McMullin ST, Lonergan TP, Rynearson CS. Twelve-month drug cost savings related to use of an electronic prescribing system with integrated decision support in primary care. J Manag Care Pharm. 2005;11(4):322-32. [pmid: 15871643]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Yeh Mei-Ling, Chen Hsing-Hsia. A new multimedia-based instruction for hip arthroplasty in clinical practice. Computer Methods and Programs in Biomedicine. 2005;80(2):181-186. [pmid: 16182405]. Does not address health IT Study is NOT an RCT AND does not address barriers, facilitators or drivers
Melinkovich P, Hammer A, Staudenmaier A, et al. Improving pediatric immunization rates in a safety-net delivery system. Jt Comm J Qual Patient Saf. 2007;33(4):205-10. [pmid: 17441558]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Menachemi N, Struchen-Shellhorn W, Brooks RG, et al. Influence of pay-for-performance programs on information technology use among child health providers: the devil is in the details. Pediatrics. Suppl 2. 2009;123:S92-6. [pmid: 19088236]. Other
Meyer BC, Raman R, Hemmen T, et al. Efficacy of site-independent telemedicine in the STRokE DOC trial: a randomised, blinded, prospective study. Lancet Neurol. 2008;7(9):787-95. [pmid: 18676180]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Miller EA. Telemedicine and doctor-patient communication: a theoretical framework for evaluation. J Telemed Telecare. 2002;8(6):311-8. [pmid: 12537917]. No original data
Miller GC, Britt H, Valenti L, et al. Acceptability and feasibility of active computerised data collection for BEACH -- results of a longitudinal controlled trial. Bettering the Evaluation and Care of Health. 2003:127-128. Methods discussion, of development article
Miller RA, Gardner RM, Johnson KB, et al. Clinical decision support and electronic prescribing systems: a time for responsible thought and action. J Am Med Inform Assoc. 2005;12(4):403-9. [pmid: 15905481]. No original data Methods discussion, of development article
Miller RH, Sim I. Physicians’ use of electronic medical records: barriers and solutions. Health Aff (Millwood). 2004;23(2):116-26. [pmid: 15046136]. Methods discussion, of development article Other*
Mitchell P. Information systems. Quality information, quality care. Health Serv J. 98;108(5634). suppl 14-5. No original data Methods discussion, of development article Other*
Shoichi Miyahara, Masatsugu Tsuji, Chikako Iizuka, et al. On the Evaluation of Economic Benefits of Japanese Telemedicine and Factors for Its Promotion. Telemedicine and e-Health. 2006;12(6):691-697. [pmid: 17250491]. No original data
Mold JW, Aspy CA, Nagykaldi Z. Implementation of evidence-based preventive services delivery processes in primary care: an Oklahoma Physicians Resource/Research Network (OKPRN) study. J Am Board Fam Med. 2008;21(4):334-44. [pmid: 18612060]. Does not address patient-centered care Other*
Molinari DL, Berry J. Telehealth: the promise and the need to overcome the knowledge deficit barrier. Home Health Care Management & Practice. 99;11(6):36-41. Does not address patient-centered care
Mollon B, Holbrook AM, Keshavjee K, et al. Automated telephone reminder messages can assist electronic diabetes care. J Telemed Telecare. 2008;14(1):32-6. [pmid: 18318927]. Does not address health IT
Montori VM, Dinneen SF, Gorman CA, et al. The impact of planned care and a diabetes electronic management system on community-based diabetes care: the Mayo Health System Diabetes Translation Project. Diabetes Care. 2002;25(11):1952-7. [pmid: 12401738]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article Other*
Morgan GJ, Grant B, Craig B, et al. Supporting families of critically ill children at home using videoconferencing. Journal of telemedicine and telecare. Suppl. 2005;11:191-2. [pmid: 15969794]. Methods discussion, of development article Other*
Morin D, Saint-Laurent L, Bresse MP, et al. The benefits of a palliative care network: a case study in Quebec, Canada. Int J Palliat Nurs. 2007;13(4):190-6. [pmid: 17551423]. Does not address health IT
Morris AH. Developing and implementing computerized protocols for standardization of clinical decisions. Ann Intern Med. 2000;132(5):373-83. [pmid: 10691588]. Does not address health IT Other*
Morrison RS, Meier DE, Fischberg D, et al. Improving the management of pain in hospitalized adults. Arch Intern Med. 2006;166(9):1033-9. [pmid: 16682579]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Murtagh MJ, Thomson RG, May CR, et al. Qualitative methods in a randomised controlled trial: the role of an integrated qualitative process evaluation in providing evidence to discontinue the intervention in one arm of a trial of a decision support tool. Qual Saf Health Care. 2007;16(3):224-9. [pmid: 17545351]. Does not address health IT Does not address patient-centered care
Myers RE, Turner B, Weinberg D, et al. Impact of a physician-oriented intervention on follow-up in colorectal cancer screening. Prev Med. 2004;38(4):375-81. [pmid: 15020170]. Does not address health IT
Nelson N. Solving the remote access challenge. Off-site access to clinical information brings multiple benefits to one cardiology group. Healthc Inform. 2004;21(8):40. [pmid: 15373304]. No original data Other*
Neumann N, Kubler A. Training locked-in patients: a challenge for the use of brain-computer interfaces. IEEE Transactions on Neural Systems and Rehabilitation Engineering. 2003;11(2):169-172. [pmid: 12899265]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Nightingale PG, Adu D, Richards NT, et al. Implementation of rules based computerised bedside prescribing and administration: intervention study. BMJ. 2000;320(7237):750-3. [pmid: 10720357]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Nikula RE, Elberg PB, Svedberg HB. Informed decisions by clinicians are fundamental for EPR implementation. Int J Med Inform. 2000;58:59141-6. Does not address patient-centered care No original data
Nitrosi A, Borasi G, Nicoli F, et al. A filmless radiology department in a full digital regional hospital: quantitative evaluation of the increased quality and efficiency. J Digit Imaging. 2007;20(2):140-8. [pmid: 17318704]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Nobel JJ, Norman GK. Emerging information management technologies and the future of disease management. Dis Manag. 2003;6(4):219-31. [pmid: 14736346]. No original data Methods discussion, of development article
Nour El, Din MM. Physicians’ use of and attitudes toward electronic medical record system implemented at a teaching hospital in saudi arabia. J Egypt Public Health Assoc. 2007;82(5–6):347-64. [pmid: 18706293]. Does not address patient-centered care Study not written in English
Nyman MA, Murphy ME, Schryver PG, et al. Improving performance in diabetes care: a multicomponent intervention. Eff Clin Pract. 2000;3(5):205-12. [pmid: 11185325]. Does not address health IT No original data
Oberg E. Electronic health records: can technology help your practice?. Integrative Medicine: A Clinician’s Journal. 2007;6(6):44-48. No original data Methods discussion, of development article
Obstfelder A, Moen A. The electronic patient record in community health services--paradoxes and adjustments in clinical work. Stud Health Technol Inform. 2006:122626-31. Does not address patient-centered care
O’Connell R, Poljak A, Powsner S. Forms that Inform. Methods Inf Med. 2004;43(3):247-55. [pmid: 15227554]. Does not address health IT
Oenema A, Brug J, Dijkstra A, et al. Efficacy and use of an internet-delivered computer-tailored lifestyle intervention, targeting saturated fat intake, physical activity and smoking cessation: a randomized controlled trial. Ann Behav Med. 2008;35(2):125-35. [pmid: 18363076]. Does not address patient-centered care Other*
O’Meara E. The effects of electronic documentation in the ambulatory surgery setting. AORN J. 2007;86(6):970-9. [pmid: 18068402]. No original data
Ornstein S, Jenkins RG, Nietert PJ, et al. A multimethod quality improvement intervention to improve preventive cardiovascular care: a cluster randomized trial. Ann Intern Med. 2004;141(7):523-32. [pmid: 15466769]. Other*
Osborn CE. Practices and productivity in acute care facilities. J AHIMA. 2000;71(2):61-6. [pmid: 10977640]. Does not address patient-centered care
Ou MH, West GA, Lazarescu M, et al. Evaluation of TELEDERM for dermatological services in rural and remote areas. Artif Intell Med. 2008;44(1):27-40. [pmid: 18599276]. Does not address patient-centered care
Ou MH, West GA, Lazarescu M, et al. Evaluation of TELEDERM for dermatological services in rural and remote areas. Artif Intell Med. 2008;44(1):27-40. [pmid: 18599276]. Other*
Ozdas A, Miller RA. Care provider order entry (CPOE): a perspective on factors leading to success or to failure. Yearb Med Inform. 2007:128-37. [pmid: 17700915]. No original data
Palm JM, Colombet I, Sicotte C, et al. Determinants of user satisfaction with a Clinical Information System. AMIA Annu Symp Proc. 2006:614-8. [pmid: 17238414]. Does not address patient-centered care
Pare G. Implementing clinical information systems: a multiple-case study within a US hospital. Health Serv Manage Res. 2002;15(2):71-92. [pmid: 12028797]. Does not address patient-centered care Other*
Park WS, Kim JS, Chae YM, et al. Does the physician order-entry system increase the revenue of a general hospital. Int J Med Inform. 2003;71(1):25-32. [pmid: 12909155]. Does not address patient-centered care Methods discussion, of development article
Patten CA, Croghan IT, Meis TM, et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns. 2006;64(1–3):249-58. [pmid: 16616449]. Does not address patient-centered care Other*
Paul David L. Wicked decision problems in remote health care: Telemedicine as a tool for sensemaking. 99;153. No original data Methods discussion, of development article
Peters D, Pinto GJ, Harris G. Using a computer-based clinical management system to improve effectiveness of a homeopathic service in a fundholding general practice. Br Homeopath J. Suppl 1. 2000;89:S14-9. [pmid: 10939776]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Peterson C. Using technology to target disease management approaches. Healthplan. 98;39(3):15-9. No original data Other*
Phansalkar S, Weir CR, Morris AH, et al. Clinicians’ perceptions about use of computerized protocols: a multicenter study. Int J Med Inform. 2008;77(3):184-93. [pmid: 17409016]. Does not address patient-centered care Other*
Pickett SM, van der Heide GW. Medicolegal risk in telemedicine: risk control in teleradiology. Med J Aust. 99;171(10):563-5. Does not address patient-centered care Methods discussion, of development article
Picot J. Meeting the need for educational standards in the practice of telemedicine and telehealth. J Telemed Telecare. Suppl 2. 2000;6:S59-62. [pmid: 10975105]. No original data
Matthias Pinsker, Karin Schindler, Jurgen Morak, et al. Experiences using mobile phones as patient-terminal for telemedical home care and therapy monitoring of patients suffering from chronic diseases. 2008;5105:LNCS1305-1312. No original data Methods discussion, of development article Other*
Pirnejad H, Bal R, Berg M. Building an inter-organizational communication network and challenges for preserving interoperability. International Journal of Medical Informatics. 2008;77(12):818-827. [pmid: 18579436]. Does not address patient-centered care
Pizziferri L, Kittler AF, Volk LA, et al. Impact of an Electronic Health Record on oncologists’ clinic time. AMIA Annu Symp Proc. 2005:1083. [pmid: 16779370]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Polemi D, Varvitsiotis A. A framework for the security of telemedical services. Stud Health Technol Inform. 2000:7967-86. Does not address patient-centered care No original data
Poon EG, Gandhi TK, Sequist TD, et al. “I wish I had seen this test result earlier!”: Dissatisfaction with test result management systems in primary care. Arch Intern Med. 2004;164(20):2223-8. [pmid: 15534158]. Does not address health IT Study is NOT an RCT AND does not address barriers, facilitators or drivers
Poon EG, Jha AK, Christino M, et al. Assessing the level of healthcare information technology adoption in the United States: a snapshot. BMC Med Inform Decis Mak. 2006:61. Does not address patient-centered care
Prince SB, Herrin DM. The role of information technology in healthcare communications, efficiency, and patient safety: application and results. J Nurs Adm. 2007;37(4):184-7. [pmid: 17415105]. Does not address patient-centered care
Prince SB, Herrin DM. The role of information technology in healthcare communications, efficiency, and patient safety: application and results. J Nurs Adm. 2007;37(4):184-7. [pmid: 17415105]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data Other*
Prins C, Schellekens M. The chilling-effect of liability law on initiatives to enhance the reliability of on-line health-related information. Eur J Health Law. 2004;11(2):201-8. [pmid: 15387426]. Does not address health IT Does not address patient-centered care No original data
Quaglini S, Grandi M, Baiardi P, et al. A computerised guideline for pressure ulcer prevention. Stud Health Technol Inform. 99:68940-3. Does not address patient-centered care Methods discussion, of development article
Raisinghani MS, Young E. Personal health records: key adoption issues and implications for management. Int J Electron Healthc. 2008;4(1):67-77. [pmid: 18583296]. No original data Other*
Ralston James D, Revere Debra, Robins Lynne S, et al. Patients’ experience with a diabetes support programme based on an interactive electronic medical record: Qualitative study. BMJ British Medical Journal. 2004;328(7449):1159. Other*
Ramaprasad A, Gupta S, Sangareddy SRP, et al. Bridging the digital divide in e-health applications leading the way to an informed patient. International Journal of Healthcare Technology and Management. 2007;8(1):120-140. Methods discussion, of development article
Rankin SB, White BA. Healthcare IT and connecticut’s acute-care hospitals. An analysis of trends, barriers, impacts and perspectives. J Healthc Inf Manag. 2008;22(3):57-63. [pmid: 19267033]. Does not address patient-centered care
Raschke RA, Gollihare B, Wunderlich TA, et al. A computer alert system to prevent injury from adverse drug events: development and evaluation in a community teaching hospital. JAMA. 98;280(15):1317-20. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Redfern RO, Horii SC, Feingold E, et al. Radiology workflow and patient volume: effect of picture archiving and communication systems on technologists and radiologists. J Digit Imaging. 2000;13(2 Suppl 1):97-100. [pmid: 10847373]. Does not address patient-centered care Other*
Reuss E, Menozzi M, Buchi M, et al. Information access at the point of care: what can we learn for designing a mobile CPR system. Int J Med Inform. 2004;73(4):363-9. [pmid: 15135755]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Michael Rich. Health Literacy via Media Literacy: Video Intervention/Prevention Assessment. American Behavioral Scientist. 2004;48(2):165-188. Does not address patient-centered care No original data
Riper H, Kramer J, Smit F, et al. Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction. 2008;103(2):218-27. [pmid: 18199300]. Does not address health IT Does not address patient-centered care Other*
Rivera ML, Donnelly J, Parry BA, et al. Prospective, randomized evaluation of a personal digital assistant-based research tool in the emergency department. BMC Med Inform Decis Mak. 2008:83. Does not address patient-centered care
Robinson JC, Casalino LP, Gillies RR, et al. Financial incentives, quality improvement programs, and the adoption of clinical information technology. Med Care. 2009;47(4):411-7. [pmid: 19238102]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Rodriguez-Ascaso A, Villalar JL, Arredondo MT, et al. An assistive home care environment for people with special needs. J Telemed Telecare. Suppl. 2002;8:272-4. No original data Other*
Roemer LK, Rocha RA, Del Fiol G, et al. Knowledge management strategies: Enhancing knowledge transfer to clinicians and patients. Stud Health Technol Inform. 2006:122440-4. Does not address health IT Does not address patient-centered care Methods discussion, of development article
Romlein J, Lyche D, Chacko A, et al. New facility picture archiving and communication system implementation strategy. J Digit Imaging. 2000;13(2 Suppl 1):3-5. [pmid: 10847351]. Methods discussion, of development article
Rose AF, Schnipper JL, Park ER, et al. Using qualitative studies to improve the usability of an EMR. J Biomed Inform. 2005;38(1):51-60. [pmid: 15694885]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Ross JD, Copas A, Stephenson J, et al. Optimizing information technology to improve sexual health-care delivery: public and patient preferences. Int J STD AIDS. 2007;18(7):440-5. [pmid: 17623499]. Other*
Ross SE, Moore LA, Earnest MA, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Rostad L, Nytro O. Towards dynamic access control for healthcare information systems. Stud Health Technol Inform. 2008:136703-8. Does not address patient-centered care Methods discussion, of development article
Rostom A, O’Connor A, Tugwell P, et al. A randomized trial of a computerized versus an audio-booklet decision aid for women considering post-menopausal hormone replacement therapy. Patient Educ Couns. 2002;46(1):67-74. [pmid: 11804772]. Does not address patient-centered care
Rothschild JM, Lee TH, Bae T, et al. Clinician use of a palmtop drug reference guide. J Am Med Inform Assoc. 2002;9(3):223-9. [pmid: 11971883]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Rovniak Liza S, Hovell Melbourne F, Wojcik Janet R, et al. Enhancing theoretical fidelity: An e-mail-based walking program demonstration. American Journal of Health Promotion. 2005;20(2):85-95. [pmid: 16295700]. Does not address health IT Does not address patient-centered care
Ruttenberg A, Clark T, Bug W, et al. Advancing translational research with the Semantic Web. BMC Bioinformatics. 2007;8. Suppl 3S2. Does not address patient-centered care
Saleem JJ, Patterson ES, Militello L, et al. Impact of clinical reminder redesign on learnability, efficiency, usability, and workload for ambulatory clinic nurses. J Am Med Inform Assoc. 2007;14(5):632-40. [pmid: 17600106]. Does not address patient-centered care Other*
Sallis James F, Kevin Patrick, Calfas Karen J, et al. A multi-media behavior change program for nutrition and physical activity in primary care: PACE+ for adults. Homeostasis in Health and Disease. 99;39(5):196-202. Does not address health IT Study is NOT an RCT AND does not address barriers, facilitators or drivers
Sandberg LA. Telemedicine continues to wrestle wicked problems: reimbursement, licensure, and bandwidth rules (or is it compliance?). Health Manag Technol 99. 20(1):134-133. No original data Methods discussion, of development article Other*
Sarkar U, Piette JD, Gonzales R, et al. Preferences for self-management support: findings from a survey of diabetes patients in safety-net health systems. Patient Educ Couns. 2008;70(1):102-10. [pmid: 17997264]. Other*
Sarkisian CA, Brusuelas RJ, Steers WN, et al. Using focus groups of older African Americans and Latinos with diabetes to modify a self-care empowerment intervention. Ethn Dis. 2005;15(2):283-91. [pmid: 15825975]. Does not address health IT
Sausser GD. Thin is in: web-based systems enhance security, clinical quality. Healthc Financ Manage. 2003;57(7):86-9. [pmid: 12866161]. No original data
Scalzi G, Sostman HD. Image is everything. New York Hospital’s institution-wide digital imaging lowers costs and improves care. Healthc Inform. 98;15(3):91-4. No original data Methods discussion, of development article
Scandurra I, Hagglund M, Engstrom M, et al. Heuristic evaluation performed by usability-educated clinicians: education and attitudes. Stud Health Technol Inform. 2007:130205-16. Does not address patient-centered care
Scanlon M. Computer physician order entry and the real world: we’re only humans. Jt Comm J Qual Saf. 2004;30(6):342-6. [pmid: 15208984]. Does not address patient-centered care No original data
Schaper LK, Pervan GP. qICT and OTs: a model of information and communication technology acceptance and utilisation by occupational therapists. Int J Med Inform. Suppl 1. 2007;76:S212-21. [pmid: 16828335]. Does not address patient-centered care Methods discussion, of development article
Scharfe-Pretino T, Von Bacho S. Nursing Intranet Web site: a critical communication tool. J Nurs Care Qual. 2006;21(2):104-9. [pmid: 16540775]. Does not address patient-centered care
Schillinger D, Handley M, Wang F, et al. Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial. Diabetes Care. 2009;32(4):559-66. [pmid: 19131469]. Does not address health IT
Schneider AJ, Mataix-Cols D, Marks IM, et al. Internet-guided self-help with or without exposure therapy for phobic and panic disorders. Psychother Psychosom. 2005;74(3):154-64. [pmid: 15832066]. Does not address patient-centered care Other*
Schneider M. Clinical information systems: strategic imperatives driving IDNs forward. Med Netw Strategy Rep. 8. 8. 99(11):1-10. 12. No original data
Schuerenberg BK. Making sense of business analytics. Organizations seek to gain efficiencies using I.T. to measure clinical and financial performance. Health Data Manag. 2007;15(4):34-36. 38 passim. Does not address patient-centered care No original data
Schwaab B, Katalinic A, Riedel J, et al. Prehospital diagnosis of myocardial ischaemia by telecardiology: safety and efficacy of a 12-lead electrocardiogram, recorded and transmitted by the patient. Journal of Telemedicine and Telecare. 2005;11(1):41-44. [pmid: 15829043]. Does not address patient-centered care Other*
Sclafani AP, Romo T 3rd. A brave new world: telemedicine and the facial plastic surgeon. Facial Plast Surg. 99;15(2):153-9. Does not address patient-centered care No original data
Sek AC, Cheung NT, Choy KM, et al. A territory-wide electronic health record--from concept to practicality: the Hong Kong experience. Stud Health Technol Inform. 2007;129(Pt 1):293-6. [pmid: 17911725]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Severson HH, Gordon JS, Danaher BG, et al. ChewFree.com: evaluation of a Web-based cessation program for smokeless tobacco users. Nicotine Tob Res. 2008;10(2):381-91. [pmid: 18236303]. Does not address patient-centered care Other*
Shaw P, Lundy M, Larson A. Rural health professionals’ use of a clinical information web site in Western Australia. Aust J Rural Health. 2006;14(1):36-8. [pmid: 16426432]. Does not address patient-centered care No original data
Shedlosky-Shoemaker R, Sturm AC, Saleem M, et al. Tools for assessing readability and quality of health-related Web sites. J Genet Couns. 2009;18(1):49-59. [pmid: 18937063]. Does not address health IT Does not address patient-centered care Other*
Shieh YY, Tsai FY, Anavim A, et al. Mobile healthcare: the opportunities and challenges. Int J Electron Healthc. 2008;4(2):208-19. [pmid: 18676344]. Other*
Short BC, Ballantyne CM. Quality assessment and lipid management: considerations for computer databases for tracking patients. Am J Cardiol. 2000;85(3A):52A-56A. Does not address patient-centered care Other*
Simkins CV, Wenzloff NJ. Evaluation of a computerized reminder system in the enhancement of patient medication refill compliance. Drug Intell Clin Pharm. 86;20(10):799-802. Does not address health IT Study published before 2000
Simon C, Acheson L, Burant C, et al. Patient interest in recording family histories of cancer via the Internet. Genet Med. 2008;10(12):895-902. [pmid: 19092442]. Other*
Simpson D, Nicholas J, Cooper K. The use of information technology in managing patients with coronary heart disease. Informatics in Primary Care. 2002;10(1):15-18. No original data Other*
Singh R, Servoss T, Kalsman M, et al. Estimating impacts on safety caused by the introduction of electronic medical records in primary care. Inform Prim Care. 2004;12(4):235-42. [pmid: 15808025]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
Sinha U, Dai B, Johnson DB, et al. Interactive software for generation and visualization of structured findings in radiology reports. AJR Am J Roentgenol. 2000;175(3):609-12. [pmid: 10954439]. Does not address patient-centered care
Sintchenko V, Coiera E. Developing decision support systems in clinical bioinformatics. Methods Mol Med. 2008:141331-51. No original data
Sittig DF, Krall M, Kaalaas-Sittig J, et al. Emotional aspects of computer-based provider order entry: a qualitative study. J Am Med Inform Assoc. 2005;12(5):561-7. [pmid: 15905478]. Does not address patient-centered care
Siwicki B. Telemedicine providers’ progress impeded at the border. The need for physicians to obtain a medical license in every state in which they practice slows the growth of telemedicine. Health Data Manag. 99;7(5):94-6. 98. 100. 2. No original data
Sjogren LH, Tornqvist H, Schwieler A, et al. The potential of telemedicine: barriers, incentives and possibilities in the implementation phase. 2001:712-13. Does not address patient-centered care Other*
Skarulis P, Brill J, Lehman M. Rush physician order entry: from physician resistors to physician champions. Electronic Healthcare. 2003;2(1):14-21. Does not address patient-centered care Other*
Skolnik NS, Willyard K, Cohen H. Handheld computers: revolutionizing clinical data management. Family Practice Recertification. 2001;23(5):23. No original data
Sligo FX, Jameson AM. The knowledge-behavior gap in use of health information. Journal of the American Society for Information Science. 2000;51(9):858-869. Does not address health IT
Smith DH, Perrin N, Feldstein A, et al. The impact of prescribing safety alerts for elderly persons in an electronic medical record: an interrupted time series evaluation. Arch Intern Med. 2006;166(10):1098-104. [pmid: 16717172]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Smith KE, Levine BA, Clement SC, et al. Impact of MyCareTeam for poorly controlled diabetes mellitus. Diabetes Technol Ther. 2004;6(6):828-35. [pmid: 15684636]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Smith WJ. A computerized database assists in the management of clinical trials. Oncol Nurs Forum. 2000;27(1):28-9. [pmid: 10660919]. No original data Other*
Snyder-Halpern R, Hoyman K. Clinical information system implementation. Challenges across two merged hospitals. Comput Nurs. 2000;18(4):157-61. [pmid: 10939184]. Does not address patient-centered care
Snyder-Halpern R, Hoyman K. Clinical information system implementation. Challenges across two merged hospitals. Comput Nurs. 2000;18(4):157-61. [pmid: 10939184]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Sokol AJ, Molzen CJ. The changing standard of care in medicine: E-health, medical errors, and technology add new obstacles. Journal of Legal Medicine. 2002;23(4):449-490. [pmid: 12495542]. No original data Other*
Soman S, Zasuwa G, Yee J. Automation, decision support, and expert systems in nephrology. Adv Chronic Kidney Dis. 2008;15(1):42-55. [pmid: 18155109]. No original data Methods discussion, of development article
Sood SP. India telemedicine venture seeks to improve care, increase access. Spurred by government initiatives, private industry invests in linked hospital network. Telemed Today. 2002;9(3):25-6. [pmid: 12528481]. No original data Methods discussion, of development article
Soopramanien A, Pain H, Stainthorpe A, et al. Using telemedicine to provide post-discharge support for patients with spinal cord injuries. Journal of telemedicine and telecare. Suppl. 2005;11:168-70. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Sorenson L. Computerized incident reporting: an example of healthcare IT for the 21st century. J Healthc Risk Manag. 2001;21(2):15-20. [pmid: 11411061]. No original data
Spek V, Cuijpers P, Nyklicek I, et al. One-year follow-up results of a randomized controlled clinical trial on internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years. Psychol Med. 2008;38(5):635-9. [pmid: 18205965]. Does not address health IT Does not address patient-centered care Other*
Spittaels H, De Bourdeaudhuij I, Brug J, et al. Effectiveness of an online computer-tailored physical activity intervention in a real-life setting. Health education research. 2007;22(3):385-96. [pmid: 16971674]. Other*
Sprague L. Electronic health records: How close? How far to go. NHPF Issue Brief. 2004;800:1-17. [pmid: 15470818]. No original data
Staccini P, Joubert M, Fieschi D, et al. Confidentiality issues within a clinical information system: moving from data-driven to event-driven design. Methods Inf Med. 38. 99(4–5):298-302. No original data Methods discussion, of development article
Stamm B, Perednia Hudnall, Douglas A. Evaluating psychosocial aspects of telemedicine and telehealth systems. Professional Psychology: Research and Practice. 2000;31(2):184-189. Methods discussion, of development article
Steuten L, Palmer S, Vrijhoef B, et al. Cost-utility of a disease management program for patients with asthma. Int J Technol Assess Health Care. 2007;23(2):184-91. [pmid: 17493304]. Does not address health IT Study is NOT an RCT AND does not address barriers, facilitators or drivers
Stevens VJ, Funk KL, Brantley PJ, et al. Design and implementation of an interactive website to support long-term maintenance of weight loss. Journal of medical Internet research. 2008;1(1):e1. [pmid: 18244892]. Does not address health IT Does not address patient-centered care
Stoicu-Tivadar L, Stoicu-Tivadar V. Human-computer interaction reflected in the design of user interfaces for general practitioners. Int J Med Inform. 2006;75(3–4):335-42. [pmid: 16188492]. Methods discussion, of development article Other*
Stone AA, Shiffman S, Schwartz JE, et al. Patient compliance with paper and electronic diaries. Control Clin Trials. 2003;24(2):182-99. [pmid: 12689739]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Strating D, MacGregor J, Campbell N. Bridging information “islands”: designing an electronic health record that meets clinical needs. Healthc Q. 2006;9(2):94-8. [pmid: 16640139]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data
Strating D, MacGregor J, Campbell N. Bridging information “islands”: designing an electronic health record that meets clinical needs. Healthc Q. 2006;9(2):94-8. [pmid: 16640139]. Other*
Strecher VJ, McClure JB, Alexander GL, et al. Web-based smoking-cessation programs: results of a randomized trial. Am J Prev Med. 2008;34(5):373-81. [pmid: 18407003]. Does not address patient-centered care Other*
Strecher VJ, McClure J, Alexander G, et al. The role of engagement in a tailored web-based smoking cessation program: randomized controlled trial. J Med Internet Res. 2008;10(5):e36. [pmid: 18984557]. Does not address patient-centered care Other*
Stredney D, Agrawal A, Barber D, et al. Interactive medical data on demand: a high-performance imaged-based approach across heterogeneous environments. Stud Health Technol Inform. 2000:70327-33. Does not address patient-centered care
Street RL, Wheeler EJ, McCaughan WT. Specialist-primary care provider-patient communication in telemedical consultations. Telemedicine Journal. 2000;6(1):45-54. Does not address patient-centered care No original data
Stutman HR, Fineman R, Meyer K, et al. Optimizing the acceptance of medication-based alerts by physicians during CPOE implementation in a community hospital environment. AMIA Annu Symp Proc. 2007:701-5. [pmid: 18693927]. Other
Subramanian S, Hoover S, Gilman B, et al. Computerized physician order entry with clinical decision support in long-term care facilities: costs and benefits to stakeholders. J Am Geriatr Soc. 2007;55(9):1451-7. [pmid: 17915344]. No original data
Sutton DR, Taylor P, Earle K. Evaluation of PROforma as a language for implementing medical guidelines in a practical context. BMC Med Inform Decis Mak. 2006:620. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data
Szilagyi PG, Schaffer S, Barth R, et al. Effect of telephone reminder/recall on adolescent immunization and preventive visits: results from a randomized clinical trial. Arch Pediatr Adolesc Med. 2006;160(2):157-63. [pmid: 16461871]. Does not address health IT
Take care: technology raises liability questions: plan carefully to reduce risks. Case Management Advisor. 2000;11(10):167. No original data
Tang PC, Black W, Young CY. Proposed criteria for reimbursing eVisits: content analysis of secure patient messages in a personal health record system. AMIA Annu Symp Proc. 2006:764-8. [pmid: 17238444]. Does not address patient-centered care
Tang PC, Black W, Young CY. Proposed criteria for reimbursing eVisits: content analysis of secure patient messages in a personal health record system. AMIA Annu Symp Proc. 2006:764-8. [pmid: 17238444]. Other*
Tange H, Van Der, Linden H, et al. Towards a PropeR combination of patient records and protocols. Int J Med Inform. 2003;70(2–3):141-8. [pmid: 12909165]. Does not address patient-centered care No original data
Tanner JL, Craig CB, Bartolucci AA, et al. The effect of a self-monitoring tool on self-efficacy, health beliefs, and adherence in patients receiving hemodialysis. J Ren Nutr. 98;8(4):203-11. Does not address health IT
Tarlow BJ, Mahoney DF. Parity in computer-based health education: designing culturally relevant Alzheimer’s disease information. Health Informatics Journal. 2005;11(3):211-224. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Ten Hoopen AJ, Zanstra PE, Van der, et al. Barriers integrating dedicated software for quality management in pain centres. Stud Health Technol Inform. 2006:124257-62. Does not address patient-centered care Other*
Ten Wolde GB, Dijkstra A, van Empelen P, et al. Long-term effectiveness of computer-generated tailored patient education on benzodiazepines: a randomized controlled trial. Addiction. 2008;103(4):662-70. [pmid: 18339112]. Does not address patient-centered care Other*
Terry NP. An eHealth diptych: the impact of privacy regulation on medical error and malpractice litigation. Am J Law Med. 2001;27(4):361-419. [pmid: 11837142]. No original data
Thomason CL. Implementation and clinical use of portal imaging. Cancer Treat Res. 98:9369-99. Does not address patient-centered care Other*
Thomson R, Robinson A, Greenaway J, et al. Development and description of a decision analysis based decision support tool for stroke prevention in atrial fibrillation. Qual Saf Health Care. 2002;11(1):25-31. [pmid: 12078365]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Tobacman Joanne K, Pamella Kissinger, Marilyn Wells, et al. Implementation of personal health records by case managers in a VAMC general medicine clinic. Patient Education and Counseling. 2004;54(1):27-33. [pmid: 15210257]. Does not address health IT
Toth-Pal E, Nilsson GH, Furhoff AK. Clinical effect of computer generated physician reminders in health screening in primary health care--a controlled clinical trial of preventive services among the elderly. Int J Med Inform. 2004;73(9–10):695-703. [pmid: 15325326]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Toth-Pal E, Wardh I, Strender LE, et al. Implementing a clinical decision-support system in practice: a qualitative analysis of influencing attitudes and characteristics among general practitioners. Inform Health Soc Care. 2008;33(1):39-54. [pmid: 18604761]. Does not address patient-centered care
Townes PG, Benson DS, Johnston P, et al. Making EMRs really work: the Southeast Health Center experience. J Ambul Care Manage. 2000;23(2):43-52. [pmid: 10848392]. Does not address patient-centered care Methods discussion, of development article
Tully M. The impact of information technology on the performance of clinical pharmacy services. J Clin Pharm Ther. 2000;25(4):243-9. [pmid: 10971774]. No original data
Tuttelmann F, Luetjens CM, Nieschlag E. Optimising workflow in andrology: a new electronic patient record and database. Asian J Androl. 2006;8(2):235-41. [pmid: 16491277]. Does not address patient-centered care Other*
Unutzer J, Choi Y, Cook IA, et al. A web-based data management system to improve care for depression in a multicenter clinical trial. Psychiatr Serv. 2002;53(6):671-3. 678. [pmid: 12045303]. No original data
van der, Meijden MJ, Tange H, et al. Development and implementation of an EPR: how to encourage the user. Int J Med Inform. 2001;64(2–3):173-85. [pmid: 11734384]. Does not address patient-centered care Study is NOT an RCT AND does not address barriers, facilitators or drivers
van Keulen HM, Mesters I, Brug J, et al. Vitalum study design: RCT evaluating the efficacy of tailored print communication and telephone motivational interviewing on multiple health behaviors. BMC public health. 2008:8216. Other*
van Walraven C, Laupacis A, Seth R, et al. Dictated versus database-generated discharge summaries: a randomized clinical trial. CMAJ. 99;160(3):319-26. Does not address patient-centered care
van Wijk MA, van der, Lei J, et al. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837]. Does not address patient-centered care
Van Wyk JT, Van Wijk MA, Moorman PW, et al. Cholgate - a randomized controlled trial comparing the effect of automated and on-demand decision support on the management of cardiovascular disease factors in primary care. AMIA Annu Symp Proc. 2003:1040. [pmid: 14728543]. Methods discussion, of development article Other*
Varonen H, Kortteisto T, Kaila M. What may help or hinder the implementation of computerized decision support systems (CDSSs): a focus group study with physicians. Fam Pract. 2008;25(3):162-7. [pmid: 18504253]. Does not address patient-centered care
Vaughan NJ, Cashman SJ, Cavan DA, et al. A detailed examination of the clinical terms and concepts required for communication by electronic messages in diabetes care. Diabetes Nutr Metab. 2000;13(4):201-9. [pmid: 10961487]. Does not address patient-centered care No original data
Veltri G. Transforming Healthcare. A top U.S. hospital implements CPOE and improves patient safety while dramatically reducing turn-around time. Health Manag Technol. 18. 2008;29(8):14-9. [pmid: 18712032]. Study is NOT an RCT AND does not address barriers, facilitators or drivers No original data Other*
Verheijden M, Bakx JC, Akkermans R, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. 2004;6(4):e44. [pmid: 15631968]. Does not address patient-centered care
Villani A, Malfatto G, Della Rosa F, et al. Disease management for heart failure patients: role of wireless technologies for telemedicine. The ICAROS project. Giornale italiano di cardiologia (2006). 2007;8(2):107-14. [pmid: 17402355]. Study not written in English
Vogt TM, Aickin M, Ahmed F, et al. The Prevention Index: using technology to improve quality assessment. Health Serv Res. 2004;39(3):511-30. [pmid: 15149476]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Wahls T, Haugen T, Cram P. The continuing problem of missed test results in an integrated health system with an advanced electronic medical record. Joint Commission Journal on Quality & Patient Safety. 2007;33(8):485-492. [pmid: 17724945]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Walker EA, Schechter CB, Caban A, et al. Telephone intervention to promote diabetic retinopathy screening among the urban poor. American journal of preventive medicine. 2008;34(3):185-91. [pmid: 18312805]. Does not address health IT
Walker JM. Electronic medical records and health care transformation. Health Aff (Millwood). 2005;24(5):1118-20. [pmid: 16162552]. No original data
Wang SJ, Middleton B, Prosser LA, et al. A cost-benefit analysis of electronic medical records in primary care. Am J Med. 2003;114(5):397-403. [pmid: 12714130]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Wangberg SC. An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res. 2008;23(1):170-9. [pmid: 17412717]. Does not address patient-centered care
Warren JR, Beliakov GV, Noone JT, et al. Chronic disease coordinated care planning: flexible, task-centered decision support. Top Health Inf Manage. 99;20(2):52-68. No original data Methods discussion, of development article
Waters R. Risk management for telemedicine providers: how to stay out of jail. Six standards define whether arrangements fall within safe harbors. Telemed Today. 2002;9(3):21-4. [pmid: 12528480]. No original data Other*
Weinert C, Cudney S, Hill W. Retention in a computer-based outreach intervention for chronically ill rural women. Appl Nurs Res. 2008;21(1):23-9. [pmid: 18226760]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Weinert C, Hill W. Computer-based health education for rural women: knowledge gained. Communicating Nursing Research. 2005:38284. No original data Other*
Weinert C. Social support in cyberspace for women with chronic illness. Rehabilitation Nursing. 2000;25(4):129. Study is NOT an RCT AND does not address barriers, facilitators or drivers Methods discussion, of development article
Weingart SN, Hamrick HE, Tutkus S, et al. Medication safety messages for patients via the web portal: the MedCheck intervention. Int J Med Inform. 2008;77(3):161-8. [pmid: 17581772]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Weingart SN, Toth M, Sands DZ, et al. Physicians’ decisions to override computerized drug alerts in primary care. Arch Intern Med. 2003;163(21):2625-31. [pmid: 14638563]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Weiss JB, Lorenzi NM. Challenges of social networking technologies for cancer care and social support. AMIA Annu Symp Proc. 2007:1151. [pmid: 18694247]. Study is NOT an RCT AND does not address barriers, facilitators or drivers Other*
Weitzel JA, Bernhardt JM, Usdan S, et al. Using wireless handheld computers and tailored text messaging to reduce negative consequences of drinking alcohol. Journal of studies on alcohol and drugs. 2007;68(4):534-7. [pmid: 17568957]. Other*
Whittaker SL, Adkins S, Phillips R, et al. Success factors in the long-term sustainability of a telediabetes programme. Journal of Telemedicine and Telecare. 2004;10(2):84-88. [pmid: 15068643]. No original data
Whitty P, Eccles MP, Hawthorne G, et al. Improving services for people with diabetes: lessons from setting up the DREAM trial. Practical Diabetes International. 2004;21(9):323-328. No original data Methods discussion, of development article
Wiecha JM, Adams WG. BostonBreathes: an RCT to improve pediatric asthma care with a home-based interactive website for patient education, monitoring, and clinical teamwork. AMIA Annu Symp Proc. 2007:1154. [pmid: 18694250]. Other*
Wiederhold BK, Jang DP, Gevirtz RG, et al. The treatment of fear of flying: a controlled study of imaginal and virtual reality graded exposure therapy. IEEE Transactions on Information Technology in Biomedicine. 2002;6(3):218-223. [pmid: 12381038]. Does not address patient-centered care
Wiljer D, Bogomilsky S, Catton P, et al. Getting results for hematology patients through access to the electronic health record. Can Oncol Nurs J. 2006;16(3):154-64. [pmid: 17523576]. Study is NOT an RCT AND does not address barriers, facilitators or drivers
Wilson JW, Oyen LJ, Ou NN, et al. Hospital rules-based system: the next generation of medical informatics for patient safety. Am J Health Syst Pharm. 2005;62(5):499-505. [pmid: 15745913]. Does not address patient-centered care No original data
Wilt DH, Muthig BA. Crossing barriers: EMR implementation across a nationwide continuum of care. J Healthc Inf Manag. 2008;22(2):23-6. [pmid: 19266991]. Does not address patient-centered care No original data Methods discussion, of development article
Laraine Winter, Gitlin Laura N. Evaluation of a Telephone-Based Support Group Intervention for Female Caregivers of Community-Dwelling Individuals with Dementia. American Journal of Alzheimer’s Disease and Other Dementias. 2007;21(6):391-397. Does not address health IT Does not address patient-centered care
Yam CS, Rofsky N, Kruskal J, et al. Development of a radiology report monitoring system for case tracking. AJR Am J Roentgenol. 2005;184(1):343-6. [pmid: 15615999]. Does not address patient-centered care No original data Methods discussion, of development article
Yang M, Brown MM, Trohimovich B, et al. The effect of bar code-enabled point of care technology on medication administration errors. Health IT Advisory Report. 2002;3(2):10-17. Other*
Yusof K, Neoh KH, bin Hashim MA, et al. Role of teleconsultation in moving the healthcare system forward. Asia Pac J Public Health. 2002;14(1):29-34. [pmid: 12597515]. No original data Methods discussion, of development article
Zafar A. A prototype user interface for a mobile electronic clinical note entry system. AMIA Annu Symp Proc. 2005:1165. [pmid: 16779451]. Methods discussion, of development article Other*
Faika Zanjani, Bree Miller, Nicholas Turiano, et al. Effectiveness of telephone-based referral care management, a brief intervention to improve psychiatric treatment engagement. Psychiatric Services. 2008;59(7):776-781. [pmid: 18586995]. Does not address health IT
Lori Zeman, Lackman Johnson, Arfken David, et al. Lessons learned: Challenges implementing a personal digital assistant (PDA) to assess behavioral health in primary care. Families, Systems, & Health. 2006;24(3):286-298. No original data Methods discussion, of development article
Zhang J, Stahl JN, Huang HK, et al. Real-time teleconsultation with high-resolution and large-volume medical images for collaborative healthcare. IEEE Trans Inf Technol Biomed. 2000;4(2):178-85. [pmid: 10866418]. Does not address patient-centered care Other*
Zurita L, Nohr C. Patient opinion--EHR assessment from the users perspective. Stud Health Technol Inform. 2004;107(Pt 2):1333-6. [pmid: 15361031]. Does not address patient-centered care No original data
Drug news. Medication safety: e-prescribing systems dramatically cut drug errors. Nursing. 2010;40(6):17. No Original data
Using data collection to improve electronic medication reconciliation. Joint Commission Benchmark. 2009;11(3):3-4. No Original Data
Alpay LL, Henkemans OB, Otten W, R÷vekamp TAJM, Dumay ACM. E-health applications and services for patient empowerment: Directions for best practices in the Netherlands. Telemedicine and E-Health. 2010;16(7):787-91. [pmid: 20815745]. No original data
Ando K, Koyama J, Abe Y, et al. Feasibility evaluation of a remote monitoring system for implantable cardiac devices in Japan. Int Heart J. 2011;52(1):39-43. [pmid: 21321467]. Development study
Avery AJ, Rodgers S, Cantrill JA, et al. Protocol for the PINCER trial: a cluster randomised trial comparing the effectiveness of a pharmacist-led IT-based intervention with simple feedback in reducing rates of clinically important errors in medicines management in general practices. Trials. 2009;10:28. [pmid: 19409095]. Not patient centered care No original data
Belden CM, Proeschold-Bell RJ. A comparison of the adoption of electronic health records in North Carolina and South Carolina HIV systems. South Med J. 2010;103(11):1115-8. [pmid: 20859247]. No patient centered care.
Bendixen RM, Levy CE, Olive ES, Kobb RF, Mann WC. Cost effectiveness of a telerehabilitation program to support chronically ill and disabled elders in their homes. Telemedicine and E-Health. 2009;15(1):31-8. [pmid: 19199845]. Applies to KQ1 but is not an RCT
Bloom MV, Huntington MK. Faculty, resident, and clinic staff’s evaluation of the effects of EHR implementation. Fam Med. 2010;42(8):562-6. [pmid: 20830621]. No patient centered care.
Cardozo L, Steinberg J. Telemedicine for recently discharged older patients. Telemedicine and E-Health. 2010;16(1):49-55. [pmid: 20064067]. Not a study of health IT
Chang J-Y, Chen L-K, Chang CC. Perspectives and expectations for telemedicine opportunities from families of nursing home residents and caregivers in nursing homes. International Journal of Medical Informatics. 2009;78(7):494-502. [pmid: 19345640]. No original data
Chang J-Y, Chen L-K, Chang CC. Perspectives and expectations for telemedicine opportunities from families of nursing home residents and caregivers in nursing homes. International Journal of Medical Informatics. 2009;78(7):494-502. [pmid: 19345640]. Not a study of health IT
Cherry BJ, Ford EW, Peterson LT. Experiences with electronic health records: early adopters in long-term care facilities. Health Care Manage Rev. 2011;36(3):265-74. [pmid: 21646885]. No patient centered care
Chou HK, Lin IC, Woung LC, Tsai MT. Engagement in E-Learning Opportunities: An Empirical Study on Patient Education using Expectation Confirmation Theory. J Med Syst. 2010. Not a study of health IT
Christian K, Haight T. Improving communication using a cancer treatment schedule tool. Oncology Nursing Forum. 2009;36(3):15. No patient centered care.
Chumbler NR, Rose DK, Griffiths P, et al. Study protocol: home-based telehealth stroke care: a randomized trial for veterans. Trials. 2010;11:74. [pmid: 20591171]. No patient centered care.
Devine EB, Williams EC, Martin DP, et al. Prescriber and staff perceptions of an electronic prescribing system in primary care: a qualitative assessment. BMC Medical Informatics and Decision Making. 2010;10:72(12). No patient centered care.
Doran D, Paterson J, Clark C, et al. A pilot study of an electronic interprofessional evidence-based care planning tool for clients with mental health problems and addictions. Worldviews Evid Based Nurs. 2010;7(3):174-84. [pmid: 20367805]. No original data
El-Kareh R, Gandhi TK, Poon EG, et al. Trends in primary care clinician perceptions of a new electronic health record. Journal of General Internal Medicine. 2009;24(4):464-8. [pmid: 19156468]. No original data
Eley R, Fallon T, Soar J, Hegney D, Buikstra E. Barriers to use of information and computer technology by AustraliaGÇÖs nurses: A national survey. Journal of Clinical Nursing. 2009;18(8):1151-8. [pmid: 19320784]. No patient centered care.
Elkjaer M, Shuhaibar M, Burisch J, et al. E-health empowers patients with ulcerative colitis: a randomised controlled trial of the web-guided ‘Constant-care’ approach. Gut. 2010;59(12):1652-61. [pmid: 21071584]. Consumer health informatics No patient centered care.
Etchells E, Adhikari NK, Cheung C, et al. Real-time clinical alerting: effect of an automated paging system on response time to critical laboratory values--a randomised controlled trial. Quality & Safety in Health Care. 2010;19(2):99-102. [pmid: 20351157]. No patient centered care.
Fabry D. Applications of telehealth for hearing care. Audiology Today. 2010;22(5):18-25. No patient centered care.
Felt-Lisk S, Johnson L, Fleming C, Shapiro R, Natzke B. Toward understanding EHR use in small physician practices. Health Care Financ Rev. 2010;31(1):11-22. [pmid: 20191754].
Finkelstein J, Dennison CR, Finkelstein J, Ossebaard HC, van Gemert-Pijnen L. A Pilot Study of Home Automated Telemanagement (HAT) System in African Americans with Congestive Heart Failure. 2010 Second International Conference on eHealth, Telemedicine, and Social Medicine (ETELEMED). Finkelstein J, Ossebaard HC, van Gemert-Pijnen L. Place of Publication: Piscataway, NJ, USA; St Maarten, Netherlands Antilles Country of Publication: USA. IEEE. 2010. Development study
Finkelstein J, Wood J. Design and implementation of home automated telemanagement system for patients with multiple sclerosis. 31st Annual International Conference of the IEEE Engineering in Medicine and Biology Society: Engineering the Future of Biomedicine, EMBC 2009. September 2, 2009 - September 6, 2009. Minneapolis, MN. United states. IEEE Computer Society. 2009:6091-4. Development study
Forsyth R, Maddock CA, Iedema RAM, Lassere M. Patient perceptions of carrying their own health information: Approaches towards responsibility and playing an active role in their own healthùImplications for a patient-held health file. Health Expectations: An International Journal of Public Participation in Health Care & Health Policy. 2010;13(4):416-26. [pmid: 20629768]. No health IT
Finkelstein J, Wood J, Cross R. Design and implementation of home automated telemanagement system for patients with ulcerative colitis. International Conference on eHealth, Telemedicine, and Social Medicine, eTELEMED 2009. February 1, 2009 - February 7, 2009. Cancun, Mexico. Inst. of Elec. and Elec. Eng. Computer Society. 2009:220-6. No original data
Fisher B, Bhavnani V, Winfield M. How patients use access to their full health records: a qualitative study of patients in general practice. J R Soc Med. 2009;102(12):539-44. [pmid: 19966130]. Not a study of health IT
Friedberg MW, Coltin KL, Safran DG, Dresser M, Schneider EC. Medical home capabilities of primary care practices that serve sociodemographically vulnerable neighborhoods. Arch Intern Med. 2010;170(11):938-44. [pmid: 20548005]. No health IT
Friesdorf F, Plavic M, Bubb H. An integral system-ergonomic approach for IT-based process management in complex work environments by example of manufacturing and health care. Human Factors and Ergonomics In Manufacturing. 2009;19(1):78-98. No patient centered care.
Furukawa MF, Raghu TS, Shao BB. Electronic medical records and cost efficiency in hospital medical-surgical units. Inquiry. 2010;47(2):110-23. [pmid: 20812460]. Not a study of health IT
Gagnon Marie-Pierre, Légaré France, Labrecque Michel, et al. Interventions for promoting information and communication technologies adoption in healthcare professionals. Marie-Pierre Gagnon, France Légaré, Michel Labrecque, Pierre Frémont, Pierre Pluye, Johanne Gagnon, Josip Car, Claudia Pagliari, Marie Desmartis, Lucile Turcot, Karine Gravel. Interventions for Promoting Information and Communication Technologies Adoption in Healthcare Professionals. Cochrane Database of Systematic Reviews: Reviews. 2009;(1). John Wiley & Sons, Ltd. Chichester, UK. [doi: 10.1002/14651858.CD006093.Pub2]. No original data
Galanter W, Liu XF, Lambert BL. Analysis of computer alerts suggesting oral medication use during computerized order entry of i.v. medications. Am J Health Syst Pharm. 2010;67(13):1101-5. [pmid: 20554597]. No patient centered care.
Giorgino T, Tormene P, Maggioni G, Pistarini C, Quaglini S. Wireless support to poststroke rehabilitation: myheart’s neurological rehabilitation concept. IEEE Transactions on Information Technology in Biomedicine. 2009;13(6):1012-8. [pmid: 19643710].
Greenhalgh T, Stramer K, Bratan T, Byrne E, Russell J, Potts HW. Adoption and non-adoption of a shared electronic summary record in England: a mixed-method case study. BMJ. 2010;340:c3111. [pmid: 20554687]. No patient centered care.
Hagland M. For all the right reasons. Approaching CPOE from a patient safety and care quality perspective is the first critical step toward success. Healthc Inform. 2009;26(9):40-4. [pmid: 19813574]. No Original data
Hargreaves JS. Will electronic personal health records benefit providers and patients in rural America?. Telemedicine and E-Health. 2010;16(2):167-76. [pmid: 20082592]. No patient centered care.
Hart JK, Newton BW, Boone SE. University of Arkansas. for Medical Sciences electronic health record and medical informatics training for undergraduate health professionals. J Med Libr Assoc. 2010;98(3):212-6. [pmid: 20648253]. No Original data
Healey L, Everett B. Charge nurse alerts: a tool for the new critical care nurse to enhance communication, performance and safety. Critical Care Nurse. 2009;29(2):e5. No patient centered care.
Heaney D, Caldow J, McClusky C, et al. The introduction of a new consulting technology into the national health service (nhs) for Scotland. Telemedicine and E-Health. 2009;15(6):546-51. [pmid: 19519276]. No original data
Hellstrom L, Waern K, Montelius E, Astrand B, Rydberg T, Petersson G. Physicians' attitudes towards ePrescribing--evaluation of a Swedish full-scale implementation. BMC Med Inform Decis Mak. 2009;9:37. [pmid: 19664219]. No patient centered care
Hine MJ, Farion KJ, Michalowski W, Wilk S. Decision making by emergency room physicians and residents: implications for the design of clinical decision support systems. International Journal of Healthcare Information Systems and Informatics. 2009;4(2):17-35. No patient centered care.
Hoerbst A, Kohl CD, Knaup P, Ammenwerth E. Attitudes and behaviors related to the introduction of electronic health records among Austrian and German citizens. International Journal of Medical Informatics. 2010;79(2):81-9. [pmid: 20031482]. No patient centered care
Howells G, Batchelor JC, Spurgeon SK, McDonald-Maier KD, Hopkins ABT. Novel secure communications technologies supporting remote healthcare. IET Conference on Assisted Living 2009. March 24, 2009 – March 25, 2009. London, United kingdom. Institution of Engineering and Technology. 2009. Abstract only
Shiang Hsien-Po, van der Schaar M. Feedback-driven interactive learning in dynamic wireless resource management for delay-sensitive users. IEEE Transactions on Vehicular Technology. 2009;58(4):2030-43. No patient centered care
Iedema R, Merrick ET, Kerridge R, et al. Handover--Enabling Learning in Communication for Safety (HELiCS): a report on achievements at two hospital sites. Med J Aust. 2009;190(11 Suppl):S133-6. [pmid: 19485862]. No patient centered care
Ilie V, Van Slyke C, Courtney JF, Styne P. Challenges associated with physicians' usage of electronic medical records. International Journal of Healthcare Information Systems and Informatics. 2009;4(3):38-54. No patient centered care
Jha A. Outcomes research in review. Prescription errors with use of computerized physician order entry pose safety risk. Journal of Clinical Outcomes Management. 2009;16(7):306-8. No original data
Johnson KB, Ho Y-X, Cala CM, Davison C. Showing Your Work: Impact of annotating electronic prescriptions with decision support results. Journal of Biomedical Informatics. 2010;43(2):321-5. [pmid: 19995617]. No patient centered care
Joubert J, Joubert LB, de Bustos EM, et al. Telestroke in stroke survivors. Cerebrovasc Dis. Suppl 4. 2009;27:28-35. [pmid: 19546539]. No patient centered care
Krishnan A, Nongkynrih B, Yadav K, Singh S, Gupta V. Evaluation of computerized health management information system for primary health care in rural India. BMC Health Serv Res. 2010;10:310. [pmid: 21078203]. No patient centered care
Kuo C-H, Li Y-C, Lee P, Wu Y. An interoperability infrastructure with portable prescription for improving patient safety- the framework of a national standard in Taiwan. 2009 WRI World Congress on Computer Science and Information Engineering, CSIE 2009. March 31, 2009 - April 2, 2009. Los Angeles, CA, United states. IEEE Computer Society. 2009:293-7. No original data
Lamiraud K, von Bremen K, Donaldson C. The impact of information on patient preferences in different delivery patterns: A contingent valuation study of prescription versus OTC drugs. Health Policy. 2009;93(2–3):102-10. [pmid: 19604597]. Not and RCT
Lee HJ, Hwang SI, Han SM, et al. Image-based clinical decision support for transrectal ultrasound in the diagnosis of prostate cancer: comparison of multiple logistic regression, artificial neural network, and support vector machine. Eur Radiol. 2010;20(6):1476-84. [pmid: 20016902]. No patient centered care
Ljótsson B, Falk L, Vesterlund AW, et al. Internet-delivered exposure and mindfulness based therapy for irritable bowel syndrome--a randomized controlled trial. Behaviour Research and Therapy. 2010;48(6):531-9. [pmid: 20362976]. No patient centered care
Lopez DM, Blobel BGME. A development framework for semantically interoperable health information systems. International Journal of Medical Informatics. 2009;78(2):83-103. [pmid: 18621574]. No patient centered care
Lubans DR, Morgan PJ, Callister R, Collins CE. Effects of integrating pedometers, parental materials, and E-mail support within an extracurricular school sport intervention. The Journal of Adolescent Health : Official Publication of the Society for Adolescent Medicine. 2009;44(2):176-83. [pmid: 19167667]. No patient centered care
Mabotuwana T, Warren J. ChronoMedIt - A computational quality audit framework for better management of patients with chronic conditions. Journal of Biomedical Informatics. 2010;43(1):144-58. [pmid: 19703585]. No patient centered care
Matsuura GT, Weeks DL. Use of pharmacy informatics resources by clinical pharmacy services in acute care hospitals. Am J Health Syst Pharm. 2009;66(21):1934-8. [pmid: 19850788]. No patient centered care
Mayer DK, Ratichek S, Berhe H, et al. Development of a health-related website for parents of children receiving hematopoietic stem cell transplant: HSCT-CHESS. J Cancer Surviv. 2010;4(1):67-73. [pmid: 19967409]. No patient centered care
McConnochie KM, Wood NE, Herendeen NE, ten Hoopen CB, Roghmann KJ. Telemedicine in urban and suburban childcare and elementary schools lightens family burdens. Telemed J E Health. 2010;16(5):533-42. [pmid: 20575720]. No patient centered care
McCullough JS, Casey M, Moscovice I, Prasad S. The effect of health technology on quality in U.S. hospitals. Health Aff (Millwood). 2010;29(4):647-54. [pmid: 20368594]. No patient centered care
McGee MK. 9 ways to make E-health succeed [e-medical record systems]. Information WEEK. 2009;(1238):27-32. No patient centered care
McGilton KS, Boscart V, Fox M, Sidani S, Rochon E, Sorin-Peters R. A systematic review of the effectiveness of communication interventions for health care providers caring for patients in residential care settings. Worldviews on Evidence-Based Nursing. 2009;6(3):149-59. [pmid: 19523033]. No original data
Meloni A, Ramazzotti A, Positano V, et al. Evaluation of a Web-based network for reproducible T2* MRI assessment of iron overload in thalassemia. International Journal of Medical Informatics. 2009;78(8):503-12. [pmid: 19345609]. Abstract only
Miguez R, Santos J, Anido L. Towards a framework to support ICT-based processes in early care settings. 2009 9th IEEE International Conference on Advanced Learning Technologies, ICALT 2009. July 15, 2009 – July 17, 2009. Riga, Latvia. IEEE Computer Society. 2009:649-51. Abstract only
Mollon B, Chong JJ, Holbrook AM, Sung M, Thabane L, Foster G. Features predicting the success of computerized decision support for prescribing: a systematic review of randomized controlled trials (Structured abstract). BMC Medical Informatics and Decision Making. 2009;9:11. [pmid: 19210782]. No original data
Moorer OW, Meterko M, Alt-White AC, Sullivan JL. Adding a nursing technology subscale to the Practice Environment Scale of the Nursing Work Index. Research in Nursing & Health. 2010;33(1):48-59. [pmid: 20014031]. No patient centered care
Nijland N, Cranen K, Verlinden SFF, Kelders SM, Boer H, Van Gemert-Pijnen JEWC. Computer generated self-care advice via web-based triage of complaints in primary care. International Conference on eHealth, Telemedicine, and Social Medicine, eTELEMED 2009. February 1, 2009 – February 7, 2009. Cancun, Mexico. Inst. of Elec. and Elec. Eng. Computer Society. 2009:129-35.
Niyato D, Hossain E, Camorlinga S. Remote patient monitoring service using heterogeneous wireless access networks: architecture and optimization. IEEE Journal on Selected Areas in Communications. 2009;27(4):412-23. No original data
Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. Journal of Hypertension. 2009;27(1):198-203. [pmid: 19145785]. No patient centered care
Patrick K, Raab F, Adams MA, et al. A text message-based intervention for weight loss: randomized controlled trial. Journal of Medical Internet Research. 2009;11(1):e1. [pmid: 19141433]. Consumer health informatics
Chen Ping, Barrera A, Rhodes C. Semantic analysis of free text and its application on automatically assigning ICD-9-CM codes to patient records. 2010 9th IEEE International Conference on Cognitive Informatics (ICCI). 7–9 July 2010. Piscataway, NJ, USA. IEEE. 2010:68-74. No original data
Yu Ping, de Courten M, Pan E, Galea G, Pryor J. The development and evaluation of a PDA-based method for public health surveillance data collection in developing countries. International Journal of Medical Informatics. 2009;78(8):532-42. [pmid: 19369114]. No patient centered care
Rantz MJ, Skubic M, Alexander G, et al. Developing a Comprehensive Electronic Health Record to Enhance Nursing Care Coordination, Use of Technology, and Research. J Gerontol Nurs. 2010:1-5.
Regier R, Gurjar R, Rocha RA. A Clinical Rule Editor in an Electronic Medical Record setting: Development, Design, and Implementation. AMIA Annu Symp Proc. 2009;2009:537-41. [pmid: 20351913]. No patient centered care
Robinson TJ, Duvall S, Wiggins R III. Creation and usability testing of a web-based pre-scanning radiology patient safety and history questionnaire set. Journal of Digital Imaging. 2009;22(6):641-7. [pmid: 18716839]. No patient centered care
Rosser B, Eccleston C. Promoting self-management through technology: SMART solutions for long-term health conditions. Journal of Integrated Care. 2009;17(6):10-9. No patient centered care
Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. 2009;169(8):771-80. [pmid: 19398689]. No patient centered care
Scott C, Seidel J, Bowen S, Gall N. Integrated health systems and integrated knowledge: creating space for putting knowledge into action. Healthc Q. 2009;13(Spec No:30-6). No patient centered care
Shaban H, Abou El-Nasr M, Buehrer RM. A framework for the power consumption and BER performance of ultra-low power wireless wearable healthcare and human locomotion tracking systems via UWB radios. 9th IEEE International Symposium on Signal Processing and Information Technology, ISSPIT 2009. December 14, 2009 – December 16, 2009. Ajman, United arab emirates. IEEE Computer Society. 2009:322-7. Development article
Shachak A, Reis S. The impact of electronic medical records on patient-doctor communication during consultation: a narrative literature review. J Eval Clin Pract. 2009;15(4):641-9. [pmid: 19522722]. No original data
Shulman RM, O'Gorman CS, Palmert MR. The impact of telemedicine interventions involving routine transmission of blood glucose data with clinician feedback on metabolic control in youth with type 1 diabetes: a systematic review and meta-analysis. Int J Pediatr Endocrinol. 2010;2010. No original data
Silvester BV, Carr SJ. A shared electronic health record: lessons from the coalface. Med J Aust. 2009;190(11 Suppl):S113-6. [pmid: 19485857]. No patient centered care
Sparrow D, Aloia M, Demolles DA, Gottlieb DJ. A telemedicine intervention to improve adherence to continuous positive airway pressure: a randomised controlled trial. Thorax. 2010;65(12):1061-6. [pmid: 20880872]. No patient centered care
Stock R, Scott J, Gurtel S. National patient safety goals. Using an electronic prescribing system to ensure accurate medication lists in a large multidisciplinary medical group. Joint Commission Journal on Quality & Patient Safety. 2009;35(5):271-7. [pmid: 19480381]. No patient centered care
Te Poel F, Bolman C, Reubsaet A, de Vries H. Efficacy of a single computer-tailored e-mail for smoking cessation: Results after 6 months. Health Education Research. 2009;24(6):930-40. [pmid: 19574405]. Consumer health informatics
Terrell KM, Perkins AJ, Dexter PR, Hui SL, Callahan CM, Miller DK. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: a randomized, controlled trial. Journal of the American Geriatrics Society. 2009;57(8):1388-94. [pmid: 19549022]. No patient centered care
rappey CV, Trappey AJC, Liu CS. Develop patient monitoring and support system using mobile communication and intelligent reasoning. 2009 IEEE International Conference on Systems, Man and Cybernetics, SMC 2009. October 11, 2009 – October 14, 2009. San Antonio, TX, United states. Institute of Electrical and Electronics Engineers, Inc. 2009:1195-200. Abstract only
VanWormer JJ, Martinez AM, Benson GA, et al. Telephone counseling and home telemonitoring: The weigh by day trial. American Journal of Health Behavior. 2009;33(4):445-54. [pmid: 19182989]. No Original data
Webster L, Spiro RF. Health information technology: A new world for pharmacy. J Am Pharm Assoc (2003). 2010;50(2):e20-31. quiz e32–4. [pmid: 20199946]. No patient centered care
Weiner M, El Hoyek G, Wang L, et al. A web-based generalistGÇôspecialist system to improve scheduling of outpatient specialty consultations in an academic center. Journal of General Internal Medicine. 2009;24(6):710-5. 2010. 12. 2. e19. [pmid: 19367375]. No patient centered care
Wietholter J, Sitterson S, Allison S. Effects of computerized prescriber order entry on pharmacy order-processing time. Am J Health Syst Pharm. 2009;66(15):1394-8. [pmid: 19635778]. No patient centered care
Williams B, Dowell J, Humphris G, et al. Developing a longitudinal database of routinely recorded primary care consultations linked to service use and outcome data. Soc Sci Med. 2010;70(3):473-8. [pmid: 19896255]. No health IT
Wilson RC. The importance of nutritional care. Journal of Human Nutrition and Dietetics. 2009;22(3):185-6. communication and coordination of care. Int J Med Inform. 78. 4. 239. 47. No health IT
Wu J, Roy J, Stewart WF. Prediction modeling using EHR data: challenges, strategies, and a comparison of machine learning approaches. Med Care. 2010;48(6 Suppl):S106-13. [pmid: 20473190].
Young J, Eley D, Fahey P, Patterson E, Hegney D. Enabling research in general practice--increasing functionality of electronic medical records. Aust Fam Physician. 2010;39(6):506-9. [pmid: 20628666]. No original data
Zhu X, Gold S, Lai A, Hripcsak G, Cimino JJ. Using timeline displays to improve medication reconciliation. International Conference on eHealth, Telemedicine, and Social Medicine, eTELEMED 2009. February 1, 2009 – February 7, 2009. Cancun, Mexico. Inst. of Elec. and Elec. Eng. Computer Society. 2009:1-6. Abstract only