# Screen and Data Abstraction Forms

Abstract Review Form

Article Review Form