# Summary of Health IT Applications

HIT-Access to care: An electronic tracking system that patient can access for a quality care and reducing medication errors, adverse events and decrease overall health care utilization costs. 1

HIT-Care coordination tools: Tools (Internet) that transmit health information, clinical practice and relationships with patient with their providers2

HIT-Clinical decision: Health information technology (HIT) focusing on clinicians’ adherence to evidence-based guidelines and the corresponding impact on patient clinical outcomes.3

HIT-Communication via e-mail: Adapting evidence-based intervention into practice delivered via the Internet between patient and physician.4

HIT-Computer-assisted self-care: Via Internet patient will able to mange monitor and improve his/her quality of care.5

HIT-Computer-guided disease management: Computer-guided disease management system useful in terms of less travel times for treatment, accessibility in remote and unusual locations, increased confidentiality, easier disclosure of sensitive information.6

HIT-Computer-guided self-management: Is an innovative techniques by which patient can minimize adverse outcome and improve self care.7

HIT-Computerized order entry: Computerized provider order entry (CPOE) system that makes patient safety by reducing medication errors and subsequent adverse drug events by the provider.8

HIT-Disease registry: Ability to generate patient registration with specific diagnosis laboratory results, or medications.9

HIT-Education via IT: Behavioral education tools such as e-mail by which online self-monitoring, physician referral, automated progress reports, and as-needed communication can be done for clinical care.4

HIT-Electronic medical records: Health information system that allows storage, retrieval and manipulation of records with data accessibility, quality and communications with medical providers.10

HIT-Electronic prescribing: “e-prescribing is simply an electronic way to generate prescriptions through an automated data-entry process utilizing e-prescribing software and a transmission network which links to participating pharmacies”.11

HIT-Information exchange: “Is defined as the mobilization of healthcare information electronically across organizations within a region, community or hospital system”.12

HIT-Interactive lifestyle counseling: lifestyle curriculum counseling is an online format that have the potential to increase frequency of practical clinical interventions.13

HIT-mHealth: Portable wireless devices that continuously monitor patients’ condition remotely on their personalized health and allows doctors to leverage data to make informed decisions and interventions immediacy.14

HIT-Patient portals: “A patient portal is an Internet-based interactive website for patients to communicate with their healthcare provider and with varied functions that gives them access to portions of their medical record and other services”.15

HIT-Personal health records: Electronic tracking system by which patient can use care services and communicates with their providers : PHR usually available through the internet, This is different from a provider’s electronic health record.16

HIT-Shared decision-making tools: The tools by which patients could be actively engaged in making decisions about their own health with their physicians.17

HIT-Telemedicine: Telemedicine has been defined as the use of electronic information and communications using videoconferencing, telephones, computers, the Internet, fax, radio, or television that provide and support health care on a distance patient.18

HIT-Telemonitoring systems: An electronic communication networks that can communicate with the patient and perform physiologic measurements and ability to monitor closely patients outside the hospital setting.19

## References

1 Balfour DC 3rd, Evans S, Januska J, et al. The future of Medicare Part D drug plans--results from a roundtable discussion. J Manag Care Pharm. 2009;15(1 Suppl A):18-21. [pmid: 19125557].
2 Rogers A, et al. Health Soc Care Community; More than technology and access: primary care patients’ views on the use and non-use of health information in the Internet age. 2004.
3 Jamal A, McKenzie K, Clark M. The impact of health information technology on the quality of medical and health care: a systematic review. HIM J. 2009;38(3):26-37. [pmid: 19875852].
4 McTigue KM, Conroy MB, Hess R, et al. Using the internet to translate an evidence-based lifestyle intervention into practice. Telemed J E Health. 2009;15(9):851-8. [pmid: 19919191].
5 Walker ER, Wexler B, Dilorio C, Escoffery C, McCarty F, Yeager KA. Content and characteristics of goals created during a self-management intervention for people with epilepsy. J Neurosci Nurs. 2009;41(6):312-21. [pmid: 19998682].
6 MacGregor AD, Hayward L, Peck DF, Wilkes P. Empirically grounded clinical interventions clients’ and referrers’ perceptions of computer-guided CBT (FearFighter). Behav Cogn Psychother. 2009;37(1):1-9. [pmid: 19364403].
7 Tumur I, Kaltenthaler E, Ferriter M, Beverley C, Parry G. Computerised cognitive behaviour therapy for obsessive-compulsive disorder: a systematic review. Psychother Psychosom. 2007;76(4):196-202. [pmid: 17570957].
8 Devine EB, Hansen RN, Wilson-Norton JL, et al. Computerized prescriber-order-entry (CPOE) system. J Am Med Inform Assoc. Jan–Feb. 2010;17(1):78-84. [pmid: 20064806].
9 Wright A, McGlinchey EA, Poon EG, Jenter CA, Bates DW, Simon SR. Ability to generate patient registries among practices with and without electronic health records. J Med Internet Res. 2009;11(3):e31. [pmid: 19674961].
10 Holden RJ. Physicians’ beliefs about using EMR and CPOE: in pursuit of a contextualized understanding of health IT use behavior. Int J Med Inform. 2010;79(2):71-80. [pmid: 20071219].
11 www.emrconsultant.com/education/e-prescribing
12 en.wikipedia.org/wiki/Health_information_exchange.
13 Estabrooks PA, Shoup JA, Gattshall M, Dandamudi P, Shetterly S, Xu S. Automated telephone counseling for parents of overweight children: a randomized controlled trial. Am J Prev Med. 2009;36(1):35-42. [pmid: 19095163].
14 Pharow P, Blobel B, Ruotsalainen P, Petersen F, Hovsto A. Portable devices, sensors and networks: wireless personalized eHealth services. Stud Health Technol Inform. 2009;150:1012-6. [pmid: 19745466].
15 Sorensen L, Shaw R, Casey E. Patient portals: survey of nursing informaticists. Stud Health Technol Inform. 2009;146:160-5. [pmid: 19592827].
16 www.cms.hhs.gov>Medicare>PersonalHealthRecords
17 Winker MA, Flanagin A, Chi-Lum B, et al. Guidelines for medical and health information sites on the internet: principles governing AMA web sites. JAMA. Mar. 22–29. 2000;283(12):1600-6. [pmid: 10735398].
18 Angaran DM. Telemedicine and telepharmacy: current status and future implications. Am J Health Syst Pharm. 1999;56(14):1405-26. [pmid: 10428449].
19 Cordisco ME, Benjaminovitz A, Hammond K, et al. Use of telemonitoring to decrease the rate of hospitalization in patients with severe congestive heart failure. Am J Cardiol. Oct. 1. 1999;84(7):860-862. A8. [pmid: 10513789].