# Detailed Search Strategies

Database | Terms | | | Returns
PubMed | HIT (search #1) | BFD (search #2) | PCC (search #3) | 8814
PubMed | 1. “e-mail”[tiab]; 2. “electronic mail”[tiab]; 3. telemonitoring[tiab]; 4. telemedicine[tiab]; 5. “information technology”[tiab]; 6. informatics[tiab]; 7. “medical informatics applications”[mh]; 8. 1 thru 7 combined by “OR”; 9. prescribing[tiab]; 10. prescription[tiab]; 11. prescriptions[mh]; 12. “disease management”[tiab]; 13. “cognitive modeling”[tiab]; 14. “patient care management”[mh]; 15. “care coordination”[tiab]; 16. “shared decision making”[tiab]; 17. communication[tiab]; 18. communication[mh]; 19. “disease registry”[tiab]; 20. “personal health record”[tiab]; 21. “medical order”[tiab]; 22. “medical record*”[tiab]; 23. “medical records”[mh]; 24. “self care”[mh]; 25. shared[tiab]; 26. decision making”[tiab]; 27. 25 and 26; 28. 9 thru 27 combined by “OR”; 29. “computer systems”[mh]; 30. computer[tiab]; 31. tool[tiab]; 32. electronic[tiab]; 33. 29 thru 32 combined by “OR”; 34. 28 and 33; 35. 8 or 34; 36. “clinical decision support system”[tiab]; 37. “natural language processing”[tiab]; 38. “text messaging”[tiab]; 39. “SMS”[tiab]; 40. 35 or 36 or 37 or 38 or 39 | 1 barrier[tiab]; 2 facilitator[tiab]; 3 driver[tiab]; 4 personalization[tiab]; 5 impersonal[tiab]; 6 “message board”[tiab]; 7 “liability, legal”[mh]; 8 “training support”[mh]; 9 “computer user training”[mh]; 10 altruism[mh]; 11 reciprocity[tiab]; 12 Health Insurance Portability and Accountability Act[mh]; 13 Health Insurance Portability and Accountability Act[tiab]; 14 HIPAA[tiab]; 15 “Insurance, health, Reimbursement”[mh]; 16 “health insurance”[tiab]; 17 reimbursement[tiab]; 18 standardization[tiab]; 19 implementation[tiab]; 20 operability[tiab]; 21 functionality[tiab]; 22 efficiency[mh]; 23 “efficiency, organizational”[mh]; 24 “direct service costs”[mh]; 25 “hospital costs”[mh]; 26 access to information”[mh]; 27 usability[tiab]; 28 initiation[tiab]; 29 “social support”[mh]; 30 “social support”[tiab]; 31 “system support”[tiab]; 32 1 thru 31 combined by “OR”; 33 cost[tiab]; 34 costs[tiab]; 35 revenue[tiab]; 36 income[tiab]; 37 capital[tiab]; 38 access[tiab]; 39 33 thru 38 combined by “OR”; 41 savings[tiab]; 42 “health care”[tiab]; 43 service[tiab]; 44 hospital[tiab]; 45 41 thru 44 combined by “OR”; 46 39 and 45; 47 liability[tiab]; 48 legal[tiab]; 49 46 and 47; 50 computer[mh]; 51 computer[tiab; 52 49 or 50; 53 training[tiab]; 54 52 and 53; 55 32 or 46 or 49 or 54 | 1. “patient-centered care”[mh]; 2. “Patient-centered care”[tiab]; 3. “patient care planning”[mh]; 4. “care coordination”[tiab]; 5. “continuity of patient care”[mh]; 6. “continuity of care”[tiab]; 7. “transition of care”[tiab]; 8. “preventive health services”[mh]; 9. “preventive health care”[tiab]; 10. “health promotion”[tiab]; 11. “common ground”[tiab]; 12. “patient needs”[tiab]; 13. “patient values”[tiab]; 14. “patient preferences”[tiab]; 15. “emotional support”[tiab]; 16. “physical comfort”[tiab]; 17. “quality of care”[tiab]; 18. “quality of health care”[tiab]; 19. “professional-patient relations”[mh]; 20. “Doctor-patient relation*”[tiab]; 21. “delivery of health care, integrated”[mh]; 22. “quality assurance, health care”[mh]; 23. “quality improvement”[tiab]; 24. “quality of care”[tiab]; 25. “cultural competence”[tiab]; 26. “social competence”[tiab]; 27. “public information”[tiab]; 28. “Community-Institutional Relations”[mh]; 29. “Community outreach”[tiab]; 30. 1 thru 29 combined by “OR”; 31. clinical[tiab]; 32. “information systems”[mh]; 33. “information systems”[tiab]; 34. 32 or 33; 35. 31 and 34; 36. learning[mh]; 37. “practice-based”[tiab]; 38. 36 and 37; 39. care[tiab; 40. integrated[tiab]; 41. 39 and 40; 42. Patients[mh]; 43. patient[tiab]; 44. 42 or 43; 45. empowerment[tiab]; 46. safety[mh]; 47. safety[tiab]; 48. feedback[tiab]; 49. engagement[tiab]; 50. 45 thru 49 combined by “OR”; 51. 44 and 50; 52. 30 or 35 or 38 41 or 51 | 8814
PubMed | HIT (search #1) | BFD (search #2) | PCC (search #3) | 8814
PubMed | 1. “e-mail”[tiab]; 2. “electronic mail”[tiab]; 3. telemonitoring[tiab]; 4. telemedicine[tiab]; 5. “information technology”[tiab]; 6. informatics[tiab]; 7. “medical informatics applications”[mh]; 8. 1 thru 7 combined by “OR”; 9. prescribing[tiab]; 10. prescription[tiab]; 11. prescriptions[mh]; 12. “disease management”[tiab]; 13. “cognitive modeling”[tiab]; 14. “patient care management”[mh]; 15. “care coordination”[tiab]; 16. “shared decision making”[tiab]; 17. communication[tiab]; 18. communication[mh]; 19. “disease registry”[tiab]; 20. “personal health record”[tiab]; 21. “medical order”[tiab]; 22. “medical record*”[tiab]; 23. “medical records”[mh]; 24. “self care”[mh]; 25. shared[tiab]; 26. decision making”[tiab]; 27. 25 and 26; 28. 9 thru 27 combined by “OR”; 29. “computer systems”[mh]; 30. computer[tiab]; 31. tool[tiab]; 32. electronic[tiab]; 33. 29 thru 32 combined by “OR”; 34. 28 and 33; 35. 8 or 34; 36. “clinical decision support system”[tiab]; 37. “natural language processing”[tiab]; 38. “text messaging”[tiab]; 39. “SMS”[tiab]; 40. 35 or 36 or 37 or 38 or 39 | 1 barrier[tiab]; 2 facilitator[tiab]; 3 driver[tiab]; 4 personalization[tiab]; 5 impersonal[tiab]; 6 “message board”[tiab]; 7 “liability, legal”[mh]; 8 “training support”[mh]; 9 “computer user training”[mh]; 10 altruism[mh]; 11 reciprocity[tiab]; 12 Health Insurance Portability and Accountability Act[mh]; 13 Health Insurance Portability and Accountability Act[tiab]; 14 HIPAA[tiab]; 15 “Insurance, health, Reimbursement”[mh]; 16 “health insurance”[tiab]; 17 reimbursement[tiab]; 18 standardization[tiab]; 19 implementation[tiab]; 20 operability[tiab]; 21 functionality[tiab]; 22 efficiency[mh]; 23 “efficiency, organizational”[mh]; 24 “direct service costs”[mh]; 25 “hospital costs”[mh]; 26 access to information”[mh]; 27 usability[tiab]; 28 initiation[tiab]; 29 “social support”[mh]; 30 “social support”[tiab]; 31 “system support”[tiab]; 32 1 thru 31 combined by “OR”; 33 cost[tiab]; 34 costs[tiab]; 35 revenue[tiab]; 36 income[tiab]; 37 capital[tiab]; 38 access[tiab]; 39 33 thru 38 combined by “OR”; 41 savings[tiab]; 42 “health care”[tiab]; 43 service[tiab]; 44 hospital[tiab]; 45 41 thru 44 combined by “OR”; 46 39 and 45; 47 liability[tiab]; 48 legal[tiab]; 49 46 and 47; 50 computer[mh]; 51 computer[tiab; 52 49 or 50; 53 training[tiab]; 54 52 and 53; 55 32 or 46 or 49 or 54 | 1. “patient-centered care”[mh]; 2. “Patient-centered care”[tiab]; 3. “patient care planning”[mh]; 4. “care coordination”[tiab]; 5. “continuity of patient care”[mh]; 6. “continuity of care”[tiab]; 7. “transition of care”[tiab]; 8. “preventive health services”[mh]; 9. “preventive health care”[tiab]; 10. “health promotion”[tiab]; 11. “common ground”[tiab]; 12. “patient needs”[tiab]; 13. “patient values”[tiab]; 14. “patient preferences”[tiab]; 15. “emotional support”[tiab]; 16. “physical comfort”[tiab]; 17. “quality of care”[tiab]; 18. “quality of health care”[tiab]; 19. “professional-patient relations”[mh]; 20. “Doctor-patient relation*”[tiab]; 21. “delivery of health care, integrated”[mh]; 22. “quality assurance, health care”[mh]; 23. “quality improvement”[tiab]; 24. “quality of care”[tiab]; 25. “cultural competence”[tiab]; 26. “social competence”[tiab]; 27. “public information”[tiab]; 28. “Community-Institutional Relations”[mh]; 29. “Community outreach”[tiab]; 30. 1 thru 29 combined by “OR”; 31. clinical[tiab]; 32. “information systems”[mh]; 33. “information systems”[tiab]; 34. 32 or 33; 35. 31 and 34; 36. learning[mh]; 37. “practice-based”[tiab]; 38. 36 and 37; 39. care[tiab; 40. integrated[tiab]; 41. 39 and 40; 42. Patients[mh]; 43. patient[tiab]; 44. 42 or 43; 45. empowerment[tiab]; 46. safety[mh]; 47. safety[tiab]; 48. feedback[tiab]; 49. engagement[tiab]; 50. 45 thru 49 combined by “OR”; 51. 44 and 50; 52. 30 or 35 or 38 41 or 51 | 8814
PubMed | 1 AND 4 | | HIT and RCT | 8814
PubMed | 1 AND 3 AND 4 | | HIT and RCT and PCC | 8814
PubMed | (1 AND 3 AND 4) NOT 5 | | HIT and RCT and PCC limited | 8814
PubMed | 1 AND 2 | | HIT and BFD | 8814
PubMed | 1 AND 2 AND 3 | | HIT and BFD and PCC | 8814
PubMed | (1 AND 2 AND 3) NOT 5 | | HIT and BFD and PCC limited | 8814
PubMed | 8 AND 9 | | overlap of 2 main strings | 8814
PubMed | 8 OR 9 | | combination of 2 main strings | 8814
CINAHL | ( ( ((TX shared AND TX “decision making” ) OR (TX prescribing OR TX prescription OR TX prescriptions OR TX “disease management” OR TX “patient care management” OR TX “care coordination” OR TX “shared decision making” OR TX communication OR TX “disease registry” OR TX “personal health record” OR TX “medical record*” OR TX “medical records” OR TX “self care” ) AND ( TX “computer systems” OR TX computer OR TX tool OR TX electronic OR TX computerized)) OR TX “e-mail” OR TX “electronic mail” OR TX telemonitoring OR TX telemedicine OR TX “information technology” OR TX informatics OR TX “clinical decision support system” OR TX “natural language processing” OR TX” text messaging” OR TX “SMS” ) and ( (TX “patient-centered care” OR TX “patient care planning” OR TX “care coordination” OR TX “continuity of patient care” OR TX “continuity of care” OR TX “transition of care” OR TX “preventive health services” OR TX “health promotion” OR TX “common ground” OR TX “patient needs” OR TX “patient values” OR TX “patient preferences” OR TX “emotional support” OR TX “physical comfort” OR TX “quality of health care” OR TX “professional-patient relations” OR TX “Doctor-patient relation*” AND TX “delivery of health care, integrated” OR TX “quality assurance, health care” OR TX “quality improvement” OR TX “quality of care” OR TX “cultural competence” OR TX “social competence” OR TX “public information” OR TX “Community-Institutional Relations” OR TX “Community outreach” OR (TX clinical AND TX “information systems”) OR (TX learning AND TX “practice-based”) OR (TX care AND TX integrated) OR ((TX Patients OR TX patient) AND (TX empowerment OR TX safety OR TX feedback OR TX engagement))) ) and ( (TX “randomized controlled trial” OR TX “randomised controlled trial” OR TX “randomized controlled trials” OR TX “randomised controlled trials” OR TX random* OR TX placebo* OR TX control* OR TX prospective OR TX volunteer* OR ((TX singl* OR TX doubl* OR TX trebl* OR TX tripl*) AND (TX blind* OR TX mask*)) OR TX cross-over OR TX crossover OR TX “latin square” OR TX “double blind method” OR TX “single blind method”) ) not ( (PT editorial OR PT letter OR PT comment) ) ) or ( ( ((TX shared AND TX “decision making” ) OR (TX prescribing OR TX prescription OR TX prescriptions OR TX “disease management” OR TX “patient care management” OR TX “care coordination” OR TX “shared decision making” OR TX communication OR TX “disease registry” OR TX “personal health record” OR TX “medical record*” OR TX “medical records” OR TX “self care” ) AND ( TX “computer systems” OR TX computer OR TX tool OR TX electronic OR TX computerized)) OR TX “e-mail” OR TX “electronic mail” OR TX telemonitoring OR TX telemedicine OR TX “information technology” OR TX informatics OR TX “clinical decision support system” OR TX “natural language processing” OR TX” text messaging” OR TX “SMS” ) and ( (TX “patient-centered care” OR TX “patient care planning” OR TX “care coordination” OR TX “continuity of patient care” OR TX “continuity of care” OR TX “transition of care” OR TX “preventive health services” OR TX “health promotion” OR TX “common ground” OR TX “patient needs” OR TX “patient values” OR TX “patient preferences” OR TX “emotional support” OR TX “physical comfort” OR TX “quality of health care” OR TX “professional-patient relations” OR TX “Doctor-patient relation*” AND TX “delivery of health care, integrated” OR TX “quality assurance, health care” OR TX “quality improvement” OR TX “quality of care” OR TX “cultural competence” OR TX “social competence” OR TX “public information” OR TX “Community-Institutional Relations” OR TX “Community outreach” OR (TX clinical AND TX “information systems”) OR (TX learning AND TX “practice-based”) OR (TX care AND TX integrated) OR ((TX Patients OR TX patient) AND (TX empowerment OR TX safety OR TX feedback OR TX engagement))) ) and ( (TX barrier OR TX facilitator OR TX driver OR TX personalization OR TX impersonal OR TX “message board” OR TX “liability, legal” OR TX “training support” OR TX “computer user training” OR TX altruism OR TX reciprocity OR TX Health Insurance Portability and Accountability Act OR TX HIPAA OR TX “Insurance, health, Reimbursement” OR TX “health insurance” OR TX reimbursement OR TX standardization OR TX implementation OR TX operability OR TX functionality OR TX efficiency OR TX “hospital costs” OR TX “access to information” OR TX usability OR TX initiation OR TX “social support” OR TX “system support” OR (TX computer AND TX training) OR (TX liability AND TX legal) OR ((TX cost OR TX costs OR TX revenue OR TX income OR TX capital OR TX access) AND (TX savings OR TX “health care” OR TX service OR TX hospital))) ) not ( (PT editorial OR PT letter OR PT comment) ) ) Limiters - Published Date from: 199801–200904; English Language; Exclude MEDLINE records | | | 2147
PyscINFO | ( ( ((TX shared AND TX “decision making” ) OR (TX prescribing OR TX prescription OR TX prescriptions OR TX “disease management” OR TX “patient care management” OR TX “care coordination” OR TX “shared decision making” OR TX communication OR TX “disease registry” OR TX “personal health record” OR TX “medical record*” OR TX “medical records” OR TX “self care” ) AND ( TX “computer systems” OR TX computer OR TX tool OR TX electronic OR TX computerized)) OR TX “e-mail” OR TX “electronic mail” OR TX telemonitoring OR TX telemedicine OR TX “information technology” OR TX informatics OR TX “clinical decision support system” OR TX “natural language processing” OR TX” text messaging” OR TX “SMS” ) and ( (TX “patient-centered care” OR TX “patient care planning” OR TX “care coordination” OR TX “continuity of patient care” OR TX “continuity of care” OR TX “transition of care” OR TX “preventive health services” OR TX “health promotion” OR TX “common ground” OR TX “patient needs” OR TX “patient values” OR TX “patient preferences” OR TX “emotional support” OR TX “physical comfort” OR TX “quality of health care” OR TX “professional-patient relations” OR TX “Doctor-patient relation*” AND TX “delivery of health care, integrated” OR TX “quality assurance, health care” OR TX “quality improvement” OR TX “quality of care” OR TX “cultural competence” OR TX “social competence” OR TX “public information” OR TX “Community-Institutional Relations” OR TX “Community outreach” OR (TX clinical AND TX “information systems”) OR (TX learning AND TX “practice-based”) OR (TX care AND TX integrated) OR ((TX Patients OR TX patient) AND (TX empowerment OR TX safety OR TX feedback OR TX engagement))) ) and ( (TX “randomized controlled trial” OR TX “randomised controlled trial” OR TX “randomized controlled trials” OR TX “randomised controlled trials” OR TX random* OR TX placebo* OR TX control* OR TX prospective OR TX volunteer* OR ((TX singl* OR TX doubl* OR TX trebl* OR TX tripl*) AND (TX blind* OR TX mask*)) OR TX cross-over OR TX crossover OR TX “latin square” OR TX “double blind method” OR TX “single blind method”) ) ) or ( ( ((TX shared AND TX “decision making” ) OR (TX prescribing OR TX prescription OR TX prescriptions OR TX “disease management” OR TX “patient care management” OR TX “care coordination” OR TX “shared decision making” OR TX communication OR TX “disease registry” OR TX “personal health record” OR TX “medical record*” OR TX “medical records” OR TX “self care” ) AND ( TX “computer systems” OR TX computer OR TX tool OR TX electronic OR TX computerized)) OR TX “e-mail” OR TX “electronic mail” OR TX telemonitoring OR TX telemedicine OR TX “information technology” OR TX informatics OR TX “clinical decision support system” OR TX “natural language processing” OR TX” text messaging” OR TX “SMS” ) and ( (TX “patient-centered care” OR TX “patient care planning” OR TX “care coordination” OR TX “continuity of patient care” OR TX “continuity of care” OR TX “transition of care” OR TX “preventive health services” OR TX “health promotion” OR TX “common ground” OR TX “patient needs” OR TX “patient values” OR TX “patient preferences” OR TX “emotional support” OR TX “physical comfort” OR TX “quality of health care” OR TX “professional-patient relations” OR TX “Doctor-patient relation*” AND TX “delivery of health care, integrated” OR TX “quality assurance, health care” OR TX “quality improvement” OR TX “quality of care” OR TX “cultural competence” OR TX “social competence” OR TX “public information” OR TX “Community-Institutional Relations” OR TX “Community outreach” OR (TX clinical AND TX “information systems”) OR (TX learning AND TX “practice-based”) OR (TX care AND TX integrated) OR ((TX Patients OR TX patient) AND (TX empowerment OR TX safety OR TX feedback OR TX engagement))) ) and ( (TX barrier OR TX facilitator OR TX driver OR TX personalization OR TX impersonal OR TX “message board” OR TX “liability, legal” OR TX “training support” OR TX “computer user training” OR TX altruism OR TX reciprocity OR TX Health Insurance Portability and Accountability Act OR TX HIPAA OR TX “Insurance, health, Reimbursement” OR TX “health insurance” OR TX reimbursement OR TX standardization OR TX implementation OR TX operability OR TX functionality OR TX efficiency OR TX “hospital costs” OR TX “access to information” OR TX usability OR TX initiation OR TX “social support” OR TX “system support” OR (TX computer AND TX training) OR (TX liability AND TX legal) OR ((TX cost OR TX costs OR TX revenue OR TX income OR TX capital OR TX access) AND (TX savings OR TX “health care” OR TX service OR TX hospital))) ) ) not ( (PT editorial OR PT letter OR PT comment) ) Limiters - Publication Year from: 1998–2009; English; Exclude Dissertations | | | 2046
Engineering Village - Compendex | (( ((((($shared WN KY AND {decision making} WN KY) OR ($prescribing WN KY OR $prescription WN KY OR $prescriptions WN KY OR {disease management} WN KY OR {cognitive modeling} WN KY OR {patient care management} WN KY OR {care coordination} WN KY OR {shared decision making} WN KY OR $communication WN KY OR {disease registry} WN KY OR {personal health record} WN KY OR {medical order} WN KY OR {medical record*} WN KY OR {self care} WN KY) AND ({computer systems} WN KY OR $computer WN KY OR $tool WN KY OR $electronic WN KY OR $computerized WN KY)) OR {e-mail} WN KY OR {electronic mail} WN KY OR $telemonitoring WN KY OR $telemedicine WN KY OR {information technology} WN KY OR $informatics WN KY OR {clinical decision support system} WN KY OR {natural language processing} WN KY OR {text messaging} WN KY OR {SMS} WN KY AND English WN LA) AND (({ca} OR {ja}) WN DT))) AND (1998–2009 WN YR)) and ( (((({patient-centered care} WN KY OR {patient care planning} WN KY OR {care coordination} WN KY OR {continuity of patient care} WN KY OR {continuity of care} WN KY OR {transition of care} WN KY OR {preventive health services} WN KY OR {preventive health care} WN KY OR {health promotion} WN KY OR {common ground} WN KY OR {patient needs} WN KY OR {patient values} WN KY OR {patient preferences} WN KY OR {emotional support} WN KY OR {physical comfort} WN KY OR {quality of care} WN KY OR {quality of health care} WN KY OR {professional-patient relations} WN KY OR {Doctor-patient relation*} WN KY OR {quality improvement} WN KY OR {quality of care} WN KY OR {cultural competence} WN KY OR {social competence} WN KY OR {public information} WN KY OR {Community outreach} WN KY OR ($clinical WN KY AND ({information systems} WN KY)) OR ($learning WN KY AND {practice-based} WN KY) OR ($care WN KY AND $integrated WN KY) OR (($Patients WN KY OR $patient WN KY) AND ($empowerment WN KY OR $safety WN KY OR $safety WN KY OR $feedback WN KY OR $engagement WN KY))) AND English WN LA) AND (({ja} OR {ca}) WN DT))) AND (1998–2009 WN YR)) and ( (((($barrier WN KY OR $facilitator WN KY OR $driver WN KY OR $personalization WN KY OR $impersonal WN KY OR {message board} WN KY OR {training support} WN KY OR {computer user training} WN KY OR $altruism WN KY OR $reciprocity WN KY OR $Health $Insurance $Portability AND $Accountability $Act WN KY OR $HIPAA WN KY OR {Insurance, health, Reimbursement} WN KY OR {health insurance} WN KY OR $reimbursement WN KY OR $standardization WN KY OR $implementation WN KY OR $operability WN KY OR $functionality WN KY OR $efficiency WN KY OR {efficiency, organizational} WN KY OR {direct service costs} WN KY OR {hospital costs} WN KY OR {access to information} WN KY OR $usability WN KY OR $initiation WN KY OR {social support} WN KY OR {social support} WN KY OR {system support} WN KY OR ($computer WN KY AND $training WN KY) OR ($liability WN KY AND $legal WN KY) OR (($cost WN KY OR $costs WN KY OR $revenue WN KY OR $income WN KY OR $capital WN KY OR $access WN KY) AND ($savings WN KY OR {health care} WN KY OR $service WN KY OR $hospital WN KY))) AND english WN LA) AND (({ja} OR {ca}) WN DT))) AND (1998–2009 WN YR))) or (( ((((($shared WN KY AND {decision making} WN KY) OR ($prescribing WN KY OR $prescription WN KY OR $prescriptions WN KY OR {disease management} WN KY OR {cognitive modeling} WN KY OR {patient care management} WN KY OR {care coordination} WN KY OR {shared decision making} WN KY OR $communication WN KY OR {disease registry} WN KY OR {personal health record} WN KY OR {medical order} WN KY OR {medical record*} WN KY OR {self care} WN KY) AND ({computer systems} WN KY OR $computer WN KY OR $tool WN KY OR $electronic WN KY OR $computerized WN KY)) OR {e-mail} WN KY OR {electronic mail} WN KY OR $telemonitoring WN KY OR $telemedicine WN KY OR {information technology} WN KY OR $informatics WN KY OR {clinical decision support system} WN KY OR {natural language processing} WN KY OR {text messaging} WN KY OR {SMS} WN KY AND English WN LA) AND (({ca} OR {ja}) WN DT))) AND (1998–2009 WN YR)) and ( (((({patient-centered care} WN KY OR {patient care planning} WN KY OR {care coordination} WN KY OR {continuity of patient care} WN KY OR {continuity of care} WN KY OR {transition of care} WN KY OR {preventive health services} WN KY OR {preventive health care} WN KY OR {health promotion} WN KY OR {common ground} WN KY OR {patient needs} WN KY OR {patient values} WN KY OR {patient preferences} WN KY OR {emotional support} WN KY OR {physical comfort} WN KY OR {quality of care} WN KY OR {quality of health care} WN KY OR {professional-patient relations} WN KY OR {Doctor-patient relation*} WN KY OR {quality improvement} WN KY OR {quality of care} WN KY OR {cultural competence} WN KY OR {social competence} WN KY OR {public information} WN KY OR {Community outreach} WN KY OR ($clinical WN KY AND ({information systems} WN KY)) OR ($learning WN KY AND {practice-based} WN KY) OR ($care WN KY AND $integrated WN KY) OR (($Patients WN KY OR $patient WN KY) AND ($empowerment WN KY OR $safety WN KY OR $safety WN KY OR $feedback WN KY OR $engagement WN KY))) AND English WN LA) AND (({ja} OR {ca}) WN DT))) AND (1998–2009 WN YR)) and ( (((($randomized $controlled $trialwn $DT OR $controlled $clinical $trialwn $DT OR $randomized $controlled $trials {mh} OR $random $allocation {mh} OR $double-blind $method {mh} OR $single-blind $method {mh} OR $clinical $trialwn $DT OR $clinical $trials {mh} OR ({clinical trial} WN KY) OR ((singl*wn $KY OR doubl*wn $KY OR trebl*wn $KY OR tripl*wn $KY) AND (mask*wn $KY OR blind*wn $KY)) OR ({latin square} WN KY) OR $placebos {mh} OR placebo*wn $KY OR random*wn $KY)) AND ((({ja} OR {ca}) WN DT) AND ({english} WN LA)))) AND (1998–2009 WN YR))) | | | 1502
EBSCOhost – Inspec database | ( ( ((TX shared AND TX “decision making” ) OR (TX prescribing OR TX prescription OR TX prescriptions OR TX “disease management” OR TX “patient care management” OR TX “care coordination” OR TX “shared decision making” OR TX communication OR TX “disease registry” OR TX “personal health record” OR TX “medical record*” OR TX “medical records” OR TX “self care” ) AND ( TX “computer systems” OR TX computer OR TX tool OR TX electronic OR TX computerized)) OR TX “e-mail” OR TX “electronic mail” OR TX telemonitoring OR TX telemedicine OR TX “information technology” OR TX informatics OR TX “clinical decision support system” OR TX “natural language processing” OR TX” text messaging” OR TX “SMS” ) and ( (TX “patient-centered care” OR TX “patient care planning” OR TX “care coordination” OR TX “continuity of patient care” OR TX “continuity of care” OR TX “transition of care” OR TX “preventive health services” OR TX “health promotion” OR TX “common ground” OR TX “patient needs” OR TX “patient values” OR TX “patient preferences” OR TX “emotional support” OR TX “physical comfort” OR TX “quality of health care” OR TX “professional-patient relations” OR TX “Doctor-patient relation*” AND TX “delivery of health care, integrated” OR TX “quality assurance, health care” OR TX “quality improvement” OR TX “quality of care” OR TX “cultural competence” OR TX “social competence” OR TX “public information” OR TX “Community-Institutional Relations” OR TX “Community outreach” OR (TX clinical AND TX “information systems”) OR (TX learning AND TX “practice-based”) OR (TX care AND TX integrated) OR ((TX Patients OR TX patient) AND (TX empowerment OR TX safety OR TX feedback OR TX engagement))) ) and ( (TX “randomized controlled trial” OR TX “randomised controlled trial” OR TX “randomized controlled trials” OR TX “randomised controlled trials” OR TX random* OR TX placebo* OR TX control* OR TX prospective OR TX volunteer* OR ((TX singl* OR TX doubl* OR TX trebl* OR TX tripl*) AND (TX blind* OR TX mask*)) OR TX cross-over OR TX crossover OR TX “latin square” OR TX “double blind method” OR TX “single blind method”) ) not ( (PT editorial OR PT letter OR PT comment) ) ) or ( ( ((TX shared AND TX “decision making” ) OR (TX prescribing OR TX prescription OR TX prescriptions OR TX “disease management” OR TX “patient care management” OR TX “care coordination” OR TX “shared decision making” OR TX communication OR TX “disease registry” OR TX “personal health record” OR TX “medical record*” OR TX “medical records” OR TX “self care” ) AND ( TX “computer systems” OR TX computer OR TX tool OR TX electronic OR TX computerized)) OR TX “e-mail” OR TX “electronic mail” OR TX telemonitoring OR TX telemedicine OR TX “information technology” OR TX informatics OR TX “clinical decision support system” OR TX “natural language processing” OR TX” text messaging” OR TX “SMS” ) and ( (TX “patient-centered care” OR TX “patient care planning” OR TX “care coordination” OR TX “continuity of patient care” OR TX “continuity of care” OR TX “transition of care” OR TX “preventive health services” OR TX “health promotion” OR TX “common ground” OR TX “patient needs” OR TX “patient values” OR TX “patient preferences” OR TX “emotional support” OR TX “physical comfort” OR TX “quality of health care” OR TX “professional-patient relations” OR TX “Doctor-patient relation*” AND TX “delivery of health care, integrated” OR TX “quality assurance, health care” OR TX “quality improvement” OR TX “quality of care” OR TX “cultural competence” OR TX “social competence” OR TX “public information” OR TX “Community-Institutional Relations” OR TX “Community outreach” OR (TX clinical AND TX “information systems”) OR (TX learning AND TX “practice-based”) OR (TX care AND TX integrated) OR ((TX Patients OR TX patient) AND (TX empowerment OR TX safety OR TX feedback OR TX engagement))) ) and ( (TX barrier OR TX facilitator OR TX driver OR TX personalization OR TX impersonal OR TX “message board” OR TX “liability, legal” OR TX “training support” OR TX “computer user training” OR TX altruism OR TX reciprocity OR TX Health Insurance Portability and Accountability Act OR TX HIPAA OR TX “Insurance, health, Reimbursement” OR TX “health insurance” OR TX reimbursement OR TX standardization OR TX implementation OR TX operability OR TX functionality OR TX efficiency OR TX “hospital costs” OR TX “access to information” OR TX usability OR TX initiation OR TX “social support” OR TX “system support” OR (TX computer AND TX training) OR (TX liability AND TX legal) OR ((TX cost OR TX costs OR TX revenue OR TX income OR TX capital OR TX access) AND (TX savings OR TX “health care” OR TX service OR TX hospital))) ) not ( (PT editorial OR PT letter OR PT comment) ) ) Limiters - Date from: 199801–200904 | | | 2666
Cochrane Reviews | ((shared:ti,ab,kw AND “decision making”:ti,ab,kw) )R prescribing:ti,ab,kw OR prescription:ti,ab,kw OR “disease management”:ti,ab,kw OR “cognitive modeling”:ti,ab,kw OR “patient care management”:ti,ab,kw OR “care coordination”:ti,ab,kw OR communication:ti,ab,kw OR “disease registry”:ti,ab,kw OR “personal health record”:ti,ab,kw OR “medical order”:ti,ab,kw OR “medical record”:ti,ab,kw OR “medical records”:ti,ab,kw OR “self care”:ti,ab,kw) AND (“computer systems”:ti,ab,kw OR computer:ti,ab,kw OR tool:ti,ab,kw OR electronic:ti,ab,kw OR computerized:ti,ab,kw) OR “e-mail”:ti,ab,kw OR “electronic mail”:ti,ab,kw OR telemonitoring:ti,ab,kw OR telemedicine:ti,ab,kw OR “information technology”:ti,ab,kw OR informatics:ti,ab,kw OR “natural language processing”:ti,ab,kw OR “text messaging”:ti,ab,kw OR “SMS”:ti,ab,kw AND (“patient-centered care”:ti,ab,kw OR “patient care planning”:ti,ab,kw OR “care coordination”:ti,ab,kw OR “continuity of patient care”:ti,ab,kw OR “continuity of care”:ti,ab,kw OR “transition of care”:ti,ab,kw OR “preventive health services”:ti,ab,kw OR “preventive health care”:ti,ab,kw OR “health promotion”:ti,ab,kw OR “common ground”:ti,ab,kw OR “patient needs”:ti,ab,kw OR “patient values”:ti,ab,kw OR “patient preferences”:ti,ab,kw OR “emotional support”:ti,ab,kw OR “physical comfort”:ti,ab,kw OR “quality of care”:ti,ab,kw OR “quality of health care”:ti,ab,kw OR “professional-patient relations”:ti,ab,kw OR “Doctor-patient relation*”:ti,ab,kw AND( “delivery of health care”:ti,ab,kw) OR “quality assurance health care”:ti,ab,kw OR “quality improvement”:ti,ab,kw OR “quality of care”:ti,ab,kw OR “cultural competence”:ti,ab,kw OR “social competence”:ti,ab,kw OR “public information”:ti,ab,kw OR “Community-Institutional Relations”:ti,ab,kw OR “Community outreach”:ti,ab,kw OR (clinical:ti,ab,kw AND “information systems”:ti,ab,kw) OR (learning:ti,ab,kw AND “practice-based”:ti,ab,kw) OR (care:ti,ab,kw AND integrated:ti,ab,kw) OR ((Patients:ti,ab,kw OR patient:ti,ab,kw) AND (empowerment:ti,ab,kw OR safety:ti,ab,kw OR feedback:ti,ab,kw OR engagement:ti,ab,kw))) AND (barrier:ti,ab,kw OR facilitator:ti,ab,kw OR driver:ti,ab,kw OR personalization:ti,ab,kw OR impersonal:ti,ab,kw OR “message board”:ti,ab,kw OR (liability:ti,ab,kw AND legal:ti,ab,kw) OR “training support”:ti,ab,kw OR “computer user training”:ti,ab,kw OR altruism:ti,ab,kw OR reciprocity:ti,ab,kw OR Health Insurance Portability and Accountability Act:ti,ab,kw OR HIPAA:ti,ab,kw OR (Insurance:ti,ab,kw AND health:ti,ab,kw AND Reimbursement:ti,ab,kw) OR “health insurance”:ti,ab,kw OR reimbursement:ti,ab,kw OR standardization:ti,ab,kw OR implementation:ti,ab,kw OR operability:ti,ab,kw OR functionality:ti,ab,kw OR efficiency:ti,ab,kw OR “direct service costs”:ti,ab,kw OR “hospital costs”:ti,ab,kw OR “access to information”:ti,ab,kw OR usability:ti,ab,kw OR initiation:ti,ab,kw OR “social support”:ti,ab,kw OR “system support”:ti,ab,kw OR (computer:ti,ab,kw AND training:ti,ab,kw) OR ((costs:ti,ab,kw OR revenue:ti,ab,kw OR income:ti,ab,kw OR capital:ti,ab,kw OR access:ti,ab,kw) AND (savings:ti,ab,kw OR “health care”:ti,ab,kw OR service:ti,ab,kw OR hospital:ti,ab,kw))) OR ((shared:ti,ab,kw AND “decision making”:ti,ab,kw) )R prescribing:ti,ab,kw OR prescription:ti,ab,kw OR “disease management”:ti,ab,kw OR “cognitive modeling”:ti,ab,kw OR “patient care management”:ti,ab,kw OR “care coordination”:ti,ab,kw OR communication:ti,ab,kw OR “disease registry”:ti,ab,kw OR “personal health record”:ti,ab,kw OR “medical order”:ti,ab,kw OR “medical record”:ti,ab,kw OR “medical records”:ti,ab,kw OR “self care”:ti,ab,kw) AND (“computer systems”:ti,ab,kw OR computer:ti,ab,kw OR tool:ti,ab,kw OR electronic:ti,ab,kw OR computerized:ti,ab,kw) OR “e-mail”:ti,ab,kw OR “electronic mail”:ti,ab,kw OR telemonitoring:ti,ab,kw OR telemedicine:ti,ab,kw OR “information technology”:ti,ab,kw OR informatics:ti,ab,kw OR “natural language processing”:ti,ab,kw OR “text messaging”:ti,ab,kw OR “SMS”:ti,ab,kw AND (“patient-centered care”:ti,ab,kw OR “patient care planning”:ti,ab,kw OR “care coordination”:ti,ab,kw OR “continuity of patient care”:ti,ab,kw OR “continuity of care”:ti,ab,kw OR “transition of care”:ti,ab,kw OR “preventive health services”:ti,ab,kw OR “preventive health care”:ti,ab,kw OR “health promotion”:ti,ab,kw OR “common ground”:ti,ab,kw OR “patient needs”:ti,ab,kw OR “patient values”:ti,ab,kw OR “patient preferences”:ti,ab,kw OR “emotional support”:ti,ab,kw OR “physical comfort”:ti,ab,kw OR “quality of care”:ti,ab,kw OR “quality of health care”:ti,ab,kw OR “professional-patient relations”:ti,ab,kw OR “Doctor-patient relation*”:ti,ab,kw AND( “delivery of health care”:ti,ab,kw) OR “quality assurance health care”:ti,ab,kw OR “quality improvement”:ti,ab,kw OR “quality of care”:ti,ab,kw OR “cultural competence”:ti,ab,kw OR “social competence”:ti,ab,kw OR “public information”:ti,ab,kw OR “Community-Institutional Relations”:ti,ab,kw OR “Community outreach”:ti,ab,kw OR (clinical:ti,ab,kw AND “information systems”:ti,ab,kw) OR (learning:ti,ab,kw AND “practice-based”:ti,ab,kw) OR (care:ti,ab,kw AND integrated:ti,ab,kw) OR ((Patients:ti,ab,kw OR patient:ti,ab,kw) AND (empowerment:ti,ab,kw OR safety:ti,ab,kw OR feedback:ti,ab,kw OR engagement:ti,ab,kw))) AND (randomized controlled trial.pt. OR controlled clinical trial.pt. OR randomized controlled trials.sh. OR random allocation.sh. OR double-blind method.sh. OR single-blind method.sh. OR clinical trial.pt. OR clinical trials.sh. OR (“clinical trial”:ti,ab) OR ((singl*:ti,ab OR doubl*:ti,ab OR trebl*:ti,ab OR tripl*:ti,ab) AND (mask*:ti,ab OR blind*:ti,ab)) OR (“latin square”:ti,ab) OR placebos.sh. OR placebo*:ti,ab OR random*:ti,ab) From 1998 to 2009 | | | 387