# Glossary of Terms

## Health Information Technology Terms

Care coordination tools: Tools (that transmit health information, clinical practice and relationships with patient with their providers1
Clinical decision support system: Clinical decision support including a variety of tools and interventions such as computerized alerts and reminders, clinical guidelines, order sets, patient data reports, and dashboards, documentation templates, diagnostic support, and clinical workflow tools. From:
  http://healthit.ahrq.gov/portal/server.pt?open=514&objID=5554&mode=2&holderDisplayURL=http://wci-pubcontent/publish/communities/k_o/knowledge_library/key_topics/health_briefing_01242006122700/clinical_decision_support.html)
Communication via e-mail: Communication delivered via the Internet between patient and physician2
Computer-assisted self-care: Patient manages, monitors, and improves his/her quality of care 3
Computer-guided disease management: Coordinated care interventions using IT to impact treatment, accessibility, confidentiality, easier 4
Computer-guided self-management: Using IT tools to minimize adverse outcome and improve self care 5
Computerized provider order entry: Electronic health records as part of a larger IT system to assist with clinical decision support.6
Disease registry: An electronic collection of medical data that is often indexed.7
Education via IT: Behavioral education tools such as e-mail by which online self-monitoring, physician referral, automated progress reports, and as-needed communication can be done for clinical care10
Electronic medical record: An electronic record of health-related information on an individual that can be created, gathered, managed, and consulted by authorized clinicians and staff within one health care organization. From
  http://healthit.hhs.gov/portal/server.pt/gateway/PTARGS_0_10741_848133_0_0_18/10_2_hit_terms.pdf
Electronic prescribing: The use of computing devices to enter, modify, review, and output or communicate drug prescriptions. From:
  http://healthit.ahrq.gov/portal/server.pt?open=514&objID=5554&mode=2&holderDisplayURL=http://wci-pubcontent/publish/communities/k_o/knowledge_library/key_topics/health_briefing_03282006124741/electronic_prescribing.html}Information exchange: process of reliable and interoperable electronic health-related information sharing conducted in a manner that protects the confidentiality, privacy, and security of the information. From: http://healthit.hhs.gov/portal/server.pt/gateway/PTARGS_0_10741_848133_0_0_18/10_2_hit_terms.pdf
Interactive lifestyle counseling: lifestyle curriculum counseling is an online format that have the potential to increase frequency of practical clinical interventions8
mHealth: Portable wireless devices that continuously monitor patients’ condition remotely on their personalized health and allows doctors to leverage data to make informed decisions and interventions immediacy9
Patient portals: “ Internet-based interactive website for patients to communicate with their healthcare provider and with varied functions that gives them access to portions of their medical record and other services”10
Personal health records: An electronic record of health-related information on an individual that conforms to nationally recognized interoperability standards and that can be drawn from multiple sources while being managed, shared, and controlled by the individual. From:
  http://healthit.hhs.gov/portal/server.pt/gateway/PTARGS_0_10741_848133_0_0_18/10_2_hit_terms.pdf
Shared decision-making tools: The tools by which patients could be actively engaged in making decisions about their own health with their physicians11
Telemedicine: The use of medical information exchanged from one site to another via electronic communications to improve patients’ health status. Closely associated with telemedicine is the term “telehealth,” which is often used to encompass a broader definition of remote healthcare that does not always involve clinical services. Videoconferencing, transmission of still images, e-health including patient portals, remote monitoring of vital signs, continuing medical education and nursing call centers are all considered part of telemedicine and telehealth. From: http://www.americantelemed.org/i4a/pages/index.cfm?pageid=3333
Telemonitoring systems: An electronic communication networks that can communicate with the patient and perform physiologic measurements and ability to monitor closely patients outside the hospital setting12

## Patient-Centered Care Terms

Alleviation of fear and anxiety: Reduction of fear or anxiety about clinical status, prognosis, and the impact of illness13
Community outreach: Demonstrable, proactive efforts to understand and reach out to the local community14
Exploring the disease and illness experience: Necessary in order to develop new practices in patient care, patient empowerment, and quality improvement.
Family and friend involvement: In decision-making and awareness and accommodation of their needs as caregivers13
Finding common ground: Necessary in order to facilitate patient engagement in care.
Integrated care: Bringing together inputs, delivery, management and organization of services related to diagnosis, treatment, care, rehabilitation and health promotion. Integration is a means to improve services in relation to access, quality, user satisfaction and efficiency (WHO European Office for Integrated Health Care Services).
Patient empowerment: Allowing patients access to choices that affect health outcomes15
Patient engagement in care: To take a more active role in the care process13
Physical comfort: Including pain management, help with activities of daily living, and clean and comfortable surroundings13
Practice-based learning: Focuses on the part of the practice cycle where program implementers and community members identify, share and apply learnings from local and other circumstances16
Prevention and health promotion: Services to address the health of patients before getting sick as well as encouraging patients to lead healthy lives
Quality and safety: quality care is safe, effective, patient centered, timely, efficient, and equitable. Thus safety is the foundation upon which all other aspects of quality care are built From: http://www.ahrq.gov/qual/nurseshdbk/
Quality improvement: Steps systematically applied to improve the patient care experience, such as effectively making, measuring, and managing change21^13^
Respecting patients’ values, preferences, and needs: awareness of quality-of-life issues, involvement in decision-making, dignity, and attention to patient needs and autonomy.13
Routine patient feedback to practice: A form of quality improvement used in practice-based learning.17
Transition and continuity: As regards to information that will help patients care for themselves away from a clinical setting, and coordination, planning, and support to ease transitions13

## References

1 Rogers A, Mead N. More than technology and access: primary care patients’ views on the use and non-use of health information in the Internet age. Health Soc Care Community. 2004;12(2):102-10. [pmid: 19777718].
2 McTigue KM, Conroy MB, Hess R, et al. Using the internet to translate an evidence-based lifestyle intervention into practice. Telemed J E Health. 2009;15(9):851-8. [pmid: 19919191].
3 Walker ER, Wexler B, Dilorio C, Escoffery C, McCarty F, Yeager KA. Content and characteristics of goals created during a self-management intervention for people with epilepsy. J Neurosci Nurs. 2009;41(6):312-21. [pmid: 19998682].
4 MacGregor AD, Hayward L, Peck DF, Wilkes P. Empirically grounded clinical interventions clients’ and referrers’ perceptions of computer-guided CBT (FearFighter). Behav Cogn Psychother. 2009;37(1):1-9. [pmid: 19364403].
5 Tumur I, Kaltenthaler E, Ferriter M, Beverley C, Parry G. Computerised cognitive behaviour therapy for obsessive-compulsive disorder: a systematic review. Psychother Psychosom. 2007;76(4):196-202. [pmid: 17570957].
6 Devine EB, Hansen RN, Wilson-Norton JL, et al. The impact of computerized provider order entry on medication errors in a multispecialty group practice. J Am Med Inform Assoc. 2010;17(1):78-84. [pmid: 20064806].
7 DesRoches CM, Campbell EG, Vogeli C, et al. Electronic health records’ limited successes suggest more targeted uses. Health Aff (Millwood). 2010;29(4):639-46. [pmid: 20368593].
8 Estabrooks PA, Shoup JA, Gattshall M, Dandamudi P, Shetterly S, Xu S. Automated telephone counseling for parents of overweight children: a randomized controlled trial. Am J Prev Med. 2009;36(1):35-42. [pmid: 19095163].
9 Pharow P, Blobel B, Ruotsalainen P, Petersen F, Hovsto A. Portable devices, sensors and networks: wireless personalized eHealth services. Stud Health Technol Inform. 2009;150:1012-6. [pmid: 19745466].
10 Sorensen L, Shaw R, Casey E. Patient portals: survey of nursing informaticists. Stud Health Technol Inform. 2009;146:160-5. [pmid: 19592827].
11 Winker MA, Flanagin A, Chi-Lum B, et al. Guidelines for medical and health information sites on the internet: principles governing AMA web sites. American Medical Association. JAMA. 2000;283(12):1600-6. [pmid: 10735398].
12 Cordisco ME, Benjaminovitz A, Hammond K, Mancini D. Use of telemonitoring to decrease the rate of hospitalization in patients with severe congestive heart failure. Am J Cardiol. 1999;84(7):860-2. A8. [pmid: 10513789].
13 Shaller Dale. Patient-centered care: what does it take?. Shaller Consulting. [Web Page]. October. 2007. http://www.commonwealthfund.org/~/media/Files/Publications/Fund%20Report/2007/Oct/Patient%20Centered%20Care%20%20What%20Does%20It%20Take/Shaller_patient%20centeredcarewhatdoesittake_1067%20pdf.pdf.
14 Silow-Carroll Sharon, Alteras Tanya, Larry Stepnick. Patient-Centered Care for Underserved Populations: Definition and Best Practices Economic and Social Research Institute. January. 2006. [Web Page]. www.esresearch.org/documents_06/Overview.pdf.
15 Slade Catherine P. Does patient-centered care affect racial disparities in health?. Georgia State University, Georgia Institute of Technology. April. 2008. [Web Page]. http://etd.gsu.edu/theses/available/etd-07092008-150900/unrestricted/slade_catherine_p_200804_phd.pdf.
16 Practice Based Learning for Better Health. [Web Page]. http://www.idmbestpractices.ca/pdf/practice-based-learning-for-health-overview.pdf.
17 Marshall S, Haywood K, Fitzpatrick R. Impact of patient-reported outcome measures on routine practice: a structured review. J Eval Clin Pract. 2006;12(5):559-68. [pmid: 16987118].