# List of Acronyms

A level/HND: advanced level/higher national diploma
A1C: glycated hemoglobin
AAP: American Academy of Pediatrics
ABPM: ambulatory blood pressure monitoring
ACE: angiotensin-converting enzyme inhibitors
ADA-NCQA: American Diabetes Association National Committee for Quality Assurance
ADD: anxiety and depressive disorder
ADL: activities of daily living
ADSL: asymmetric digital subscriber line
AF: Air Force
AHRQ: Agency for Healthcare Research and Quality
ALT: alanine aminotransferase
APHA: American Public Health Association
APN: advanced practice nurse
ARB: angiotensin receptor blockers
ARDS: acute respiratory distress syndrome
ATDM: automated telephone disease management
BCT: breast conserving therapy
BG: blood glucose
BIT: Behavioral Internet Treatment
BMD: bone mineral density
BMI: body mass index
BP: blood pressure
BZD: benzodiazepines
CAD: coronary artery disease
CAHE: computer-assisted health education
CC: coached care
CDEs: certified diabetes educator
CDS: clinical decision support
CDSMP: Chronic Disease Self-Management Program
CDSS: clinical decision support systems
CDT: chronic disease trajectory group
CG: control group
CGI: clinical global impressions
CHD: coronary health disease
CHESS SCRP: Comprehensive Health Enhancement Support System for Smoking Cessation and Relapse Prevention
CHESS-MAB: Comprehensive Health Enhancement Support System-Menopause and Beyond
CHI: consumer health informatics
CHOICE: creating better health outcomes by improving communication about patients’ experiences
CI: confidence interval
COPD: chronic obstructive pulmonary disease
CPAP: continuous positive airway pressure
CPGs: clinical practice guidelines
CPOE: computerized provider order entry
CPR: computer-based patient record
CPRS: computerized patient record system
CR: community resources
CRQ: chronic respiratory questionnaire
CSII: continuous subcutaneous insulin infusion
CSQ: client satisfaction questionnaire
CT: computed tomography
CV: cardiovascular
CVA: cerebro vascular accident
CVD: cardiovascular disease
DA: decision aid
DBP: diastolic blood pressure
DEMS: diabetes electronic management system
Dl: deciliter
DM: diabetes mellitus
DMH: Department of Mental Health
DMS: diabetes management system
D-PHIMS: Distributed personal health information management system
DQOL: diabetes quality of life
DSS: decision support system
DV: domestic violence
DVT: deep vein thrombosis
Dx: diagnosis
EBMeDS: Evidence-based medicine electronic decision support
ECPR: electronic chronic patient record
ED: emergency department
EDECS: emergency department expert charting System
eDSMP: Internet-Based Dyspnea Self-Management Program
HER: electronic health record
EI: electronic interface
EMR: electronic medical record
EORTC-QLQ: European Organization for Research and Treatment of Cancer Quality of life Questionnaire
EPC: Evidence-based Practice Center
F/U: follow up
fDSMP: Face to Face Dyspnea Self-Management Programs
FEV: forced expiratory volume
FFB: Fat and Fiber Behavior Scale
FFQ: food frequency questionnaire
FMH: French-speaking Belgian medical houses
FP: family physician
FPG: fasting plasma glucose
FQ: fear questionnaire
FSH: follicle stimulating hormone
FT: full time
FVC: forced vital capacity
GAD: generalized anxiety disorder
GD: general diabetes
GDS: Geriatric Depression Scale
GHb: glycated hemoglobin
GHP: Geisinger Health Plan
GHQ: General Health Questionnaire
GIMC: general internal medicine clinic
GP: general practitioner
GSI: global severity index
GWU: George Washington University
H&N: head and neck
HAD: hospital anxiety and depression
HbA1c: glycated hemoglobin
HBPM: home blood pressure monitoring
HbSbthal: hemoglobin S beta-thalasemia
HbSC: hemoglobin genotype SC
HCO: Homecare organization
HDL: high-density lipoprotein
HDL-C: high-density lipoprotein cholesterol
HER: health electronic record
HF: heart failure
HIV: human immunodeficiency virus
HMG: HMG CoA Reductase Inhibitor
HMO: health maintenance organization
HPSA: health Professional Shortage Area
HRQoL: health-related quality of life
HRT: hormone replacement therapy
HS: high school
HSD: health search database
HT: hormone therapy
HTMS: home telecare management system
HTN: hypertension
HTU: home telemedicine unit
ICD9: International Statistical Classification of Diseases and Related Health Problems
ICU: intensive care unit
ICVAMC: Iowa City Veterans Affairs Medical Center
IDC: implanted cardioverter-defibrilater
IEEE: The Institute of Electrical and Electronics Engineers
IET: Institution of Engineering and Technology
IHS: International Headache Society
IIS: immunization information system
IM: internal medicine
IMPACT: Interactive Multimedia Program for Asthma Control and Tracking
INR: International Normalized Ratio
IOM: Institute of Medicine
ISDN: integrated services digital network
ISS: injury severity score
IT: information technology
IVD: interactive video disk
IVR: interactive voice response
JHH: Johns Hopkins Hospital
JHU: Johns Hopkins University
JNC: Joint National Committee on Prevention Detection Evaluation and Treatment of High Blood Pressure
KCCQ: Kansas City Cardiomyopathy Questionnaire
kg/m: kilogram per meter
km: kilometer
KQ: Key question
L: liters
LDL: low-density lipoproteins
LDL-C: low-density lipoprotein cholesterol
LMR: longitudinal medical record
MAW: maximum allowable weight
MCIR: The Michigan Care Improvement Registry
MD: Doctor of Medicine
MDD: major depressive disorder or mixed anxiety
MeSH: medical subject heading
mg: milligrams
mHealth: mobile health
MLHF: Minnesota Living with Heart Failure Score
mmHg: millimeters mercury
mmol: mill moles
MMSE: Mini Mental Status Exam
MMSE: Mini Mental Status Examination
MOS: medical outcomes study
MT: mastectomy
MTN: Missouri Telehealth Network
MUA: medically underserved area
NC: No counseling
NCI: National Cancer Institute
NetLET: internet letter
NHS: National Health Service
NICU: neuro-intensive care unit
NIH: National Institutes of Health
No: number
NP: nurse practitioner
NPI: Neuropsychiatric Inventory
NRT: nicotine replacement therapy
NS: not specified
NSAID: non-steroidal anti-inflammatory drug
NSW: New South Wales
NYHA: New York Heart Association
OAB: overactive bladder
OSAS: obstructive sleep apnea syndrome
PA: physician’s assistant
PAD: panic disorder with agoraphobia
PI: principal investigator
PAPM: precaution adoption process model
PAS: pain assessment screen
PASMA: portal for assessment and self-management of asthma
PCASSO: patient-centered access to secure systems online
PCC: patient centered care
PCP: primary care provider or primary care physician
PD: paper documentation
PDA: personal digital assistant
PDF: portable document format
PE: pulmonary embolism
PEEP: positive end-expiratory pressure
PEFR: peak expiratory flow rate
PHIMS: personal health information management system
PHQ: Patient Health Questionnaire
PHR: personal health record
PIRS: Pharmacist Intervention Recording System
PRP: Provider Recognition Program
PSA: prostate specific antigen
PSDI: positive symptom distress index
PSG: polysomnography
PST: positive symptom total
PTS: patients
PTSD: post traumatic stress disorder
QOL: quality of life
QLQ: quality of life questionnaire
RCT: randomized controlled trial
RIAS: Roter Interaction Analysis System
RM: results manager
RN: registered nurse
Rx: prescription
SAS: sleep apnea syndrome
SBP: systolic blood pressure
SBT: strength and balance training
SD: standard deviation
SDM: shared decisionmaking
SDMT: symbol digit modalities test
SF: store and forward or short form
SMBG: self-monitoring of blood glucose
SMI: severe mental illness
SMS: short message service
SOS: Stomp Out Smokes
SPPARO: System Providing Access to Records Online
SPs: subspecialty pediatricians
SSRI: selective serotonin reuptake inhibitor
T1DM: type 1 diabetes mellitus
TBI: traumatic brain injury
TCA: tricyclic antidepressants
TDA: traditional decision aid
TEP: Technical Expert Panel
TF: telephone follow-up
TG: telecare group
Total-C: total cholesterol
TPC: tablet personal computers
TS: touch-screen
TSH: thyroid stimulating hormone
TSM: tailored self-management
TTM: transtheoretical model
TTYD: TalkToYourDocs
UCD: University of California Davis
UCSD: University of California San Diego
UK: United Kingdom
UKPDS: United Kingdom Prospective Diabetes Study
URI: upper respiratory infection
USAF: United States Air Force
USD: United States Dollar
VA: Veterans Affairs
VAMC: Veterans Affairs Medical Center
VCTP: video conference telepsychiatry
VLBW: very low birth weight
WHO: World Health Organization
YHP: youth health provider
YWCA: Young Women Christian Association