# Acknowledgments

The EPC thanks Drs. Christoph Lehmann, Harold Lehmann, Fred Brancati, George Demiris, Michael Barr, and Lisa Cooper for their input throughout the project.

We would like to thank Hosne Begum, Beth Barnett, Todd Noletto, Jonathan Weiner, Rebecca Stainman, Eunme Cha, and Natalia Lapshina for their assistance with data abstraction and the final assembly and formatting of this report, and Dr. Teresa Zayas Cabán for her valuable insight throughout the project.