# Results

## Literature Search

A total of 2,440 records were identified using the search strategy designed for KQs 1–5. Of these, 1,918 records were excluded based on title and abstract screening, leaving 522 records for full text assessment.

The search strategy for KQ6 returned 236 records to be screened for title and abstract (including 15 reviewer-nominated studies). Of these, 43 records passed to full text screening, and 4 records were included in the review.

In total, 84 unique studies (published in 92 papers) were included in this review. The study flow process is depicted in Figure 1 (PRISMA flow chart). The included studies were 21 chart reviews, 10 case series, 21 cohort studies, 21 cross sectional studies, four quasi experimental studies, and 6 case-control/nested case control studies.

Figure 1 PRISMA flow chart - Febrile infant (0–3 months)

Figure 1 is a flow chart that summarizes the identification and selection of articles separately for KQ1-5 and KQ6. The bibliographic citations were identified through searching Medline, CINAHL, EBM Reviews, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, and EMBASE databases. For KQ1-5, we identified 3367 citations and 19 citations were additionally nominated by reviewers. Of these, 946 citations representing duplicate publications and narrative reviews were excluded, leaving 2440 citations. Further screening excluded 1918 citations for the following reasons: non-English publication, not relevant primary objective, and not from pre-specified geographic location. Afterwards, full texts of the remaining 522 citations were retrieved and reviewed to identify potentially eligible studies. Through this process, additional 430 citations were excluded as not relevant (age of the study population, language of publication not English, did not address key question). The remaining 92 citations, representing 84 unique studies, were included in the final report. For KQ6, we identified 223 citations and 15 citations were additionally nominated by reviewers. Of these, 2 citations representing duplicate publications were excluded, leaving 236 citations. Further screening excluded 193 citations for the following reasons: non-English publication, not relevant primary objective, and not from pre-specified geographic location. Afterwards, full texts of the remaining 43 citations were retrieved and reviewed to identify potentially eligible studies. Through this process, additional 39 citations were excluded as not relevant (age of the study population, did not address key question). The remaining 4 citations, representing 4 unique studies, were included in the final report.

Five studies were reported in multiple publications: Bilavsky et al. (2009/2010),45,103 Levine et al. (2004/2005/2009),65,79,80 Maniaci et al. (2008),61,104 Chen et al. (2008 and 2009),71,105 and the PROS study by Pantell, et al., (2002/2004/2005/2008).5,51,76,106 In this report we referred to only one of the publications judged as the primary publication, however relevant data extracted from all publications pertaining to any given study have been presented. Where unique data by any secondary publications was reported, the appropriate citations have been indicated.

## Study Populations

Total number of included infants with laboratory and culture results could be verified in 78/84 studies (n = 53,873). The percentage of infants with confirmed total SBI could be obtained from in 70 studies. (4,273/45,639, 9.4 percent)

The reviewed studies included febrile infants aged 0–3 months with fever (rectal temperature ≥ 38°C measured at home or on arrival at emergency department) and with no history of major disease(s) who had been admitted and assessed in an emergency department, an outpatient clinic, or a primary care physician's office. The source of fever for most of these infants was described as not known (fever without a source or FWS). These studies excluded infants who had a current or previous antibiotic treatment. Of the 83 included studies, 58 (69.9 percent) were conducted in North America, eight (9.6 percent) in Western Europe, and seven (8.4 percent) in Asia (Taiwan or Korea). Information on ethnicity and socioeconomic status were poorly reported in majority of reports. The span of data collection for these studies ranged from 1974 to 2009. Twelve of the studies included more than one hospital/office sites, including the Pediatric Research in Office Settings (PROS) study, which included 219 physicians' office practice sites.5 The remaining studies were conducted at a single site. Twenty-two studies reported information on neonates (0–28 days old). The detailed information for all included studies is presented in Appendix C (Evidence Tables 1–8).

## Methods for Classification (i.e., Screening Tests to Predict SBI) and Diagnosis of SBI and Viral Infection

The reviewed studies reported a wide array of index tests (i.e., criteria) for predicting the risk of serious bacterial infection in febrile infants assessed in emergency departments or outpatient clinics. These criteria were comprised of either clinical or laboratory features alone or represented a variety of combinations of clinical features and laboratory thresholds which were tested in febrile infants in order to predict serious bacterial infection. Some of these tests were commonly used criteria such as the Boston criteria,22,55 Philadelphia protocol,9,11,12,22,25,58,59 Rochester criteria, and 10,23-27,35,56,57,60 Milwaukee protocol10(Table 1). Other criteria also used were Yale scoring criteria,64,65 and Young Infant Observational Scale (YIOS).21(Appendix F) Other reported criteria were various of clinical (e.g., ill or toxic appearance, impression of sepsis, age, rectal temperature) and/ or laboratory features using different techniques with varying thresholds such as serum WBC counts, erythrocyte sedimentation rate (ESR), C-reactive protein (CRP), absolute band count (ABC), cerebrospinal fluid (CSF) (e.g., presence of pleocytosis), Procalcitonin levels (PCT), and urine analysis (e.g., microscopy: WBC of spun urine, dipstick: leukocyte esterase/nitrite).5,26-29,31-36,38-40,46,49,66,67,70,82,85

Table 1 Commonly used combined clinical and laboratory criteria

| Boston Criteria | Milwaukee Criteria | Philadelphia Protocol | Rochester Criteria
Age range | 28–89 d | 28–56 d | 29–60 d | ≤60 d
Temperature | ≥ 38.0°C | ≥ 38.0°C | ≥ 38.2°C | ≥ 38.0°C
History^*^ | No immunizations within last 48 hours No antimicrobial within 48 hours Not dehydrated | Not defined | Not defined | Term infant No perinatal antibiotics No underlying disease Not hospitalized longer than the mother
Physical examination^*^ | Well appearing no sign of focal infection (middle ear, soft tissue, bone/joint) | Well appearing (normal breathing, alert, active, normal muscle tone) Not dehydrated No sign of focal infection (middle ear, soft tissue, bone/joint) | Well appearing Unremarkable examination | Well appearing no sign of focal infection (middle ear, soft tissue, bone/joint)
Laboratory parameters^*^ | CSF < 10 /mm^3^ WBC < 20,000/mm^3^ UA < 10 WBC/hpf Chest radiograph: no infiltrate (if obtained) | CSF < 10/mm^3^ WBC < 15,000/ mm^3^ UA < 5-10 WBCs/hpf (no bacteria, negative LE/nitrite) Chest radiograph: no infiltrate (if obtained) | CSF < 8/mm^3^ WBC < 15,000/mm^3^ UA < 10 WBC/hpf Urine Gram stain negative CSF Gram stain negative Chest radiograph: no infiltrate Stool: no blood, few or no WBCs on smear (if indicated) Band-neutrophil ratio < 0.2 | CSF: NA (no lumbar puncture is indicated) WBC > 5,000 and 15,000/mm^3^ ABC < 1,500 UA ≤ 10 WBC/hpf Stool: WBC ≤ 5 /hpf smear (if indicated)
Management strategy for low risk | Home/outpatient Empiric antibiotics Followup required | Reliable caretaker followup required IM ceftriaxone 50 mg/kg followed by reevaluation within 24 hours | Home/ outpatient No antibiotics Followup required | Home/ outpatient No antibiotics Followup required
Management strategy for high risk | Hospitalize Empiric antibiotics | Not defined | Hospitalize Empiric antibiotics | Hospitalize Empiric antibiotics

* The evaluation algorithms rate patients as normal/low risk versus high/not low risk for serious bacterial infection based on information in each of these domains. The example values in the table represent low risk.

ABC = absolute band count; ° = degrees C = Celsius; CSF = cerebrospinal fluid; d=day(s); hpf = high power field; UA = urinalysis; WBC = white blood cells

The presence of serious bacterial infection was determined by confirming bacterial growth in blood, cerebrospinal fluid, stool, and/or urine. The definition of urinary tract infection was based on supra-pubic tap > 1,000 colony forming units/mL or catheterization > 10,000 colony forming units/mL) although one report employed the higher threshold of > 20,000 colony forming units/mL with a single organism.5 Although serious bacterial infection studies consistently reported on bacteremia, meningitis and urinary tract infection, some other studies chose to include osteomyelitis, suppurative arthritis, soft tissue infections (cellulites, abscess, mastitis), gastroenteritis, and pneumonia. The following bacterial isolates were considered as pathogens: Streptococcus pneumoniae, Neisseria meningitidis, Klebsiella species, Salmonella species, Group A Streptococcus, Group B Streptococcus, Haemophilus influenzae type b, Staphylococcus aureus, Moraxella catarrhalis, Escherichia coli, Listeria monocytogens, or other enteric gram-negative rods. Urine cultures were thought contaminated if the symptoms of febrile infants disappeared without appropriate treatment or if the isolated bacteria were not regarded as a pathogen.

The diagnosis of UTI accounted for the greatest proportion of all types of SBI (bacteremia, meningitis, pneumonia, cellulitis, gastroenteritis, others). For example, the prevalence of diagnosis of UTI across studies ranged from 15.0 percent to 94.0 percent. In contrast, the ranges for this prevalence for bacteremia and meningitis were 0 percent to 41.0 percent and 0 percent to 25.9 percent, respectively (with the exception of one study reporting the prevalence of 34.0 percent for bacterial meningitis in infants 0–2 months of age.21

In total, E. coli was found in 60.0 percent of total SBI cases (1136/1890). The same organism was responsible for 68.0 percent (range: 37.5 percent to 100.0 percent) of all UTI cases, 24.3 percent (range 0 percent to 55.5 percent) of all bacteremia, and 8.0 percent (range: 0 percent to 40.0 percent) of all bacterial meningitis. Group B streptococcus was the second most prevalent organism found in bacteremia, and bacterial meningitis cases (25.0 percent).

The presence of influenza A was confirmed by documented positive direct antigen Flu A testing or positive viral culture. Enterovirus (EV) was diagnosed using polymerase chain reaction or culture (blood, cerebrospinal fluid, nasopharyngeal and throat swabs). The diagnosis of respiratory syncytial virus (RSV) was documented by rapid immunoassay or viral culture. 27,74,78,79,86,107

## Study Outcomes

The outcomes of reviewed studies were performance characteristics (i.e., accuracy indices: sensitivity, specificity, positive and negative predictive value, the area under receiver operating curve, likelihood ratios) of variety of classification methods in predicting the risk of serious bacterial infection in febrile infants (KQs 1a, 1b, 2a, 3a) or herpes simplex virus (HSV) infection (KQ1c). Other studies compared prevalence of serious bacterial infection in febrile infants between those with or without viral infection (prevalence ratios, odds ratios) (Question 4).27,60,74,76,78,79,86

Several studies in “low-risk” or “not low-risk” groups of infants (as classified by index tests or criteria) explored and reported outcomes such as hospitalization, total health care costs associated with hospitalization, incidence of serious bacterial infection and treatment-related harms (e.g., infiltrated intravenous lines, drug-related rush, diarrhea), parents' compliance, and culture contamination (blood, urine, cerebrospinal fluid).5,9,10,12,23,26,28,29,55-58,67,70,108

## Risk of Bias (Study and Reporting Quality)

The study and reporting quality of the included in the review studies were assessed using the Quality Assessment of Studies of Diagnostic Accuracy Included in Systematic Reviews (QUADAS). (Appendix G)

The mean (range) 14-item QUADAS score for included studies was 9.0 (3^43,109^-14^9,67^). For example, the study with lowest quality score of 3 was rated “Yes” on only 3 items and the study with the highest score was rated “Yes” on all 14 items. About 86.9 percent of the studies clearly described selection criteria, 91.3 percent used a valid reference standard for the diagnosis, and in 68.1 percent of studies there was a short period of time between reference standard and index test. The reference standard and index tests were reported to be independent in about 75.4 percent of the studies. Only 28.9 percent of the studies explicitly reported that test results were interpreted without knowledge of either reference standard, or index test results (33.3 percent). The withdrawals were explained in 54.7 percent of the studies.

Based on qualitative assessment, study quality did not seem to account for the observed discrepancies in the diagnostic accuracy parameters for a specific criteria or protocol across the studies. For Boston, Rochester, Philadelphia, Milwaukee criteria, comparison of results according to QUADAS score was not possible due to: (a) relative lack of variability in quality, (b) different combinations of clinical criteria used, (c) various laboratory criteria (or thresholds) used, and/or (d) various target conditions for which a given index test was evaluated (e.g., serious bacterial infection, bacteremia, meningitis).

## KQ1a In infants < 3 months old who present with a fever, what are the sensitivity, specificity and predictive values of individual or combinations of clinical features (history including information on the mother's history and previous testing, risk factors, findings on clinical exam, laboratory tests, and formal scoring instruments based on clinical features) for identifying those with serious bacterial illness (SBI)?

In this section, the classification criteria (i.e., index tests) for predicting the risk of SBI were divided into the following three broad groups: (1) Combined clinical and laboratory criteria, (2) clinical criteria alone, and (3) laboratory criteria alone.

### Key Findings

The most commonly used combined criteria (Philadelphia, Rochester, Boston, and Milwaukee protocol/criteria) demonstrated similar degree of overall accuracy (i.e., sensitivity and specificity) in correctly classifying febrile infants with and without total SBI with high sensitivity (range: 84.4 percent–100.0 percent), but lower specificity (range: 26.6 percent–69.0 percent). The application of Young Infant Observation Scale and Yale Observation Score was associated with lower sensitivity (76.0 percent and 33.3 percent, respectively) for total SBI. The corresponding range of sensitivity for the other combined clinical (e.g., well, ill, good appearance) and various laboratory features (e.g., WBC, ESR, CRP, ABC, and/or urine dipstick test) was from 68.3 percent to 99.1 percent. We found no evidence relating to other possibly relevant factors such as the clinical history of the mother.

Criteria based on clinical history (i.e., no history of recent immunization or rapid influenza test-negative result) demonstrated higher sensitivity (range: 94.0 percent–95.4 percent) for total SBI compared with criteria based on age (≤ 30 days; sensitivity: 35.0 percent), gender (sensitivity: 74.0 percent), the degree of fever (≥ 39.5°C; range of sensitivity: 7.3 percent-26.1 percent), and ill appearance (range of sensitivity: 21.0 percent-33.3 percent). Criteria based on clinical appearance (ill, toxic, impression of sepsis) alone or criteria that combined age (> 30 days) with clinical ill-appearance tended to yield higher sensitivity (range: 80.0 percent-100.0 percent) than criteria based on the degree of fever > 40°C (range: 5.1 percent-12.5 percent) for identifying infants with bacteremia.

Across and within studies, the sensitivity for identifying total SBI tended to increase with lower thresholds of WBC (e.g., from ≥ 5,000/mm3 to ≥ 20,000/mm3), ABC (from ABC>250/mm3 to ABC>3,000/mm3), and absolute neutrophil count (ANC) (from 4,650/μL to 12,500/μL). The overall accuracy of ANC (AUC: 78.0 percent) and ABC (AUC: 81.0 percent) was greater than that for WBC (AUC range: 59.0 percent-69.0 percent). The use of C-reactive protein (CRP) demonstrated the highest sensitivity in correctly identifying infants with and without SBI (AUC: 84.0 percent).

### Detailed Presentation

This review included 62 studies that reported data on the performance characteristics (i.e., accuracy indices: sensitivity, specificity, PPV, NPV) of variety of criteria used in predicting the risk of SBI in febrile infants admitted to emergency departments or outpatient clinics (Tables 2–5).

Table 2 Test results – Combined clinical & laboratory criteria I (Boston criteria, Milwaukee protocol, Philadelphia protocol, Rochester criteria, and Yale observation score)

Study ID QUADAS Total Score | N/n^*^ Age Range | N (%) with SBI | Sensitivity (%) [95% CI] | Specificity (%) [95% CI] | PPV (%) [95% CI] | NPV (%) [95% CI] | Other
Boston Criteria
Kadish (2000)22 [12] | 394/372 1–28 d | Total: 45 (12.1) UTI: 32 Bacteremia: 12 Meningitis: 5 Cellulitis: 3 Septic arthritis: 1 Gastroenteritis: 1 Pneumonia: 1 | 82.0 [67.4, 91.5] | 68.0 [62.8, 73.1] | 26.0 [19.4, 34.4] | 97.0 [93.0, 98.4] | LR^+^=2.58 LR-= 0.26
Kadish (2000)22 [12] | 394/372 1–28 d | Bacteremia: 12 | 75.0 [42.8, 93.3] | 63.3 [58.1, 68.3] | 6.4 [3.1, 12.1] | 98.7 [96.0, 99.6] | LR^+^=2.04 LR-= 0.39
Kaplan (2000)55 [8] | 3,166/2,190 28–90 d | Total: 191 (8.7) Types of SBI: NR | 88.5 [82.8, 92.5] | 56.2 [54.0, 58.4] | 16.2 [14.0, 18.6] | 98.1 [97.0, 98.7] | LR^+^= 2.02 LR-= 0.20
Stanley (2005)35 [13] | 5,279/5,279 0–90 d | Total: 480 (9.1) UTI: 305 Meningitis: 10 Bacteremia: 39 Bacteremia/meningitis: 8 Bacteremia/UTI: 11 Pneumonia: 70 Cellulitis: 26 Bacterial enteritis: 11 | 99.5 [98.3, 99.9] | NR | NR | NR | NR
Milwaukee Protocol
Bonadio (1993)10 [5] | 534/534 29–60 d | Total: 24 (4.5) UTI: 11 Bacterial meningitis: 4 Bacteremia: 6 Bacterial enteritis: 2 Pneumonia: 1 | 96.0 [88.0, 100.0] | 28.0 [23.0, 36.0] | 5.9 [3.6, 8.2] | 99.3 [98.0, 100.0] | LR^+^= 1.33 LR-= 0.15
Philadelphia Protocol
Baker (1999)11 [13] | 254/254 3–28 d | Total: 32 (12.5) UTI: 17 Bacteremia: 8 Meningitis: 4 Cellulitis: 1 Gastroenteritis: 2 Peritonitis: 1 Osteomyelitis: 1 | 84.4 [67.0, 95.0] | 46.8 [40.0, 53.0] | 18.6 [12.0, 25.0] | 95.4 [90.0, 99.0] | LR^+^=1.58 LR-= 0.33
Baker (1999)11 [13] | 254/254 3–28 d | Bacteremia: 8 | 75.0 [35.6, 95.5] | 43.5 [37.2, 49.9] | 4.1 [1.7, 9.1] | 98.1 [92.7, 99.7] | LR^+^=1.32 LR-= 0.57
Baker (1999)11 [13] | 254/254 3–28 d | Meningitis: 4 | 100.0 [39.6, 100.0] | 43.6 [37.4, 49.9] | 2.7 [0.9, 7.3] | 100.0 [95.7, 100.0] | LR^+^=1.77 LR-= 0
Baker (1999)9 [14] | 422/422 29–60 d | Total: 43 (10.2) UTI: 17 Bacteremia: 9 Meningitis: 5 Gastroenteritis: 5 Cellulitis: 5 Chlamydia pneumonia: 2 Enterocolitis: 1 Osteomyelitis: 1 Septic arthritis: 1 | 100.0 [89.7, 100.0] | 26.6 [22.3, 31.4] | 14.0 [10.0, 17.7] | 100.0 [96.0, 100.0] | LR+= 1.36 LR-= 0
Baker (1999)9 [14] | 422/422 29–60 d | Bacteremia: 9 | 100.0 [62.9, 100.0] | 24.4 [20.4, 28.9] | 2.8 [1.4, 5.4] | 100.0 [95.4, 100.0] | LR+= 1.32 LR-= 0
Baker (1999)9 [14] | 422/422 29–60 d | Meningitis: 5 | 100.0 [46.3, 100.0] | 24.2 [20.3, 28.7] | 1.5 [0.6, 3.8] | 100.0 [95.4, 100.0] | LR+= 1.31 LR-= 0
Baker (1993)12 [11] | 747/747 29–56 d | Total: 65 (8.7) UTI: 24 Bacteremia: 19 Meningitis: 9 Cellulitis: 6 Gastroenteritis: 13 Adenitis: 1 | 98.0 [92.0, 100.0] 100.0^‡^ [93.0, 100.0] | 42.0 [38.0, 46.0] 42.0^‡^ [38.3, 45.9] | 14.0 [11.0, 17.0] 14.1^‡^ [11.1, 17.7] | 99.7 [98.0, 100.0] 100.0^‡^ [98.3, 100.0] | LR^+^=1.69 LR-= 0.03 LR^+^=1.72 LR-= 0
Baker (1993)12 [11] | 747/747 29–56 d | Bacteremia: 19 | 100.0^‡^ [79.0, 100.0] | 39.4^‡^ [35.8, 43.0] | 4.1^‡^ [2.5, 6.5] | 100.0^‡^ [98.3, 100.0] | LR^+^=1.65 LR-= 0
Baker (1993)12 [11] | 747/747 29–56 d | Meningitis: 9 | 100.0^‡^ [62.8, 100.0] | 38.9^‡^ [35.4, 42.5] | 2.0^‡^ [0.9, 3.8] | 100.0^‡^ [98.3, 100.0] | LR^+^=1.63 LR-= 0
Brik (1997)58 [12] | 492/492 0–90 d | Total: 60 (12.3) UTI: 40 Meningitis: 2 Bacteremia: 10 Gastroenteritis: 4 Cellulitis: 2 Adenitis: 1 | 86.6 [74.8, 93.6] | 66.6 [62.0, 71.0] | 26.5 [20.6, 33.4] | 97.3 [94.5, 98.7] | LR+= 2.60 LR-= 0.20
Condra (2010) 59 [7] | 1,672/240 29–60 d | Data on only low risk infants (n=62) Total: 2 (NR) UTI: 2 | NR | NR | NR | 96.7 [NR] | NR
Garra (2005)25 [12] | 302/259 0–56 d | Total: 65 (25.1) UTI: 51 Bacteremia/UTI: 5 Bacteremia: 8 Bacteremia/Meningitis:1 | 98.5 [92.0, 100.0] | 41.9 [38.0, 46.0] | 13.9 [11.0, 17.0] | 99.7 [98.0, 100.0] | LR+= 1.70 LR-= 0.03
Garra (2005)25 [12] | 302/259 0–56 d | Bacteremia: 8 | 87.5 [46.7, 99.3] | 19.1 [13.6, 25.9] | 4.7 [2.1, 9.9] | 97.0 [82.9, 99.8] | LR+= 1.08 LR-= 0.65
Kadish (2000)22 [12] | 394/372 1–28 d | Total: 45 (12.1) UTI: 32 Bacteremia: 12 Meningitis: 5 Cellulitis: 3 Septic arthritis: 1 Gastroenteritis: 1 Pneumonia: 1 | 87.0 [72.5, 94.4] | 55.0 [49.5, 60.5] | 21.0 [15.5, 27.6] | 97.0 [92.8, 98.7] | LR+=1.92 LR-= 0.24
Kadish (2000)22 [12] | 394/372 1–28 d | Bacteremia: 12 | 83.3 [50.8, 97.0] | 51.1 [45.8, 56.3] | 5.3 [2.7, 9.9] | 98.9 [95.6, 99.8] | LR+=1.70 LR-= 0.32
Kadish (2000)22 [12] | 394/372 1–28 d | Meningitis: 5 | 100.0 [46.3, 100.0] | 50.7 [45.5, 55.9] | 2.6 [0.9, 6.5] | 100.0 [97.4, 100.0] | LR+=2.03 LR-= 0
Rochester Criteria^†^
Baskin (1992)56 [11] | 503/501 28–89 d | Total: 27 (5.4) Bacteremia: 8 UTI + bacteremia: 1 UTI: 8 Gastroenteritis: 10 | 52.0 [31.7, 71.6] | NR | NR | NR | NR
Baskin (1992)56 [11] | 503/501 28–89 d | Bacteremia: 8 | 55.5 [22.6, 84.6] | NC | NC | NC | NC
Bonadio (1993)10 [5] | 534/532 29–60 d | Total: 22 (4.1) UTI: 11 Meningitis: 4 Bacteremia: 6 Klebsiella pneumoniae: 1 | 59.0 [36.6, 78.5] | 26.3 [22.5, 30.3] | 3.3 [1.9, 5.8] | 93.7 [88.0, 96.9] | LR+=0.80 LR-= 1.55
Bonadio (1993)10 [5] | 534/532 29–60 d | Bacteremia: 6 | 33.3 [6.0, 75.9] | 26.3 [22.5, 30.3] | 0.5 [0.09, 2.1] | 97.1 [92.3, 99.0] | LR+=0.45 LR-= 2.53
Bonadio (1993)10 [5] | 534/532 29–60 d | Meningitis: 4 | 50.0 [9.1, 90.8] | 26.7 [23.0, 30.7] | 0.5 [0.08, 2.1] | 98.6 [94.5, 99.7] | LR+=0.68 LR-= 1.87
Byington (2004)60 [10] | 894/888 (infants without viral infections) 1–90 d | Total: 109 (12.3) Types of SBI: bacteremia, UTI, meningitis, pneumonia | 91.7 [84.5, 95.9] | 36.0 [32.6, 39.4] | 16.6 [13.8, 20.0] | 96.9 [94.0, 98.5] | LR+= 1.43 LR-= 0.23
Chiu (1997)57 [12] | 250/250 4–28 d | Total: 41 (16.4) UTI: 16 Bacteremia/Meningitis: 7 Bacteremia/Enteritis: 3 Enteritis: 2 Bacteremia/Osteomyelitis: 1 Others: NR | 97.6 [92.9, 100.0] | 62.2 [55.6, 68.8] | 33.6 [25.1, 42.1] | 99.2 [97.7, 100.0] | LR+= 2.58 LR-= 0.04
Chiu (1997)57 [12] | 250/250 4–28 d | Bacteremia/Meningitis: 7 Bacteremia/Enteritis: 3 Bacteremia/Osteomyelitis: 1 | 100.0 [67.8, 100.0] | 54.8 [48.2, 61.2] | 9.2 [4.9, 21.2] | 100.0 [96.4, 100.0] | LR+= 2.21 LR-= 0
Dagan (1988)26 [11] | 237/236 < 60 d | Total: 22 (9.3) Bacteremia: 8 UTI: 6 Otitis media: 6 Gastroenteritis: 1 Bacteremia: 1 (not included) | 100.0 [80.7, 100.0] | 68.8 [62.1, 74.8] | 23.8 [15.7, 34.3] | 100.0 [96.8, 100.0] | LR+= 3.20 LR-= 0
Dagan (1988)26 [11] | 237/236 < 60 d | Bacteremia: 8 | 100.0 [59.7, 100.0] | 64.9 [58.3, 71.0] | 9.0 [4.3, 17.6] | 100.0 [96.8, 100.0] | LR+= 2.85 LR-= 0
Dagan (1985)27 [12] | 233/233 < 60 d | Total: 23 (9.8) Bacteremia: 9 UTI: 6 Other: NR | 96.0 [78.0, 100.0] | 68.0 [61.0-74.0] | 24.7 [19.9, 25.8] | 99.3 [96.3, 100.0] | LR+= 2.99 LR-= 0.06
Ferrera (1997)24 [12] | 188/134 0–28 d | Total: 22 (16.4) UTI: 13 UTI/meningitis: 1 Bacteremia: 4 Bacteremia/UTI: 1 Bacteremia/meningitis: 1 Listeria meningitis: 1 Pneumonia: 1 | 86.4 [64.0, 96.4] | 46.4 [36.3, 56.7] | 26.8 [17.2, 38.8] | 93.8 [81.8, 98.4] | LR+=1.61 LR-= 0.29
Ferrera (1997)24 [12] | 188/134 0–28 d | Bacteremia: 4 | 100.0 [39.5, 100.0] | 41.7 [32.7, 51.3] | 5.6 [1.8, 14.3] | 100.0 [90.2, 100.0] | LR+=1.71 LR-= 0
Garra (2005)25 [12] | 302/259 0–56 d | Total: 65 (25.1) UTI: 51 Bacteremia/UTI: 5 Bacteremia: 8 Bacteremia/Meningitis: 1 | 96.9 [89.3, 99.6] | 36.6 [29.8, 43.8] | 33.9 [31.1, 34.8] | 97.3 [90.3, 99.5] | LR+=1.52 LR-= 0.08
Garra (2005)25 [12] | 302/259 0–56 d | Bacteremia: 8 | 75.0 [35.5, 95.5] | 28.3 [22.9, 34.3] | 3.2 [1.3, 7.3] | 97.3 [89.6, 99.5] | LR+=1.04 LR-= 0.88
Garra (2005)25 [12] | 302/259 0–56 d | Bacteremia/UTI: 5 | 100.0 [46.3, 100.0] | 28.7 [23.3, 34.8] | 2.6 [0.9, 6.5] | 100.0 [93.6, 100.0] | LR+=1.40 LR-= 0
Jaskiewicz (1994)23 [10] | 1057/931 0–60 d | Total: 66 (7.0) UTI: 34 Skin/soft tissue infection: 18 Bacteremia: 16 Gastroenteritis: 4 Pneumonia: 1 | 92.4 [82.5, 97.2] | 50.0 [46.5, 53.3] | 12.3 [9.6, 15.6] | 98.9 [97.2, 99.6] | LR+=1.84 LR-= 0.15
Jaskiewicz (1994)23 [10] | 1057/931 0–60 d | Bacteremia: 16 (1.7) | 87.5 [60.4, 97.8] | 47.5 [44.2, 50.8] | 2.8 [1.6, 4.8] | 99.5 [98.2, 99.9] | LR+= 1.66 LR-= 0.26
Stanley (2005)35 [13] | 5,279/5,279 0–90 d | Total: 480 (9.1) UTI: 305 Meningitis: 10 Bacteremia: 39 Bacteremia/meningitis: 8 Bacteremia/UTI: 11 Pneumonia: 70 Cellulitis: 26 Bacterial enteritis: 11 | 99.8 [98.6, 99.9] | NR | NR | NR | NR
YIOS score ≥ 7 (affect, respiratory status/effort, peripheral perfusion)
Bonadio (1993)21 [13] | 242/233 0–29 d | Total: 29 (12.4) Meningitis: 10 Bacteremia: 12 UTI: 7 | 76.0 [56.0, 88.9] | 81.9 [75.7, 86.7] | 37.3 [25.3, 50.8] | 96.0 [91.6, 98.2] | ROC given
Yale Observation Scale (YOS) > 10
Baker (1990)64 [8] | 126/126 29–56 d | Total: 12 (9.5%) UTI: 5 Bacterial sepsis: 4 Other: 3 | 33.3 [11.3, 64.5] | 72.8 [63.5, 80.5] | 11.4 [3.7, 27.6] | 91.2 [82.9, 95.8] | LR+= 1.22 LR-= 0.91
Baker (1990)64 [8] | 126/126 29–56 d | Bacterial sepsis: 4 | 75.0 [21.9, 98.6] | 73.7 [64.8, 81.1] | 8.5 [2.2, 24.1] | 98.9 [93.1, 99.9] | LR+= 2.85 LR-= 0.33
Zorc (2005)65 | 1,513/995 1–60 d | Total: 91 (9.0%) UTI | 4.4 [1.4, 11.5] | 92.6 [90.6, 94.1] | 5.6 [1.8, 14.5] | 90.5 [88.5, 92.3] | LR+=0.60 LR-= 1.03

d=day(s); LR=likelihood ratio; NPV= negative predictive value; NR=not reported; PPV= positive predictive value; SBI=serious bacterial infection; UTI=urinary tract infection; YIOS=Young Infant Observation scale

‡ Values based on Philadelphia protocol + no immunodeficiency syndrome, band-to-neutrophil ratio < 0.2

* N/n: number of infants enrolled/ number of infants with culture and test results

† The Rochester Criteria does not require cerebrospinal fluid (CSF) testing through lumbar puncture (LP)

Table 3 Test results –combined clinical & laboratory criteria II (Other combinations)

Criteria | Study ID QUADAS total score | N/n^*^ Age range | N (%) with SBI | Sensitivity (%) [95% CI] | Specificity (%) [95% CI] | PPV (%) [95% CI] | NPV (%) [95% CI] | Other
Clinical Impression of Sepsis/ Appearance of Infant + Laboratory Markers
Toxic appearance (↑ irritability, ↓ eye contact, unwillingness to feed, and the state of alertness) and ABC ≥ 5,000 /μL | Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia) | 100.0 [46.3, 100.0] | 49.0 [34.3, 63.7] | 17.2 [6.5, 36.5] | 100.0 [82.2, 100.0] | LR+=1.95 LR-= 0
| Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia)
Toxic appearance and CRP positive | Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia) | 100.0 [46.3, 100.0] | 48.0 [32.4, 61.7] | 16.6 [6.3, 35.4] | 100.0 [81.5, 100.0] | LR+=1.88 LR-= 0
| Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia)
Toxic appearance and ABC ≥ 5,000 ABC/μL and WBC ≥ 15,000 /μL | Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia) | 100.0 [46.3, 100.0] | 49.0 [34.3, 63.7] | 17.2 [6.5, 36.5] | 100.0 [81.5, 100.0] | LR^+^=1.96 LR^-^=0
Ill appearance WBC ≥ 15,000/mm^3^ | Caspe (1983)34 [11] | 305/107 0–30 d | Total: 7 (6.5) (bacteremia) | 28.5 [5.1, 69.7] | NR | NR | NR | NR
Ill appearance WBC ≥ 15,000/mm^3^ | Caspe (1983)34 [11]
Ill appearance WBC ≥ 15,000/mm^3^ | Caspe (1983)34 [11] | 305/198 30–60 d | Total: 4 (2.0) (bacteremia) | 75.0 [21.9, 98.6] | 95.8 [91.7, 98.0] | 27.3 [7.3, 60.6] | 99.4 [96.6, 99.9] | LR^+^=18.1 LR^-^=0.26
No findings consistent with soft tissue, skeletal, ear, eye, or umbilical infection and UA: WBC < 10 /hpf, ESR < 30 mm/h, CRP < 20 mg/L, WBC: 5,000-15,000/mm^3^, 1,500 band forms/ mm^3^ | Chiu (1994)66 [9] | 254/254 4–31 d | Total: 45 (17.7) UTI: 16 Bacteremia/meningitis: 13 Enterocolitis: 2 Abscess: 2 Peritonitis: 1 Omphalitis: 10 Pustulosis: 1 Purulent conjunctivitis: 1 | 60.3 [53.3, 66.9] | 82.2 [67.4, 91.5] | 30.8 [22.9, 40.0] | 94.0 [88.2, 97.2] | LR^+^= 2.07 LR^-^= 0.29
No findings consistent with soft tissue, skeletal, ear, eye, or umbilical infection and UA: WBC < 10 /hpf, ESR < 30 mm/h, CRP < 20 mg/L, WBC: 5,000-15,000/mm^3^, 1,500 band forms/ mm^3^ | Chiu (1994)66 [9] | 254/254 4–31 d
No findings consistent with soft tissue, skeletal, ear, eye, or umbilical infection and UA: WBC < 10 /hpf, ESR < 30 mm/h, CRP < 20 mg/L, WBC: 5,000-15,000/mm^3^, 1,500 band forms/ mm^3^ | Chiu (1994)66 [9] | 254/254 4–31 d | Bacteremia/meningitis: 13 | 55.2 [48.6, 61.5] | 92.3 [62.0, 99.6] | 10.0 [5.5, 17.1] | 99.2 [95.3, 99.9] | LR^+^= 2.06 LR^-^= 0.13
Low risk: -ve or ambivalent impression of sepsis and both WBC < 15,000/mm^3^ and ESR < 30 mm/h High risk: 1) strong, or ambivalent impression of sepsis with either WBC ≥ 15,000 /mm^3^ , or ESR ≥ 30 mm/h, or 2) -ve impression of sepsis and both WBC and ESR criteria | Crain (1988)31 [9] | 46/35 0–15 d | Total: 3 (8.5) Sepsis/meningitis | 100.0 [31.0, 100.0] | 75.0 [56.2, 87.9] | 27.3 [7.3, 60.7] | 100.0 [82.8, 100.0] | LR^+^=4.0 LR^-^=0
Clinical impression of sepsis [-ve] (infant's level of activity, irritability, responsiveness, ability to be consoled, feeding pattern) and WBC ≥ 15,000/mm^3^ + ESR ≥ 30 mm/h | Crain (1982)33 [11] | 134/134 0–60 d | Total: 5 (3.7) (bacteremia) | 100.0 [46.3, 100.0] | 17.0 [11.2, 24.9] | 4.5 [1.6, 10.6] | 100.0 [81.5, 100.0] | LR^+^=1.20 LR^-^= 0
| Crain (1982)33 [11] | 134/134 0–60 d | Total: 5 (3.7) (bacteremia)
Clinical impression of sepsis [strong or ambivalent] and WBC ≥ 15,000/mm^3^ or ESR ≥ 30 mm/h | Crain (1982)33 [11] | 134/134 0–60 d | Total: 5 (3.7) (bacteremia) | 100.0 [46.3, 100.0] | 17.0 [11.2, 24.9] | 4.5 [1.6, 10.6] | 100.0 [81.5, 100.0] | LR^+^=1.20 LR^-^=0
Impression of sepsis + either WBC > 15,000 /mm^3^ or ESR > 30 mm/h, or both; or –ve impression of sepsis + both WBC > 15,000 /mm^3^ and ESR > 30 mm/h | Crain (1990)85 [12] | 442/442 8–57d | Total: 33 (7.4) (UTI) | 46.0 [31.1, 66.1] | 98.0 [95.7, 98.9] | 64.0 [42.6, 81.3] | 95.9 [93.4, 97.5] | LR^+^=22.0 LR^-^=0.52
General appearance (well appearing versus not well appearing) and Urine - UA: dipstick (LE^+^, nitrite, ^+^ or both versus normal) | Gomez (2010) 30 [9] | 1,125/ 1,018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 87.0 [67.9, 95.5] | NR/NC | NR/NC | 99.4 [98.2, 99.8] | NR/NC
Well appearance without focal infection, full term, no underlying illness, no previous hospitalization, no perinatal antibiotics (if < 14 days old), no sibling with group GBS disease; WBC: 5,000-15,000/ mm^3^, ABC ≤ 1,500/mm^3^, enhanced UA (WBC ≤ 9 mm^3^; -ve Gram stain), CSF WBC ≤ 5/mm^3^ and –ve Gram stain | Herr (2001)28 [13] | 434/344 < 59 d | SBI: 41 (12.0) UTI: 25 Pneumonia: 8 Bacteremia: 3 Meningitis: 2 Gastroenteritis: 1 Chlamydia: 1 | 68.3 [51.7, 81.4] | 37.6 [32.2, 43.3] | 12.9 [8.8, 18.2] | 89.7 [82.8, 94.2] | LR+=1.09 LR-=0.84
| Herr (2001)28 [13]
| Herr (2001)28 [13] | 434/42 0–14 d | SBI: 3 (7.1) | 100.0 [31.0, 100.0] | 28.2 [15.5, 45.1] | 9.6 [2.5, 26.9] | 100.0 [67.8, 100.0] | LR^+^=1.39 LR^-^=0
| Herr (2001)28 [13]
| Herr (2001)28 [13] | 434/104 15–28 d | SBI: 9 (8.6) | 100.0 [62.8, 100.0] | 26.3 [18.0, 36.5] | 11.3 [5.6, 21.0] | 100.0 [83.0, 100.0] | LR^+^=1.35 LR^-^=0
| Herr (2001)28 [13]
| Herr (2001)28 [13] | 434/138 29–45 d | SBI: 19 (13.7) | 100.0 [79.0, 100.0] | 39.5 [30.7, 48.9] | 20.8 [13.3, 30.9] | 100.0 [90.5, 100.0] | LR^+^=1.65 LR^-^=0
| Herr (2001)28 [13]
| Herr (2001)28 [13] | 434/113 46–59 d | SBI: 10 (8.7) | 100.0 [65.5, 100.0] | 35.9 [26.8, 46.0] | 13.1 [6.8, 23.3] | 100.0 [88.2, 100.0] | LR^+^=1.56 LR^-^=0
Unremarkable medical history, good appearance, no focal/physical signs of infection + ESR < 30 mm/h, WBC 5,000-15,000/mm^3^, normal UA (dipstick: LE, nitrites) | Marom (2007)29 [10] | 449/386 0–90 d | Total: 108 (28.0) UTI: 54 Acute OM: 13 Gastroenteritis: 2 Meningitis: 2 Others: NR | 99.1 [94.2, 99.9] | 59.3 [53.3, 65.1] | 48.6 [41.8, 55.4] | 99.4 [99.3, 99.5] | LR^+^=2.43 LR^-^=0.01
Previously healthy infants without physical finding of OM, skin or musculoskeletal infection + WBC: 5,000-15,000/mm^3^, ABC ≤ 1,500/mm^3^, UA- WBC ≤ 10/hpf, and stool- WBC ≤ 5 /hpf (in infants with diarrhea) | McCarthy (1990)70 [5] | 86/NR 0–60 d | SBI: 1 (NR) (data given only on 1 infant with SBI out of 86 infants classified as ‘low risk’) | NR | NR | NR | 98.8 [92.7, 99.9] | NR
Clinical appearance; WBC < 5,000/ mm^3^ or WBC >15,000/mm^3^ | Pantell (2004)5 [10] | 3,066/ 1,746 0–90d | Total: 63 (3.6) (Bacteremia/bacterial meningitis | 83.9 [NC] | 54.0 [NC] | NR | NR | LR^+^=1.82 LR^-^=0.29
Clinical appearance; WBC < 5,000/ mm^3^ or WBC >15,000/mm^3^; UA- WBC ≥ 5/hpf | | 3,066/ 1,746 0–90d | Total: 63 (3.6) (Bacteremia/bacterial meningitis) | 87.1 [NC] | 50.7 [NC] | NR | NR | LR^+^=1.75 LR^-^=0.25
Not ill appearing + WBC 5000–15,000/mm^3^; absence of LE in noncentrifuged urine on dipstick test CSF-WBC < 23 /hpf | Schwartz (2009)37 [9] | 449/449 0–28 d | SBI: 87 (19.4) | 83.9 [75.6, 90.0] | 58.6 [56.6, 60.0] | 32.7 [29.5, 35.1] | 93.8 [90.6, 96.1] | LR^+^= 2.02 LR^-^=0.27
Low risk: not ill appearing, no bacterial illness + benign laboratory screening findings (undefined) | Wasserman (1990)67 [14] | NR/443 < 90 d | Total: 53 (12.0) Bacteremia: 8 Meningitis: NR Soft tissue infection: NR UTI: NR Enteritis: NR | 90.5 [78.6, 96.5] | 55.4 [50.3, 60.3] | 21.6 [16.5, 27.7] | 97.7 [94.5, 99.1] | LR^+^=2.10 LR^-^=0.17
Other Clinical Criteria + Laboratory Markers
Age < 13 d; T > 39.6°C UA (LE+ or nitrite+) WBC < 4,100/mm^3^, > 20,000/mm^3^ | Bachur (2001)49 [12] | 5,279/ 5,279 0–90 d | Total: 373 (7.0) UTI: 297 Meningitis: 17 Bacteremia: 40 Bacteremia/meningitis: 8 Bacteremia/UTI: 11 | 82.0 [78.0, 86.0] | 76.0 [75.0, 77.0] | 21.0 [19.0, 23.0] | 98.3 [97.8, 98.7] | LR+=3.48 LR-=0.23
Age < 13 d; T > 39.6°C UA (LE+ or nitrite+) WBC < 4,100/mm^3^, > 20,000/mm^3^ | Bachur (2001)49 [12] | 5,279/ 5,279 0–90 d
Age < 13 d; T > 39.6°C UA (LE+ or nitrite+) WBC < 4,100/mm^3^, > 20,000/mm^3^ | Bachur (2001)49 [12] | 5,279/ 5,279 0–90 d | Bacteremia or meningitis: 48 | NR | NR | NR | 99.6 [99.4, 99.8] | LR+=2.36 LR-= 0.48
Sex of infant (male) spun urine + WBC ≥ 10/hpf, and CRP ≥ 3.6 mg/L (probability > 0.265 based on logistic regression model) | Chen (2009) 82 [6] | 135/135 0–90 d | Total: 34 (25.2) | 77.8 [NR] | 77.8 [NR] | NR | NR | NR
Lack of mild upper respiratory tract infection symptoms, and no upper respiratory tract infection symptoms in the patient's siblings + CRP ≥ 1.87 mg/dL, | Shin (2009) 68 [7] | NR/211 0–90 d | Total: 51 (23.0) UTI: 28 Bacteremia: 6 Meningitis: 4 UTI/ bacteremia: 3 Other: 10 | 61.0 [NR] | 90.0 [NR] | 60.0 [NR] | 91.0 [NR] | NR
| Shin (2009) 68 [7]
Lack of mild upper respiratory tract infection symptoms+ CRP ≥ 1.87 mg/dL | Shin (2009) 68 [7] | NR/183 (excluding 28 infants with UTI) 0–90 d | Total: 23 (10.4) Bacteremia: 6 Meningitis: 4 UTI/bacteremia: 3 Miscellaneous: 10 | 38.5 [NR] | 93.5 [NR] | 31.3 [NR] | 95.2 [NR] | NR

ABC = absolute band count; CRP = C-reactive protein; CSF = cerebrospinal fluid; d = day(s); ESR = erythrocyte sedimentation rate; GBS = group B streptococcal disease; h = hour; LE = leukocyte esterase; LR = likelihood ratio; NC = not calculable; NPV = negative predictive value; NR = not reported; OM = otitis media; PPV = positive predictive value; T = temperature; UA = urinalysis; UTI = urinary tract infection; WBC = white blood cell count; ↑ = increased; ↓ = decreased; -ve = negative;

* N/n: number of infants enrolled/number of infants with test and culture results

Table 4 Test results – Clinical criteria alone

Criteria | Study ID | N/n^*^ Age range | N (%) with SBI | Sensitivity % [95% CI] | Specificity % [95% CI] | PPV % [95% CI] | NPV % [95% CI] | Other
Appearance at Presentation
Ill appearance | Bonadio (1994)38 [9] | 367/356 60–90 d | Total: 33 (9.3) UTI: 17 Meningitis: 5 Bacteremia: 8 Salmonella: 3 | 33.3 [18.5, 51.9] | NR | NR | NR | NR
Ill appearance | Bonadio (1994)38 [9] | 367/356 60–90 d | Bacteremia: 8 (2.2) | 37.5 [10.2, 74.1] | NR | NR | NR | NR
Ill appearance | Bonadio (1994)38 [9] | 367/356 60–90 d | UTI: 17 (4.7) | 17.6 [4.6, 44.2] | NR | NR | NR | NR
Ill appearance | Bonadio (1994)38 [9] | 367/356 60–90 d | Salmonella: 3 (0.8) | 0.0 [NA] | NR | NR | NR | NR
Ill appearance | Bonadio (1994)38 [9] | 367/356 60–90 d | Meningitis: 5 (1.4) | 100.0 [46.3,100.0] | NR | NR | NR | NR
Toxic appearance (i.e., increased irritability, decreased eye contact, unwillingness to feed, and the state of alertness) | Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia) | 80.0 [29.8, 98.9] | 80.0 [66.2, 90.3] | 30.7 [10.3, 61.1] | 97.4 [84.5, 99.8] | LR^+^=4.17 LR^-^=0.24
Ill appearance (inconsolable when held or fed or unresponsive to their environment) | Caspe (1983)34 [11] | 305/305 0–90 d | Total: 11 (3.6) (bacteremia) | 91.0 [57.1, 99.5] | 56.6 [49.3, 63.5] | 10.4 [5.4, 18.7] | 99.1 [94.4, 99.9] | LR^+^=2.10 LR^-^=0.16
Ill appearance (inconsolable when held or fed or unresponsive to their environment) | Caspe (1983)34 [11] | 305/107 0–30 d | Total: 7 (6.5) (bacteremia) | 85.7 [42.0, 99.2] | 73.2 [63.4, 81.3] | 18.2 [76.1, 36.0] | 98.6 [91.8, 99.9] | LR^+^=3.20 LR^-^=0.19
Ill appearance (inconsolable when held or fed or unresponsive to their environment) | Caspe (1983)34 [11] | 305/198 30–60 d | Total: 4 (2.0) (bacteremia) | 100.0 [39.6,100.0] | 69.6 [62.5, 75.9] | 6.3 [2.0, 16.2] | 100.0 [96.5, 100.0] | LR^+^=3.28 LR^-^=0
Ill appearance (inconsolable when held or fed or unresponsive to their environment) | Caspe (1983)34 [11] | 305/305 0–90 d | UTI 7 (2.3) | 42.8 [11.8, 79.8] | NR | NR | NR | NR
Ill appearance (at least one of the following: tachypnea, dyspnea, tachycardia, bradycardia, decrease of activity, lethargy, and decrease of appetite) | Chen (2008)71 | 44/NR 0–90 d | Total: 23 (NR) UTI: 17 Bacteremia: 2 Meningitis: 2 Other: 2 (data given only on 23 infants with SBI out of 44 infants classified as ‘high risk’) | NR | NR | 52.3 [36.8, 67.3] | NR | NR
Clinical impression of sepsis (infant's level of activity, irritability, responsiveness, ability to be consoled, feeding pattern) | Crain (1982)33 [9] | 134/134 0–60 d | Total: 5 (3.7) (bacteremia) | 100.0 [46.3,100.0] | 58.1 [49.1, 66.6] | 8.5 [3.1, 19.4] | 100.0 [93.9, 100.0] | LR^+^=2.38 LR^-^=0
Ill appearing (based on appearance, respiratory, and circulatory functioning) | Gomez (2010)30 [9] | 1,125/ 1,018 0–90 d | Total: 198 (19.4) UTI: 172 Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 Cellulitis: 2 Otitis media: 1 | NR/NC | NR/NC | NR/NC | NR/NC | NR/NC
Not well appearing (based on appearance, respiratory, and circulatory functioning) versus well- appearing | Gomez (2010)30 [9] | 1,125/ 1,018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 26.1 [11.3, 47.2] | 95.8 [95.4, 96.3] | 12.5 [5.4, 22.6] | 98.2 [97.9, 98.7] | LR^+^=6.18 LR^-^=0.77
Septic appearance (yes, no, unsure) based on physical examination, complete history, initial laboratory results | King (1987)b39 [6] | NR/97 < 60 d | Total: 4 (5.4) Bacteremia or meningitis | 100.0 [39.6,100.0] | 66.0 [54.9, 74.9] | 11.1 [3.6, 27.0] | 100.0 [92.6, 100.0] | LR^+^=2.90 LR^-^=0
Clinical appearance (well or minimally ill) | Pantell (2004)5 [10] | 3,066/ 3,066 0–90d | Total: 63 (3.6) (Bacteremia/bacterial meningitis) | 58.1 [NC] | 68.1 [NC] | NR | NR | LR^+^=1.82 LR^-^=0.61
Clinical impression of sepsis (irritable, toxic, lethargic) | Rosenberg (1985)40 [6] | 122/122 0–60 d | Total: 5 (4.0) (bacteremia) | 80.0 [29.9, 98.9] | 37.5 [28.7, 47.2] | 5.4 [1.7, 13.9] | 97.6 [86.2, 99.8] | LR^+^=1.28 LR^-^=0.53
Not ill appearing | Shwartz (2008)37 [9] | 644/449 0–28 d | Total: 87 (19.4) Bacteremia + meningitis + UTI: 2 Bacteremia + meningitis: 1 Bacteremia + UTI: 10 UTI: 70 Pneumonia: 2 Omphalitis: 1 | 21.0 [NR] | NR | NR | 82.5 [78.5, 86.0] | NR
Age/ Gender of Infant Alone or in Combination with Other Clinical Criteria
Age ≤ 30 days versus > 30 days | Gomez (2010)30 [9] | 1,125/ 1,018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 34.8 [17.3, 56.9] | 76.4 [76.0, 76.9] | 3.3 [1.6, 5.4] | 98.1 [97.5, 98.7] | LR^+^=1.47 LR^-^=0.85
Gender (male versus female) | Gomez (2010)30 [9] | 1,125/ 1,018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 73.9 [51.6, 88.9] | 42.9 [42.4, 43.3] | 2.9 [2.0, 3.5] | 98.6 [97.4, 99.4] | LR^+^=1.29 LR^-^=0.60
High risk: age < 30 d and ill-appearing Low risk: age > 30 d and well-appearing | Pantell (2004)5 [10] | 3,066/ 1,746 0–90d | Total: 63 (3.6) (Bacteremia/bacterial meningitis) | 95.2 [NC] | 35.49 [NC] | NR | NR | LR^+^=1.47 LR^-^=0.13
Well or minimally ill appearance, Temperature < 38.6°C, age < 25 d | Pantell (2004)5 [10] | 3,066/ 3,066 0–90 d | Total: 63 (3.6) (Bacteremia/bacterial meningitis) | 93.6 [NC] | 27.3 [NC] | NR | NR | LR^+^=1.28 LR^-^=0.23
Well or minimally ill appearance, Temperature < 38.6°C, age ≥ 25 d | Pantell (2004)5 [10] | 3,066/ 3,066 0–90 d | Total: 14 (0.7) (Bacteremia/bacterial meningitis) | 71.4 [42.0, 90.4] | 56.8 [54.5, 59.1] | 1.2 [0.6, 2.4] | 99.6 [98.9, 99.8] | LR^+^=1.65 LR^-^=0.50
Fever Temperature
Temperature > 40.0°C | Bonadio (1991)36 [12] | 683/683 30–60 d | Total: 34 (5.0) Meningitis: 6 Bacteremia: 8 UTI: 16 Enteritis: 4 | 21.0 [9.3, 38.4] | 97.0 [95.2, 98.0] | 26.0 [11.8, 46.6] | 95.8 [94.0, 97.2] | LR^+^=6.68 LR^-^=0.81
Temperature > 40.0°C | Bonadio (1991)36 [12] | 683/683 30–60 d | Bacteremia: 8 | 12.5 [0.6, 53.3] | 96.1 [94.3, 97.4] | 3.7 [0.2, 20.8] | 98.9 [97.7, 99.5] | LR^+^=3.24 LR^-^=0.91
Temperature > 40.0°C | Bonadio (1991)36 [12] | 683/683 30–60 d | Meningitis: 6 | 33.3 [5.9, 75.9] | 96.3 [94.5, 97.5] | 7.4 [1.3, 25.7] | 99.4 [98.3, 99.8] | LR^+^=9.02 LR^-^=0.69
Temperature > 40.0°C | Stanley (2005)35 [13] | 5,279/ 5,279 0–90 d | Total: 480 (9.1) UTI: 305 Meningitis: 10 Bacteremia: 39 Bacteremia/meningitis: 8 Bacteremia/UTI: 11 Pneumonia: 70 Cellulitis: 26 Bacterial enteritis: 11 | 7.3† [5.2, 10.1] | 98.8 [98.4, 99.1] | 38.0 [28.3, 48.8] | 91.4 [90.6, 92.1] | LR^+^=6.13 LR^-^=0.93
Temperature > 40.0°C | Stanley (2005)35 [13] | 5,279/ 5,279 0–90 d | Bacteremia: 39 | 5.1 [0.9, 18.6] | 98.3 [97.8, 98.6] | 2.1 [0.3, 8.3] | 99.3 [99.0, 99.5] | LR^+^=2.98 LR^-^=0.96
Temperature > 40.0°C | Stanley (2005)35 [13] | 5,279/ 5,279 0–90 d | Bacteremia/meningitis: 8 | 25.0 [4.4, 64.4] | 98.3 [97.8, 98.6] | 2.2 [0.4, 8.4] | 99.8 [91.6, 99.6] | LR^+^=0 LR^-^=0.76
Temperature > 40.0°C | Stanley (2005)35 [13] | 5,279/ 5,279 0–90 d | Meningitis: 10 | 0 [0, 34.4] | 98.2 [97.8, 98.6] | 0 [0, 5.0] | 99.8 [99.6, 99.9] | LR^+^=14.6 LR^-^=1.01
Temperature ≥ 39.5°C versus 38°C–39.4°C | Gomez (2010)30 [9] | 1,125/1018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 26.1 [11.2, 48.0] | 90.5 [90.2, 91.0] | 6.1 [2.6, 11.3] | 98.1 [97.7, 98.7] | LR^+^=2.75 LR^-^=0.81
Clinical History
Not previously healthy versus previously healthy | Gomez (2010)30 | 1,125/ 1,018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 21.7 [8.4, 43.6] | 88.5 [88.2, 89.0] | 4.2 [1.6, 8.4] | 98.0 [97.7, 98.6] | LR^+^=1.89 LR^-^=0.88
Rapid influenza test (negative versus positive) | Mintegi (2009)41 [3] | 520/381 0–90 d | Total: 50 (13.1) UTI: 34 Bacteremia: 8 Meningitis: 5 Other: 3 | 94.0 [83.1, 98.4] | 33.2 [31.6, 33.9] | 17.5 [15.5, 18.4] | 97.3 [92.5, 99.3] | LR^+^=1.4 LR^-^=0.18
No history of recent immunization (72 hrs preceding the ED visit)£ | Wolff (2009) 42 [10] | 2,247/1,978 45–90 d | Total: 130 (6.6) UTI: 105 Bacteremia: 11 Bacteremia/UTI: 4 Meningitis: 3 Pneumonia: 7 | 95.4^μ^ [90.0, 98.1] | 11.3 [10.9, 11.5] | 7.1 [6.7, 7.3] | 97.2 [93.8, 98.8] | LR^+^=1.07 LR^-^=0.4

d = day(s); hpf = high-power field; LR = likelihood ratio; NC = not calculable; NPV = negative predictive value; NR = not reported; PPV = positive predictive value; T = temperature; UTI = urinary tract infection

* N/n: number of infants enrolled/ number of infants with test and culture results

£ Inactivated polio virus, hepatitis B, Haemophilus Influenzae B, diphtheria-tetanus-acellular pertussis, pneumococcal conjugate, rotavirus, and Pediarix (pentavalent vaccine) vaccines; μ 28 cases of possible SBI were excluded from the calculations of the test accuracy indices

Table 5 Test results - Laboratory criteria

Criteria | Study ID QUADAS total score | N/n Age range | N (%) with SBI | Sensitivity % [95% CI] | Specificity % [95% CI] | PPV % [95% CI] | NPV (%) [95% CI] | Other
Blood Markers in Neonates (0–28 d)
WBC > 15,000/mm^3^ | Bonadio (1987)112 [7] | 55/55 0–28 d | Total: 8 (14.5) UTI: 3 Gastroenteritis: 2 Meningitis: 2 Bacteremia: 1 | 0.0 [NA] | NR | NR | NR | NR
ABC >1,500/mm^3^ | Bonadio (1987)112 [7] | 55/55 0–28 d | Total: 8 (14.5) UTI: 3 Gastroenteritis: 2 Meningitis: 2 Bacteremia: 1 | 50.0 [17.4, 82.5] | NR | NR | NR | NR
CBC Differential Ratio < 1 (Low risk) | Bonadio (1987)112 [7] | 55/55 0–28 d | Total: 8 (14.5) UTI: 3 Gastroenteritis: 2 Meningitis: 2 Bacteremia: 1 | 87.5 [46.6, 99.3] | NR | NR | NR | NR
WBC < 5,000, or > 15,000 [underlined: (fever < 12 hours duration)] | Bressan (2010)47 [7] | 99/99 7–28 d | Total: 25 (25.3) UTI: 15 Meningitis: 3 Bacteremia: 3 Bacteremia + UTI: 2 Pneumonia: 1 Osteomyelitis: 1 | 28.0 [14.3, 47.6] | 87.7 [78.2, 93.4] | 43.75 [23.1, 66.8] | 78.1 [68.0, 85.6] | LR^+^ = 2.3 LR^-^ = 0.8
WBC < 5,000, or > 15,000/mm^3^ ([underlined: fever > 12 hours duration)] | Bressan (2010)47 [7] | 99/58 7–28 d | Total: 5 (8.6) only low risk infants determined by the same criteria | 80.0 [37.6, 96.4] | 90.6 [79.7, 95.9] | 44.4 [18.9, 73.3] | 98.0 [89.3, 99.6] | LR^+^ = 8.5 LR^-^ = 0.2
ANC > 10,000/mm^3^ (fever < 12 hours duration) | Bressan (2010)47 [7] | 99/99 7–28 d | Total: 25 (25.3) | 20.0 [8.9, 39.1] | 97.3 [90.6, 99.3] | 71.4 [35.9, 91.8] | 78.0 [68.5, 85.3] | LR+ = 7.3 LR- = 0.8
ANC > 10,000/mm^3^ [underlined: (fever > 12 hours duration)] | Bressan (2010)47 [7] | 99/58 7–28 d | Total: 5 (8.6) only low risk infants determined by the same criteria | 80.0 [37.6, 96.4] | 100.0 [93.2, 100.0] | 100.0 [51.0, 100.0] | 98.2 [90.2, 99.7] | LR^+^ = NR LR^-^ = 0.2
CRP > 20 mg/L [underlined: (fever < 12 hours duration)] | Bressan (2010)47 [7] | 99/99 7–28 d | Total: 25 (25.3) | 48.0 [30.3, 66.5] | 93.2 [85.1, 97.1] | 70.6 [46.9, 86.7] | 84.2 [74.7, 90.5] | LR^+^ = 7.1 LR^-^ = 0.6
CRP > 20 mg/L [underlined: (fever > 12 hours duration)] | Bressan (2010)47 [7] | 99/58 7–28 d | Total: 5 (8.6) only low risk infants determined by the same criteria | 100.0 [56.6, 100.0] | 96.2 [87.2, 99.0] | 71.4 [35.9, 91.8] | 100.0 [93.0, 100.0] | LR^+^ = 0.2 LR^-^ = 0
WBC 10,000/mm^3^ | Brown (2005)43 [3] | 71/69 < 28 d | Total: 8 (12.0) UTI: 4 Bacteremia: 2 Other: NR | 100.0 [60.0, 100.0] | 31.0 [19.9, 44.7] | 17.0 [8.0, 30.7] | 100.0 [78.1, 100.0] | LR^+^ = 1.40 LR^-^ = 0
WBC 12,000/mm^3^ | Brown (2005)43 [3] | 71/69 < 28 d | Total: 8 (12.0) UTI: 4 Bacteremia: 2 Other: NR | 75.0 [35.5, 95.5] | 53.0 [41.6, 68.0] | 18.0 [7.8, 37.0] | 94.0 [78.9, 98.9] | LR^+^ = 1.60 LR^-^ = 0.50
WBC 15,000/mm^3^ | Brown (2005)43 [3] | 71/69 < 28 d | Total: 8 (12.0) UTI: 4 Bacteremia: 2 Other: NR | 50.0 [17.4, 82.5] | 74.0 [64.4, 87.0] | 21.0 [7.8, 50.2] | 91.0 [79.5, 97.3] | LR^+^ = 1.90 LR^-^ = 0.70
WBC 17,000/mm^3^ | Brown (2005)43 [3] | 71/69 < 28 d | Total: 8 (12.0) UTI: 4 Bacteremia: 2 Other: NR | 38.0 [9.0, 76.0] | 89.0 [78.1, 95.7] | 33.0 [9.0, 69.0] | 91.0 [80.0, 96.7] | LR^+^ = 3.80 LR^-^ = 0.70
WBC 5,000/mm^3^ | Brown (2005)43 [3] | 71/69 < 28 d | Total: 8 (12.0) UTI: 4 Bacteremia: 2 Other: NR | 100.0 [NC] | 2.0 [NC] | 12.0 [NC] | 100.0 [NC] | LR^+^ = 1.00 LR^-^ = 0
WBC within 5,000 - 10,000; 12,000 - 15,000; 17,000 - 20,000; 22,000 - 25,000/mm^3^ | Brown (2005)43 [3] | 71/69 < 28 d | Total: 8 (12.0) UTI: 4 Bacteremia: 2 Other: NR | NA | NA | NA | NA | ROC (AUC) = 72.3, 95% CI: 56.6, 87.9
WBC ≥ 15,000/mm^3^ | Caspe (1983)34 [11] | 305/107 0–30 d | Total: 7 (6.5) (bacteremia) | 28.6 [5.1, 69.7] | NR | NR | NR | NR
Blood Markers in Infants 0–60 d
PMN ≥ 10,000/mm^3^ | Berkowitz (1985)109 [3] | 434/239 < 60 d | Total: 10 (4.2) Sepsis/meningitis | 38.0 [NC] | 93.0 [NC] | NR | NR | LR^+^ = 5.42 LR^-^ = 0.66
WBC ≥ 15,000/mm^3^ | Berkowitz (1985)109 [3] | 434/239 < 60 d | Total: 10 (4.2) Sepsis/meningitis | 50.0 [NC] | 77.0 [NC] | NR | NR | LR^+^ = 2.17 LR^-^ = 0.64
WBC ≥ 15,000/mm^3^ + PMN ≥ 10,000/mm^3^ | Berkowitz (1985)109 [3] | 434/239 < 60 d | Total: 10 (4.2) Sepsis/meningitis | 38.0 [NC] | 94.0 [NC] | NR | NR | LR^+^ = 6.33 LR^-^ = 0.65
WBC ≥ 15,000/mm^3^ + ABC ≥ 500/mm^3^ | Berkowitz (1985)109 [3] | 434/239 < 60 d | Total: 10 (4.2) Sepsis/meningitis | 63.0 [NC] | 84.0 [NC] | NR | NR | LR^+^ = 3.93 LR^-^ = 0.44
ABC ≥ 500/mm^3^ | Berkowitz (1985)109 [3] | 434/239 < 60 d | Total: 10 (4.2) Sepsis/meningitis | 88.0 [NC] | 61.0 [NC] | NR | NR | LR^+^ = 2.25 LR^-^ = 0.19
Total WBC/mm^3^ (3,000, 10,000, 12,000, 18,000, 20,000) | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | NA | NA | NA | NA | ROC (AUC): 61.0 (SE: 0.038)
WBC >10,000/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 69.0 [57.7, 78.6] | 52.0 [48.2, 54.7] | 11.0 [8.5, 14.2] | 95.0 [92.6, 96.7] | LR^+^ = 1.43 LR^-^ = 0.59
WBC >12,000/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 51.0 [39.6, 61.8] | 72.0 [68.9, 74.8] | 14.0 [10.0, 18.1] | 94.0 [92.3, 95.9] | LR^+^ = 1.82 LR^-^ = 0.68
WBC >15,000/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 31.0 [21.3, 42.2] | 88.0 [85.5, 89.8] | 18.0 [12.3, 25.7] | 94.0 [91.6, 95.0] | LR^+^ = 2.58 LR^-^ = 0.78
WBC >20,000/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 16.0 [9.1, 26.2] | 97.0 [96.2, 98.3] | 35.0 [20.7, 52.6] | 93.0 [91.1, 94.5] | LR^+^ = 5.33 LR^-^ = 0.86
WBC >8,000/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 74.0 [62.9, 82.9] | 28.0 [25.4, 31.4] | 8.0 [6.4, 10.6] | 93.0 [88.7, 95.2] | LR^+^ = 1.02 LR^-^ = 0.92
ABC (250, 500, 1,000, 2,000, and 3,000/mm^3^) | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | NA | NA | NA | NA | ROC (AUC): 81 .0 (SE: 0.025)
ABC > 250/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 93.0 [82.4, 96.1] | 44.0 [40.8, 47.3] | 13.0 [9.9, 15.4] | 99.0 [96.4, 99.3] | LR^+^ = 1.66 LR^-^ = 0.15
ABC > 500/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 80.0 [76.5, 92.7] | 61.0 [55.5, 63.0] | 16.0 [12.3, 19.2] | 98.0 [96.4, 99.0] | LR^+^ = 2.05 LR^-^ = 0.32
ABC >1,000/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 74.0 [62.9, 82.9] | 80.0 [76.9, 82.1] | 24.0 [19.0, 30.0] | 97.0 [95.7, 98.2] | LR^+^ = 3.70 LR^-^ = 0.32
ABC>2,000/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 42.0 [31.2, 53.4] | 93.0 [91.2, 94.6] | 35.0 [25.5, 45.0] | 96.0 [93.1, 96.1] | LR^+^ = 6.00 LR^-^ = 0.62
ABC>3,000/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 19.0 [11.0, 29.0] | 98.0 [97.0, 98.9] | 47.0 [29.5, 64.9] | 93.0 [91.4, 94.7] | LR^+^ = 9.50 LR^-^ = 0.82
ABC>1,500/mm^3^ | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 50.0 [17.4, 82.5] | NR | NR | NR | NR
CBC Differential Ratio < 1 (Low risk) | Bonadio (1992)44 [10] | 1,009/ 1,009 4–60 d | Total: 81 (8.0) Meningitis: 21 UTI: 29 Bacteremia: 23 Enteritis: 8 | 87.5 [46.6, 99.3] | NR | NR | NR | NR
WBC > 15,000/μL | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 38.8 [31.0, 47.3] | 84.6 [82.4, 86.6] | NR | NR | LR^+^ = 2.5 LR^-^ = 0.7
WBC > 20,000/μL | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 16.4 [11.1–23.6] | 95.6 [94.3, 96.7] | NR | NR | LR^+^ = 3.8 LR^-^ =0.9
WBC < 4,100 or > 20,000/μL | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 17.2 [11.7, 24.4] | 93.2 [91.6, 94.6] | NR | NR | LR^+^ = 2.5 LR^-^ = 0.9
WBC < 5,000 or > 15,000/μL | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 42.5 [34.5, 51.0] | 79.3 [76.9, 81.6] | NR | NR | LR^+^ = 2.1 LR^-^ = 0.7
ANC >4.650/μL | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 70.9 [62.7, 77.9] | 63.3 [60.5, 66.1] | NR | NR | LR^+^ = 1.9 LR^-^ = 0.5
ANC>10,000/μL | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 28.4 [21.4, 36.5] | 95 [93.6, 96.0] | NR | NR | LR^+^ = 5.7 LR^-^ = 0.8
ANC>12.500/μL | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 11.9 [7.5, 18.5] | 97.8 [96.7, 98.5] | NR | NR | LR^+^ = 5.4 LR^-^ =0.9
ANC/WBC > 20% | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 98.5 [94.7, 99.6] | 7.2 [5.8, 8.9] | NR | NR | LR^+^ = 1.0 LR^-^ =0.2
ANC/WBC > 40% | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 76.1 [68.2, 82.6] | 50.0 [47.0, 52.9] | NR | NR | LR^+^ = 1.5 LR^-^ = 0.5
ANC/WBC > 60% | Bilavsky (2010)45 [9] | 1,257/ 1,257 0–60 d | Total SBI: 134 (10.7%) UTI: 104 Bacteremia + UTI: 9 Isolated bacteremia: 4 Bacteremia + enteritis: 3 Pneumonia: 13 Enteritis: 1 Bacterial meningitis: 0 | 27.6 [20.1, 35.7] | 89.6 [87.7, 91.2] | NR | NR | LR^+^ = 2.7 LR^-^ = 0.8
WBC ≥ 15,000 /μL | Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia) | 20.0 [1.0, 70.0] | 80.0 [66.2, 90.3] | 10.0 [0.5, 45.8] | 90.4 [76.4, 96.9] | LR^+^ = 1.00 LR^-^ = 1.00
ABC ≥ 5,000 /μL | Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia) | 80.0 [29.8, 98.9] | 57.0 [42.2, 71.4] | 16.6 [5.4, 38.1] | 96.4 [79.7, 99.8] | LR^+^ = 1.86 LR^-^ = 0.35
CRP ^+^ve | Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia) | 64.0 [17.0, 92.7] | 67.0 [52.7, 80.4] | 16.6 [4.4, 42.2] | 94.1 [78.9, 98.9] | LR^+^ = 1.93 LR^-^ = 0.53
ESR ≥ 30 mm/h | Broner (1990)32 [9] | NR/52 4–56 d | Total: 5 (9.6) (bacteremia) | 25.0 [1.0, 70.1] | 87.0 [73.5, 94.7] | 14.3 [0.7, 58.0] | 91.1 [77.8, 97.1] | LR^+^ = 1.92 LR^-^ = 0.86
WBC ≥ 15,000/mm^3^ | Caspe (1983)34 [11] | 305/198 30–60 d | Total: 4 (2.0) (bacteremia) | 75.0 [21.9, 98.7] | NR | NR | NR | NR
ESR ≥ 30 mm/h | Crain (1982)33 [11] | 134/99 0–60 d | Total: 5 (5.0) (bacteremia) | 80.0 [29.8, 98.9] | 93.6 [86.0, 97.3] | 40.0 [13.7, 72.6] | 99.0 [93.0, 99.9] | LR^+^ =12.50 LR^-^ = 0.21
Bacteriuria (Any number of bacteria by hpf) | Hoberman (1993)91 [11] | NR/306 0–59 d | Total: 14 (UTI) | 64.0 [35.6, 86.0] | NR | NR | NR | NR
% Immature neutrophils ≥ 20% | King (1987)a39 [6] | NR/321 < 60 d | Total: 16 (5.0) Bacteremia or meningitis | 69.0 [41.5, 87.9] | 75.0 [69.7, 79.7] | 12.6 [6.8, 21.9] | 97.0 [94.8, 99.2] | LR^+^ = 2.76 LR^-^ = 0.41
WBC ≤ 5,000 /mm^3^ | King (1987)a39 [6] | NR/342 < 60 d | Total: 16 (5.0) Bacteremia or meningitis | 44.0 [20.7, 69.4] | 96.0 [93.1, 97.7] | 35.0 [16.3, 59.0] | 97.0 [94.5, 98.6] | LR^+^ = 11.00 LR^-^ = 0.58
ESR ≥ 30 mm/h | King (1987)a39 [6] | NR/74 < 60 d | Total: 4 (5.4) Bacteremia or meningitis | 25.0 [1.3, 78.0] | 75.7 [63.7, 84.8] | 5.5 [0.2, 29.3] | 94.6 [84.2, 98.6] | LR^+^ = 1.04 LR^-^ = 0.99
WBC > 15,000 / μL | Lin (2000)53 [10] | 223/162 < 60 d | Total: 22 (13.5) (UTI) | 36.0 [18.0, 59.1] | 80.0 [72.2, 86.0] | 22.2 [10.7, 39.6] | 88.9 [81.7, 93.5] | LR^+^ = 1.80 LR^-^ = 0.80
CRP > 20 mg/L | Lin (2000)53 [10] | 223/162 < 60 d | Total: 22 (13.5) (UTI) | 59.0 [36.6, 78.5] | 90.0 [83.5, 94.2] | 48.1 [29.1, 67.6] | 93.3 [87.3, 96.7] | LR^+^ = 5.90 LR^-^ = 0.40
ESR > 30 mm/h | Lin (2000)53 [10] | 223/162 < 60 d | Total: 22 (13.5) (UTI) | 73.0 [49.5, 88.4] | 78.0 [69.9, 84.2] | 34.0 [21.3, 49.4] | 94.7 [88.5, 97.8] | LR^+^ = 3.30 LR^-^ = 0.30
Blood Markers in Infants 0–90 d
WBC > 15,000/μL | Bilavsky (2009) 46 [8] | 892/892 0–90 d | Total: 102 (11.3) UTI: 84 Bacteremia: 6 Pneumonia: 11 Meningitis: 1 | 48.0 [38.6, 57.6] | 84.1 [81.4, 86.5] | NR | NR | LR^+^ = 3.00 LR^-^ = 0.60
WBC > 20,000/μL | Bilavsky (2009) 46 [8] | 892/892 0–90 d | Total: 102 (11.3) UTI: 84 Bacteremia: 6 Pneumonia: 11 Meningitis: 1 | 21.6 [14.7, 30.5] | 95.2 [93.5, 96.5] | NR | NR | LR^+^ = 4.50 LR^-^ = 0.80
WBC > 15,000/μL or WBC < 5,000/μL | Bilavsky (2009) 46 [8] | 892/892 0–90 d | Total: 102 (11.3) UTI: 84 Bacteremia: 6 Pneumonia: 11 Meningitis: 1 | 50.0 [40.5, 59.5] | 78.1 [75.0, 80.8] | NR | NR | LR^+^ = 2.30 LR^-^ = 0.60
CRP > 8 mg/dL | Bilavsky (2009)46 [8] | 892/892 0–90 d | Total: 102 (11.3) UTI: 84 Bacteremia: 6 Pneumonia: 11 Meningitis: 1 | 23.5 [16.4, 32.6] | 98.2 [97.1, 98.9] | NR | NR | LR^+^ = 13.30 LR^-^ = 0.80
CRP > 4 mg/dL | Bilavsky (2009)46 [8] | 892/892 0–90 d | Total: 102 (11.3) UTI: 84 Bacteremia: 6 Pneumonia: 11 Meningitis: 1 | 44.1 [34.9, 53.8] | 92.2 [90.1, 93.8] | NR | NR | LR^+^ = 5.60 LR^-^ = 0.60
CRP > 2 mg/dL | Bilavsky (2009)46 [8] | 892/892 0–90 d | Total: 102 (11.3) UTI: 84 Bacteremia: 6 Pneumonia: 11 Meningitis: 1 | 55.9 [46.2, 65.1] | 82.2 [79.3, 84.7] | NR | NR | LR^+^ = 3.10 LR^-^ = 0.50
WBC < 5,000/mm^3^ | Bonsu (2003)111 [9] | 3,961/ 3,810 0–89 d | Total: 38 (1.0) (bacteremia) | - | - | - | - | LR = 3.90
WBC < 5,000 or WBC ≥ 15,000/mm^3^ | Bonsu (2003)111 [9] | 3,961/ 3,810 0–89 d | Total: 38 (1.0) (bacteremia) | 66.0 [49.0, 80.0] | 72.0 [71.0, 74.0] | 2.3 [1.5, 3.5] | 99.5 [99.1, 99.7] | LR^+^ = 2.37 LR^-^ = 0.47
WBC < 5,000 or WBC 20,000/mm^3^ | Bonsu (2003)111 [9] | 3,961/ 3,810 0–89 d | Total: 38 (1.0) (bacteremia) | 45.0 [29.0, 62.0] | 88.0 [87.0, 89.0] | 3.6 [2.2, 5.8] | 99.3 [99.0, 99.6] | LR^+^ = 3.70 LR^-^ = 0.62
WBC ≥ 10,000/mm^3^ | Bonsu (2003)111 [9] | 3,961/ 3,810 0–89 d | Total: 38 (1.0) (bacteremia) | 61.0 [43.0, 76.0] | 42.0 [40.0, 44.0] | 1.0 [0.6, 1.5] | 99.0 [98.4, 99.4] | LR^+^ = 1.04 LR^-^ = 0.94
WBC ≥ 15,000/mm^3^ | Bonsu (2003)111 [9] | 3,961/ 3,810 0–89 d | Total: 38 (1.0) (bacteremia) | 45.0 [29.0, 62.0] | 78.0 [76.0, 79.0] | 2.0 [1.2, 3.2] | 99.3 [98.9, 99.5] | LR^+^ = 2.00 LR^-^ = 0.71
WBC ≥ 20,000/mm^3^ | Bonsu (2003)111 [9] | 3,961/ 3,810 0–89 d | Total: 38 (1.0) (bacteremia) | 24.0 [11.0, 40.0] | 93.0 [92.0, 94.0] | 3.4 [1.6, 6.6] | 99.1 [98.8, 99.4] | LR^+^ = 3.50 LR^-^ = 0.81
WBC ≥ 5,000/mm^3^ | Bonsu (2003)111 [9] | 3,961/ 3,810 0–89 d | Total: 38 (1.0) (bacteremia) | 79.0 [63.0, 90.0] | 5.0 [4.0, 6.0] | 0.8 [0.6, 1.2] | 96.2 [92.3, 98.2] | LR^+^ = 0.83 LR^-^ = 3.95
WBC ≤5,000 - ≤15,000/mm^3^ | Bonsu (2003)111 [9] | 3,961/ 3,810 0–89 d | Total: 38 (1.0) (bacteremia) | NA | NA | NA | NA | LR = 0.40
ANC ≥ 10,000/mm^3^ | Gomez (2010) 30 [9] | 1,125/1018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | NR/NC | NR/NC | NR/NC | NR/NC | AUC=71.1% [58.5, 83.8]
WBC ≥ 15,000/mm^3^ | Gomez (2010) 30 [9] | 1,125/1018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | NR/NC | NR/NC | NR/NC | NR/NC | AUC=67.9% [55.3, 80.4]
CRP at 70 g/L | Gomez (2010)30 [9] | 1,125/ 1,018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 69.6 [49.1, 89.4] | 93.8 [92.1, 95.1] | 20.5 [14.1, 25.3] | 99.3 [98.5, 99.6] | LR^+^ = 11.17 LR^-^ = 0.32 AUC=84.7% [75.4, 94.0]
CRP at 20 g/L | Gomez (2010)30 [9] | 1,125/ 1,018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 73.9 [53.5, 87.5] | 74.8 [72.0, 77.5] | 6.3 [4.4, 7.6] | 99.2 [98.5, 99.7] | LR^+^ = 2.93 LR^-^ = 0.34 AUC=84.7% [75.4, 94.0]
PCT at 0.13 ng/mL | Maniaci (2008)61 [11] | 435/234 0–90 d | Total: 30 (12.8) Bacteremia: 4 Bacteremia + UTI: 2 UTI: 24 | 96.7 [81.0, 99.8] | 30.3 [24.0, 37.5] | NR | 98.3 [89.7, 99.9] | NR
PCT-Q (semi-quantitative PCT) ≥ 0.5 ng/mL | Olaciregui (2008)48 [10] | 375/347 0–90 d | Total: 82 (23.6) UTI: 69 (4 with bacteremia) Bacteremia: 5 Cellulitis: 2 (1 with bacteremia) Sepsis: 4 (2 with bacteremia) Gastroenteritis: 1 with bacteremia | 63.0 [52.0, 74.0] | 87.0 [83.0, 91.0] | 59.0 [48.0, 70.0] | 89.0 [85.0, 93.0] | LR+ = 4.8 LR- = 0.42
Leucocyte count (5,000–15,000), CRP (<30), PCT (<0.5), good general state and –ve urine dipstick | Olaciregui (2008)48 [10] | 375/347 0–90 d | Total: 82 (23.6) UTI: 69 (4 with bacteremia) Bacteremia: 5 Cellulitis: 2 (1 with bacteremia) Sepsis: 4 (2 with bacteremia) Gastroenteritis: 1 with bacteremia | 96.0 [88.0, 99.0] | 35.0 [29.0, 42.0] | 32.0 [25.0, 38.0] | 96.0 [92.0, 100] | LR+ = 1.48 LR- = 0.11
PCT-Q (semi-quantitative PCT) > 0.5 ng/mL | Olaciregui (2008)48 [10] | 375/347 0–90 d | Bacteremia: 5 (1.4) | 86 .0 [58.0, 100.0] | 93.0 [90.0, 96.0] | 35.0 [19.0, 51.0] | 99.0 [98.0, 100.0] | LR+ = 12.3 LR- = 0.15
Leucocyte count (5,000–15,000), CRP (<30), PCT (<0.5), good general state and –ve urine dipstick | Olaciregui (2008)48 [10] | 375/347 0–90 d | Bacteremia: 5 (1.4) | 100 [74.0, 100.00] | 29 [24.0, 35.0] | 6 [3.0, 9.0] | 100 [96.0, 100.0] | LR+ = 1.4 LR- = 0
CRP ≥ 30 mg/L | Olaciregui (2008)48 [10] | 375/347 0–90 d | Total: 82 (23.6) UTI: 69 (4 with bacteremia) Bacteremia: 5 Cellulitis: 2 (1 with bacteremia) Sepsis: 4 (2 with bacteremia) Gastroenteritis + bacteremia: 1 | 59.0 [48, 70] | 89.0 [85.0, 93] | 63.0 [52.0, 74.0] | 87.0 [83.0, 91.0] | LR+ = 5.4 LR- = 0.46
CRP ≥ 20 mg/L | Olaciregui (2008)48 [10] | 375/347 0–90 d | Total: 82 (23.6) UTI: 69 (4 with bacteremia) Bacteremia: 5 Cellulitis: 2 (1 with bacteremia) Sepsis: 4 (2 with bacteremia) Gastroenteritis + bacteremia: 1 | 64.0 [54.0, 74.0] | 84.0 [80.0, 88.0] | 55 [45.0, 65.0] | 88.0 [84.0, 92.0] | LR+ = 4.0 LR- = 0.43
CRP > 30 mg/L | Olaciregui (2008)48 [10] | 375/347 0–90 d | Bacteremia: 5 (1.4) | 56.0 [32.0, 80] | 74.0 [69.0, 79.0] | 9.6 [4.0, 16.0] | 97 [95.0, 99.0] | LR+ = 2.15 LR- = 0.59
Cerebro-Spinal Fluid (CSF) Markers
CSF pleocytosis (≥ 20 WBC/mm^3^ and > 1 WBC per 500 red blood cells/mm^3^) | Caviness (2008)63 [8] | 960/800 0–28 d | Total: 119 (14.8) UTI: 78 Bacteremia: 29 Meningitis: 12 | 31.1 [23.1, 40.3] | 75.5 [72.0, 78.6] | 18.1 [13.2, 24.2] | 86.2 [83.1, 88.8] | LR^+^ = 1.26 LR^-^ = 0.91
CSF pleocytosis (≥ 20 WBC/mm^3^ and > 1 WBC per 500 red blood cells/mm^3^) | Caviness (2008)63 [8] | 960/800 0–28 d | Bacteremia: 29 | 34.5 [18.6, 54.3] | 74.8 [71.6, 77.8] | 4.9 [2.5, 9.1] | 96.8 [95.0, 98.0] | LR^+^ = 1.37 LR^-^ = 0.87
CSF pleocytosis (≥ 20 WBC/mm^3^ and > 1 WBC per 500 red blood cells/mm^3^) | Caviness (2008)63 [8] | 960/800 0–28 d | Meningitis: 12 | 91.6 [59.7, 99.5] | 75.5 [72.3, 78.4] | 5.4 [2.8, 9.6] | 99.8 [98.9, 99.9] | LR^+^ = 3.74 LR^-^ = 0.11
CSF pleocytosis (neonates: WBC ≥ 25 cells/ μL; age 29–90 d: WBC ≥ 10 cells/ μL) | Meehan (2008)69 [9] | 2,820/ 2,003 0–90 d | Total: 192 UTI: 160 Bacteremia: 25 Meningitis: 7 | 12.5 [8.3, 18.2] | 91.6 [90.2, 92.8] | 13.6 [9.1, 19.8] | 90.8 [89.3, 92.0] | LR^+^ = 1.48 LR^-^ = 0.95
CSF pleocytosis (neonates: WBC ≥ 25 cells/ μL; age 29–90 d: WBC ≥ 10 cells/ μL) | Meehan (2008)69 [9] | 2,820/ 2,003 0–90 d | Bacteremia: 25 | 28.0 [12.8, 49.6] | 91.4 [90.1, 92.6] | 3.9 [1.7, 8.3] | 99.0 [98.4, 99.4] | LR^+^ = 3.27 LR^-^ = 0.78
CSF pleocytosis (neonates: WBC ≥ 25 cells/ μL; age 29–90 d: WBC ≥ 10 cells/ μL) | Meehan (2008)69 [9] | 2,820/ 2,003 0–90 d | Meningitis: 7 | 71.4 [30.2, 94.8] | 91.4 [90.1, 92.6] | 2.8 [1.0, 6.8] | 99.9 [99.5, 99.9] | LR^+^ = 8.33 LR^-^ = 0.31
>Urine Markers
Urine - UA: dipstick (LE^+^, nitrite, ^+^ or both) and microscopy (pyuria: ≥ 5 WBC/hpf) | Bachur (2001)52 [8] | NR/868 0–29 d | UTI: 73 (8.4) | 82.0 [71.0, 90.0] | 92.0 [90.0, 94.0] | 48.4 [39.4, 57.5] | 98.2 [96.9, 99.0] | LR^+^ = 10.25 LR^-^ = 0.19
Urine - UA: dipstick (LE^+^, nitrite, ^+^ or both) and microscopy (pyuria: ≥ 5 WBC/hpf) | Bachur (2001)52 [8] | NR/2,283 29–89 d | UTI: 172 (7.5) | 82.0 [75.0, 87.0] | 94.0 [93.0, 95.0] | 52.6 [46.4, 58.7] | 98.4 [97.8, 98.9] | LR^+^ = 13.60 LR^-^ = 0.20
Urine – UA (LE^+^ or nitrite^+^) | Bachur (2001)49 [12] | 5,279/ 5,279 0–90 d | Total: 373 (7.0) UTI: 297 Meningitis: 17 Bacteremia: 40 Bacteremia/meningitis: 8 Bacteremia/UTI: 11 | 71.0 [66.0, 76.0] | NR | NR | NR | NR
Urine – UA (LE^+^ or nitrite^+^) | Bachur (2001)49 [12] | 5,279/ 5,279 0–90 d | UTI: 297 (5.6) | 81.0 [76.0, 85.0] | NR | NR | NR | NR
Urine – UA (LE,^+^ nitrite,^+^ or protein) | Bonsu (2007)50 [11] | 3,765/ 3,765 0–89 d | UTI: 307 (8.1) (UTI with sepsis) | 84.0 [79.3, 87.8] | 63.6 [62.0, 65.2] | 17.0 [15.1, 19.0] | 97.8 [97.1, 98.3] | LR^+^ = 2.31 LR^-^ = 0.25
Urine - Any LE alone | Dayan (2002)13 [11] | 246/193 1 - 60 d | UTI: 27(14.0) | 80.0 [62.5, 97.5] | 94.2 [90.7, 97.7] | 67.7 [48.5, 82.6] | 96.3 [91.7, 98.5] | LR^+^ = 13.80 LR^-^ = 0.21
Urine - Any nitrite alone | Dayan (2002)13 [11] | 246/193 1 - 60 d | UTI: 27(14.0) | 35.0 [14.1, 55.9] | 97.7 [95.4, 99.9] | 69.2 [38.8, 89.6] | 90.0 [84.4, 93.8] | LR^+^ = 15.10 LR^-^ = 0.67
Urine - Gram stain, any organisms | Dayan (2002)13 [11] | 246/193 1 - 60 d | UTI: 27(14.0) | 80.0 [62.5, 97.5] | 99.4 [93.8, 100.0] | 95.6† [76.0, 99.8] | 96.8 [92.9, 98.9] | LR^+^ = 138.40 LR^-^ = 0.20
Urine - Nitrite + LE | Dayan (2002)13 [11] | 246/193 1 - 60 d | UTI: 27(14.0) | 30.0 [10.0, 50.0] | 100.0 [98.3, 100.0] | 100.0 [60.0, 100.0] | 89.7 [84.2, 93.5] | LR^+^ = ∞ LR^-^ = NA
Urine - UA (LE^+^ or nitrite^+^) | Dayan (2002)13 [11] | 246/193 1 - 60 d | UTI: 27(14.0) | 85.0 [69.4, 100.0] | 91.9 [87.8, 96.0] | 62.1 [44.8, 77.0] | 97.4 [93.1, 99.1] | LR^+^ = NA LR^-^ = 0.16
Urine –Microscopy of spun urine (≥ 5 WBC/hpf) | Dayan (2002)13 [11] | 246/193 1 - 60 d | UTI: 27(14.0) | 65.0 [44.1, 85.9] | 92.4 [88.6, 96.4] | 56.6 [37.6, 74.0] | 93.8 [88.7, 96.8] | LR^+^ = 8.60 LR^-^ = 0.38
Urine –Microscopy of spun urine (≥ 10 WBC/hpf) | Dayan (2002)13 [11] | 246/193 1 - 60 d | UTI: 27(14.0) | 45.0 [23.2, 66.8] | 97.6 [95.4, 99.9] | 75.0 [47.4, 91.6] | 91.5 [86.1, 95.0] | LR^+^ = 19.50 LR^-^ = 0.56
Urine - UA: dipstick (LE^+^, nitrite, ^+^ or both) | Gomez (2010) 30 [9] | 1,125/ 1,018 0–90 d | Total: 23 (2.2) Bacteremia: 9 UTI/bacteremia: 8 Meningitis: 4 Sepsis: 2 | 43.5 [24.1, 64.8] | 82.8 [82.3, 83.3] | 5.6 [3.1, 8.4] | 98.4 [97.9, 99.0] | LR^+^ = 2.52 LR^-^ = 0.68
Urine –UA Microscopy (hemocytometer; ≥ 10 WBC/μL) | Lin (2000)53 [10] | 223/162 < 60 d | UTI: 22 (13.5) | 82.0 [59.0, 94.0] | 94.0 [88.6, 97.3] | 69.2 [48.1, 84.9] | 97.0 [92.2, 99.0] | LR^+^ = 12.70 LR^-^ = 0.20
Urine – UA Microscopy (spun urine; ≥ 5 WBC/hpf) | Lin (2000)53 [10] | 223/162 < 60 d | UTI: 22 (13.5) | 59.0 [36.7, 78.5] | 93.0 [86.9, 96.3] | 56.5 [34.8, 76.1] | 93.5 [87.7, 96.8] | LR^+^ = 8.30 LR^-^ = 0.40
Urine – UA Microscopy (spun urine; ≥ 5 WBC/hpf, LE^+^ or nitrite^+^) | Reardon (2009) 54 [8] | NR/51 < 90 d | Total: NR (UTI) | 40.0 [7.0, 83.0] | 85.0 [71.0, 93.0] | NR | NR | NR
Urine –UA (LE^+^) by bag | Schroeder (2005)5,51 | 3,066/ 1,482 0–90 d | UTI: 152 (10.2) UTI/bacteremia: 16 | 76.0 [NC] | 84.0 [NC] | NR | NR | LR^+^ = 4.75 LR^-^ = 0.28
Urine - UA (LE^+^) by CATH | Schroeder (2005)5,51 | 3,066/ 1,482 0–90 d | UTI: 152 (10.2) UTI/bacteremia: 16 | 86.0 [NC] | 94.0 [NC] | NR | NR | LR^+^ = 14.33 LR^-^ = 0.14
Urine – UA (LE^+^) combined both methods: bag/CATH | Schroeder (2005)5,51 | 3,066/ 1,482 0–90 d | UTI: 152 (10.2) UTI/bacteremia: 16 | 84.0 [NC] | 91.0 [NC] | NR | NR | LR^+^ = 9.33 LR^-^ = 0.17
Urine – UA\ (Nitrites ^+^) by bag | Schroeder (2005)5,51 | 3,066/ 1,482 0–90 d | UTI: 152 (10.2) UTI/bacteremia: 16 | 25.0 [NC] | 98.0 [NC] | NR | NR | LR^+^ = 17.50 LR^-^ = 0.76
Urine - UA (Nitrites ^+^) by CATH | Schroeder (2005)5,51 | 3,066/ 1,482 0–90 d | UTI: 152 (10.2) UTI/bacteremia: 16 | 43.0 [NC] | 99.0 [NC] | NR | NR | LR^+^ = 43.00 LR^-^ = 0.57
Urine - UA (Nitrites^+^) combined both methods: bag/CATH | Schroeder (2005)5,51 | 3,066/ 1,482 0–90 d | UTI: 152 (10.2) UTI/bacteremia: 16 | 39.0 [NC] | 99.0 [NC] | NR | NR | LR^+^ = 39.00 LR^-^ = 0.61
Urine microscopy (0-2, 3-5, 6-10, 11-20, > 20 WBC/hpf) combined both methods: bag/CATH | Schroeder (2005)5,51 | 3,066/ 1,056 0–90d | UTI: 152 (10.2) UTI/bacteremia: 16 | NR | NR | NR | NR | ROC (AUC): 83.0%, 95% CI: 79.0, 87.0
Urine microscopy (0-2, 3-5, 6-10, 11-20, > 20 WBC/hpf) by bag | Schroeder (2005)5,51 | 3,066/273 0–90d | UTI: 152 (10.2) UTI/bacteremia: 16 | NR | NR | NR | NR | ROC (AUC): 71.0%, 95% CI: 61.0, 82.0
Urine microscopy (0-2, 3-5, 6-10, 11-20, > 20 WBC/hpf) by CATH | Schroeder (2005)5,51 | 3,066/716 0–90d | UTI: 152 (10.2) UTI/bacteremia: 16 | NR | NR | NR | NR | ROC (AUC): 86.0%, 95% CI: 82.0, 91.0
Urine dipstick– UA (absence of LE) | Schwartz (2009)37 | 644/449 0–28 d | Total: 87 (19.4) UTI: 82 | 73.2 [NR] | NR | NR | 94.1 [91.7, 96.3] | NR

ABC = absolute band count; ANC = absolute neutrophil count; CATH = catheterization; CBC = complete blood count; CRP = C-reactive protein; CSF = cerebrospinal fluid; d = day(s); ESR = erythrocyte sedimentation rate; hpf = high-power field; LE = leukocyte esterase; LR = likelihood ratio; NA = not applicable; NC = not calculable; NPV = negative predictive value; NR = not reported; PCT = Procalcitonin; PMN = polymorphonuclear count; PPV = positive predictive value; ROC (AUC) = receiver operating characteristic (area under the curve); SBI = serious bacterial infection; SE = standard error; UA = urinanalysis; UTI = urinary tract infection; WBC = white blood cell count; +ve = positive

* N/n: number of infants enrolled/number of infants with test and culture results

#### Combined Clinical and Laboratory Criteria/Protocols (Philadelphia, Boston, Rochester, Milwaukee, and Young Infant Observation Scale)

Total serious bacterial infection. The performance characteristics of the Philadelphia, Boston, Rochester, Milwaukee protocol/criteria, and Young Infant Observation Scale (YIOS) for predicting the risk of total SBI in febrile infants was reported and/or ascertained from 19 studies (Table 2).9-12,21-27,35,55-60,64

Based on results from 17 studies, the Philadelphia, 9,11,12,25,58,59 Rochester,23-27,35,57,60 Boston, 35,55 and Milwaukee criteria 10 demonstrated similar degree of overall accuracy (i.e., sensitivity and specificity) in correctly classifying febrile infants with and without SBI (e.g., UTI, bacteremia, meningitis, pneumonia, and gastroenteritis). Specifically, these four criteria showed high sensitivity (range: 84.4 percent–100.0 percent), and as expected, lower specificity (range: 26.6 percent–69.0 percent) for identifying infants without SBI. The probability of being free of SBI among test-negative infants (i.e., NPV) across these 4 criteria was also high (> 94.0 percent).

The pooling of sensitivity values was possible for only Rochester (94.0 percent; 95.0 percent CI: 91.0, 96.0) 23-27,57,60 and Philadelphia criteria (93.0 percent; 95 percent CI: 89.0, 95.0). 9,11,12,22,25,58 The specificity for Rochester (range: 36.0 percent to 69.0 percent) and Philadelphia criteria (range: 27.0 percent to 67.0 percent) could not be pooled due to high degree of statistical heterogeneity (Rochester: I^2^ = 95.9 percent, Chi-squared = 147.0, p<0.01 and Philadelphia: I^2^ = 96.8 percent, Chi-squared = 157.2, p<0.01). The forest plots for sensitivity and specificity of Rochester and Philadelphia protocol/criteria are given in Figures 2–5.

Figure 2 Sensitivity plots (Rochester criteria)

Figure 2 and Figure 3 depict summary receiver operating characteristic curves (SROC) for the Rochester criteria and Philadelphia protocol, respectively. SROC is a method of summarizing the overall performance of an index test across different studies regardless of thresholds used in these studies. Specifically, this method represents a plot of the pairs of sensitivity and specificity for each study on a two-dimensional plane connected by a curve, where sensitivity (true positive rate) is a function of 1-specificity (false positive rate). The area under the curve (AUC) indicates the overall accuracy performance of a given test. A greater magnitude of AUC corresponds to a better accuracy for an index test. Given, Figures 2-3, the AUCs of the Rochester criteria and Philadelphia protocol are 72.5% and 75.3%, respectively, showing similar degree of accuracy in distinguishing infants with and without SBI. For example, the AUC of 72.5% for the Rochester criteria (Figure 2) is interpreted as the probability of correctly classifying randomly chosen pair of infants with and without SBI into high-risk and low-risk groups, respectively.

| Sensitivity (95% CI)
Byington 2004 | 0.92 (0.85 - 0.96)
Chiu 1997 | 0.98 (0.87 - 1.00)
Ferrera 1997 | 0.86 (0.65 - 0.97)
Garra 2005 | 0.97 (0.89 - 1.00)
Jaskiewicz 1994 | 0.92 (0.83 - 0.97)
Dagan 1988 | 1.00 (0.84 - 1.00)
Dagan 1985 | 0.96 (0.78 - 1.00)

Pooled Sensitivity = 0.94 (0.91 to 0.96)

Chi-square = 7.94; df = 6 (p = 0.2423)

Inconsistency (I-square) = 24.5 %

Figure 3 Specificity plots (Rochester criteria)

Figure 2 and Figure 3 depict summary receiver operating characteristic curves (SROC) for the Rochester criteria and Philadelphia protocol, respectively. SROC is a method of summarizing the overall performance of an index test across different studies regardless of thresholds used in these studies. Specifically, this method represents a plot of the pairs of sensitivity and specificity for each study on a two-dimensional plane connected by a curve, where sensitivity (true positive rate) is a function of 1-specificity (false positive rate). The area under the curve (AUC) indicates the overall accuracy performance of a given test. A greater magnitude of AUC corresponds to a better accuracy for an index test. Given, Figures 2-3, the AUCs of the Rochester criteria and Philadelphia protocol are 72.5% and 75.3%, respectively, showing similar degree of accuracy in distinguishing infants with and without SBI. For example, the AUC of 72.5% for the Rochester criteria (Figure 2) is interpreted as the probability of correctly classifying randomly chosen pair of infants with and without SBI into high-risk and low-risk groups, respectively.

| Specificity (95% CI)
Byington 2004 | 0.36 (0.33 - 0.39)
Chiu 1997 | 0.62 (0.55 - 0.69)
Ferrera 1997 | 0.46 (0.36 - 0.57)
Garra 2005 | 0.37 (0.30 - 0.44)
Jaskiewicz 1994 | 0.50 (0.47 - 0.53)
Dagan 1988 | 0.69 (0.62 - 0.75)
Dagan 1985 | 0.68 (0.61 - 0.74)

Pooled Specificity = 0.49 (0.47 to 0.51)

Chi-square = 147.05; df = 6 (p = 0.0000)

Inconsistency (I-square) = 95.9 %

Figure 4 Sensitivity plots (Philadelphia protocol)

Figure 4 and Figure 5 depict plots of sensitivity and specificity values, respectively for the Rochester criteria as reported across 7 studies. In Figure 4, the reported sensitivity values ranged from 36% to 100% with a pooled sensitivity of 94%. In Figure 5, the reported specificity values ranged from 36% to 69%, with a pooled specificity of 49%.

| Sensitivity (95% CI)
Baker 1993 | 0.98 (0.92 - 1.00)
Baker 1999a | 1.00 (0.92 - 1.00)
Baker 1999b | 0.84 (0.67 - 0.95)
Brik 1997 | 0.87 (0.75 - 0.94)
Garra 2005 | 0.97 (0.89 - 1.00)
Kadish 2000 | 0.87 (0.73 - 0.95)

Pooled Sensitivity = 0.93 (0.89 to 0.95)

Chi-square = 20.41; df = 5 (p = 0.0010)

Inconsistency (I-square) = 75.5 %

Figure 5 Specificity plots (Philadelphia protocol)

Figure 4 and Figure 5 depict plots of sensitivity and specificity values, respectively for the Rochester criteria as reported across 7 studies. In Figure 4, the reported sensitivity values ranged from 36% to 100% with a pooled sensitivity of 94%. In Figure 5, the reported specificity values ranged from 36% to 69%, with a pooled specificity of 49%.

| Specificity (95% CI)
Baker 1993 | 0.42 (0.38 - 0.46)
Baker 1999a | 0.27 (0.22 - 0.31)
Baker 1999b | 0.47 (0.40 - 0.54)
Brik 1997 | 0.67 (0.62 - 0.71)
Garra 2005 | 0.37 (0.30 - 0.44)
Kadish 2000 | 0.55 (0.49 - 0.61)

Pooled Specificity = 0.46 (0.44 to 0.48)

Chi-square = 157.18; df = 5 (p = 0.0000)

Inconsistency (I-square) = 96.8 %

Three studies reporting lowest sensitivity values for the Rochester (52.0 percent and 59.0 percent) 10,56 and Boston criteria (82.0 percent) 22 were not considered in the analyses. The included infants in the first study,56 were older (up to 89 days) than it is specified in the Rochester criteria (≤ 2 months). The second study 10 did not report the inclusion/exclusion criteria and baseline characteristics of the included infants. The third study,22 included infants 28 days or younger, that is, outside the age eligibility of the Boston criteria (28 - 89 days).

In one study of febrile infants 2 months or younger,21 the Young Infant Observation Scale (YIOS) was evaluated for predicting risk of total SBI. The YIOS included three factors (affect, respiratory status, and peripheral perfusion which were scored as 1 (no compromise), 3 (intermediate level of compromise), or 5 (severe compromise). For predicting the risk of total SBI, the YIOS score ≥7 yielded the sensitivity, specificity, and NPV of 76.0 percent, 75.0 percent, and 96.0 percent, respectively.

In two studies of infants 2 months or younger,64,65 the application of Yale Observation Score (YOS > 10 denoting a high risk of SBI given ill appearance) demonstrated low sensitivity in correctly identifying infants with UTI (4.4 percent, 95 percent CI: 1.4, 11.5)65 or total SBI (33.3 percent, 95 percent CI: 11.3, 64.5).64

Specific types of serious bacterial infection. The accuracy indices of Boston,22 Philadelphia,9,11,12,22,25,58 and Rochester 10,23-27,56,57 protocols/criteria for identifying febrile infants with bacteremia, meningitis, and/or bacteremia/meningitis were ascertained for 14 studies. This information could not be ascertained for the Milwaukee criteria.10

The sensitivities of Boston,22 Rochester,23-27 and Philadelphia criteria9,11,12,22,25 in identifying bacteremia overlapped and ranged from 75.0 percent to 100.0 percent. The corresponding specificity for bacteremia was more variable across these criteria, ranging from 19.1 percent–51.1 percent for Philadelphia, 26.3 percent–64.9 percent for Rochester criteria, and 63.3 percent for Boston criteria. In one study, for the Rochester criteria, the sensitivity value for correctly identifying bacteremia was 33.3 percent (see SBI subsection for more detail about this study).10 The probability of being free of bacteremia among test-negative infants (i.e., NPV) for the Philadelphia, Boston, and Rochester criteria was 97.0 percent or greater. The sensitivity of Yale Observation Score (YOS) test in predicting bacterial sepsis was 75.0 percent (95 percent CI: 21.9, 98.6).64

The Philadelphia protocol demonstrated high sensitivity (100.0 percent) and high NPV (100 percent) but lower specificity (24.2 percent9–50.7 percent22) in correctly identifying meningitis.

There was insufficient data to compare the validity indices across these criteria with respect to the identification of infants with meningitis. The use of Rochester criteria,10 reported to have misclassified two cases of bacterial meningitis (total of four cases) into the category of low risk for SBI.

Combined clinical and laboratory criteria (other). The data on the diagnostic accuracy of different combinations of clinical (e.g., clinical/good/toxic/ill appearance, impression of sepsis, age, rectal temperature, unremarkable medical history) and laboratory features such as serum and urine WBC (with different thresholds), ABC ≥ 5,000/μL, ESR < 30 (or 20) mm/h, C-reactive protein (CRP) < 20 mg/L, or urine dipstick result (leukocyturia and/or nitrituria) were reported for 16 studies (Table 3).5,28-34,37,49,66-68,70,82,85

Total serious bacterial infection. Criteria that combined infant appearance (e.g., well, ill, good) with various laboratory features (e.g., WBC: 5,000–15,000/mm^3^, ESR < 30 mm/h, CRP < 20 mg/L, UA-WBC < 10/hpf, ABC ≤ 1,500/mm^3^, CSF-WBC < 23/hpf, and/or urine dipstick test for the presence of leukocyturia/ nitrituria), reported across 6 studies,28-30,37,66,67 were able to rule out the presence of total SBI with sensitivity ranging from 68.3 percent28 to 99.1 percent.29 The same criteria yielded specificity values ranging from 37.6 percent28 to 60.3 percent.66 The NPVs for these criteria ranged from 90.0 percent28 to 99.4 percent.29,30 The combination of clinical appearance and laboratory values (WBC: 5,000-15,000/mm^3^, ESR < 30 mm/h, normal UA: LE/nitrites) had the highest overall accuracy in correctly classifying infants with and without SBI (sensitivity 99.1 percent, specificity 59.3 percent, and NPV 99.4).29

Criteria that combined infant age (< 13 days) and rectal temperature of 39.6°C with WBC < 4,100/mm^3^ or WBC > 20,000/mm^3^ and test positive for LE or nitrate demonstrated similar accuracy (sensitivity: 82.0 percent, specificity: 76.0 percent, and NPV=98.3 percent)49 to criteria that combined infant sex (male) with spun urine WBC count ≥ 10/hpf and CRP ≥3.6 mg/L (sensitivity: 78.0 percent, specificity: 78.0 percent, NPV=not available).82 One of these criteria misclassified one case of bacterial meningitis into low risk.49

Criteria consisting of the lack of mild upper respiratory tract infection symptoms (URI) and no URI symptoms in the patient's sibling combined with CRP ≥ 1.87 mg/dL yielded relatively lower sensitivity (61.0 percent) but higher specificity (90.0 percent) in correctly identifying the absence or presence of SBI.68

Specific types of serious bacterial infection. Criteria that combined clinical impression of sepsis/toxic appearance with one or more laboratory features (e.g., WBC ≥ 15,000/mm^3^, ABC ≥ 5,000/μL, ESR ≥ 30 mm/h, CRP positive) reported in 3 studies ruled out the presence of sepsis/meningitis31 or bacteremia32,33 with sensitivity of 100.0 percent and specificity ranging from 17.0 percent33 to 75.0 percent.31 The NPV reported in these studies was 100.0 percent. The ill appearance combined with WBC ≥ 15,000/mm^3^ reported in two studies demonstrated lower sensitivity for identifying bacteremia (75.0 percent in infants aged 1-2 months and 28.5 percent in neonates 30 days or younger)34 or bacteremia/meningitis (83.9 percent; infants aged 0-3 months).5 In one of these studies,5 age ≤ 30 days, very ill appearance, and abnormal WBC count (WBC ≥ 15,000/mm^3^ or WBC < 5,000/mm^3^) were the strongest predictors of bacteremia/meningitis (p = 0.001) in a logistic regression model. This model had the AUC of 80.0 percent, which was an increase from the AUC of 76.0 percent after the addition of abnormal WBC count (≥ 15,000/mm^3^ or < 5,000/mm^3^) as a dichotomized variable.5

In one study,66 the criteria that combined infant appearance (no findings consistent with soft tissue, skeletal, ear, or eye infection) and laboratory values (UA-WBC: < 10/hpf, WBC: 5,000-15,000/mm3, CRP < 20 mg/L, and ABC ≤ 1,500/mm3) showed a higher sensitivity for correctly identifying infants with bacteremia/meningitis (92.3 percent, 95 percent CI: 62.0, 99.6) than for total SBI (82.2 percent, 95 percent CI: 67.4, 91.5). In this study, there were 13 cases of bacteremia/meningitis one of which was misclassified as low risk for SBI. Another study,70 using similar criteria reported to have misclassified one infant who was later hospitalized with diagnosis of Neisseria meningitidis. This study included 86 infants younger than 2 months of age who were classified as low risk for SBI. The total number of infants with SBI or Neisseria meningitidis could not be ascertained.

Clinical criteria alone. The use and performance characteristics of clinical criteria for predicting the risk of SBI in febrile infants was reported in and/or ascertained from 15 studies (Table 4).5,30,32-42,71,110

Total serious bacterial infection. Criteria based on clinical history, namely ‘no history of recent immunization’(inactivated polio virus, hepatitis B, Haemophilus influenzae B, diphtheria-tetanus-acellular pertussis, pneumococcal conjugate, and rotavirus vaccines)41 or rapid influenza test-negative result42 demonstrated higher sensitivity (range: 94.0 percent–95.4 percent) but lower specificity (11.3 percent–33.2 percent)41,42 compared with criteria based on age (≤ 30 days; sensitivity: 35.0 percent, specificity: 76.4 percent),30 gender (sensitivity: 74.0 percent, specificity: 42.9 percent),30 and the degree of fever (≥ 39.5°C; range of sensitivity: 7.3 percent-26.1 percent, range of specificity: 90.5 percent–99.0 percent)30,35,36 The only exception for the criteria based on clinical history was not previously healthy which demonstrated lower sensitivity (21.7 percent) and higher specificity (88.5 percent).30

The association between grunting respiration and the presence of SBI was assessed in one observational study,110 in which 40 cases (infants with grunting) and 40 controls (infants with no grunting) admitted to a hospital were matched on age, day of hospitalization, and fever. The association between grunting and SBI was not significant with 3 infants with SBI in the case group versus two infants with SBI in the control group (7.5 percent vs. 5.0 percent; OR=1.54, 95 percent CI: 0.19, 14.1).

Specific types of serious bacterial infection. Criteria based on clinical appearance (ill, toxic, impression of sepsis) alone32-34,39,40 was available for identifying bacteremia which tended to yield higher sensitivity (range: 80.0 percent-100.0 percent) and lower specificity (40.0 percent–80.0 percent) than criteria based on the degree of fever > 40°C (range of sensitivity: 5.1 percent-12.5 percent, range of specificity: 96.1 percent– 98.3 percent).35,36 The use of rectal temperature ≥ 40°C criterion was reported to have missed one of six cases of infants with bacterial meningitis.36

Laboratory criteria alone. The use and performance characteristics of laboratory thresholds for predicting the risk of SBI or bacteremia in febrile infants was reported in and/or ascertained from the reports of 27 studies (Table 5).5,13,30,32-34,37,39,40,43-50,52-54,61,63,69,91,109,111,112

A wide variety of laboratory variables and thresholds were applied alone or combination across the reviewed studies. Some of the examples are UA (microscopy, dipstick),5,13,30,30,49,50,52-54 WBC,32,34,39,40,43-47,53,109,111,112ESR,33,39,53 ABC,32,44,109,112 and procalcitonin (PCT).48,61,104

Blood cell count (WBC; ABC; ANC) Across and within studies, the sensitivity for identifying total SBI tended to decrease (16.0 percent-100.0 percent) and the corresponding specificity increase (31.0 percent–95.2 percent) with higher thresholds of WBC (≥8,000/mm3 to ≥20,000/mm).43-46 Similar pattern of trade off between sensitivity and specificity was observed for absolute neutrophil count thresholds (>4,650/μL to >12,500/μL),45 and ABC thresholds (>250/mm3 to >3,000/mm3).44

Two studies calculating the AUCs,43,47 demonstrated numerically better overall accuracy of ANC compared to WBC in correctly classifying infants with and without total SBI. In the first study,47 the areas under ROC for ANC and WBC were 0.78 (95 percent CI: 0.69, 0.86) and 0.59 (95 percent CI 0.49, 0.69), respectively. In the second study,43 corresponding AUCs for ANC and WBC were 0.77 (95 percent CI: 0.67, 0.78) and 0.69 (95 percent CI: 0.61, 0.73), respectively. Similarly, in one study,44 the AUC for ABC was greater than that for WBC (81.0 percent versus 61.0 percent).

In three studies,30,46,48 the value of blood CRP levels (C-reactive protein) was shown to be greater than those of WBC, ANC, and PCT levels in predicting risk of SBI (AUC-CRP: 74.0 percent-84.0 percent vs. AUC-WBC: 68.0 percent-70.0 percent vs. AUC-ANC: 71.1 percent vs. AUC-PCT: 77.0 percent).

One study concluded that laboratory markers are more accurate and reliable predictors of SBI when performed after 12 hours of initiation of fever.47

Erythrocyte sedimentation rate (ESR). All three studies,33,39,53 that tested criterion of ESR > 30 mm/h demonstrated high values of specificity (range: 75.7 percent - 93.6 percent) for bacteremia or UTI. The sensitivity values for bacteremia (or meningitis) differed in two studies: 80.0 percent33 and 25.0 percent.39 In the third study, ESR > 30 mm/h predicted the risk of UTI with sensitivity of 73.0 percent (95 percent CI: 50.0, 88.4).53

C-reactive protein (CRP). In one study,46 the predictive ability of blood CRP levels (> 2 mg/dL, > 4 mg/dL, > 8 mg/dL) was shown to be better than WBC levels (> 15 K/μL, > 20 K/μL, > 15 or < 5 K/ μL) in terms of sensitivity, specificity, and the values of likelihood ratio. The areas under the ROC curve (AUC) for CRP and WBC in predicting SBI were 74.0 percent (95 percent CI: 67.0 percent, 80.0 percent) and 70.0 percent (95 percent CI: 64.0 percent, 76.0 percent), respectively. In one study,30 the use of CRP (at 70 g/L) resulted in higher sensitivity and specificity (69.6 percent and 93.8 percent, respectively) for predicting bacteremia compared to urine dipstick (43.5 percent and 82.8 percent, respectively) in 1,018 febrile infants (≥ 38.0°C) aged 3 months or younger. Likewise, the AUC for CRP (84.7 percent) was significantly greater than AUCs for WBC (67.9 percent) and absolute neutrophil count (ANC; 71.1 percent).30 In one study,47 CRP (> 20 mg/L) was used to predict SBI in 99 febrile neonates (7–28 days) at admission (duration of fever < 12 hours). Serious bacterial infection (UTI, bacteremia, meningitis, pneumonia, cellulitis, osteomyelitis, septic arthritis) was found in 25 (25.3 percent) of the neonates. The area under ROC for CRP was 0.77 (95 percent CI: 0.67, 0.85).

Procalcitonin (PCT). In a study by Maniaci (2008),61,104 the performance of procalcitonin (PCT) for identifying SBI (bacteremia, UTI, meningitis, pneumonia, bacterial GI) or possible SBI (UTI with urine culture of 10,000 to 49,000, or bacterial pneumonia as a chest radiograph interpreted by an attending radiologist) for febrile infants ≤ 3 months of age was examined. Overall, 30/234 (12.8 percent), and 12 /234 (5.12 percent) of infants were identified with definite SBI and possible SBI, respectively. At a cut off value of 0.13 ng/mL, procalcitonin had a sensitivity of 96.7 percent (95 percent CI: 81.0 percent–99.8 percent), specificity of 30.3 percent (95 percent CI: 24.0, 37.5), and NPV of 98.3 percent (95 percent CI: 89.7, 99.9). In discriminating definite plus possible SBIs and no SBI, a cutoff value of 0.12 ng/mL yielded a sensitivity of 95.2 percent (95 percent CI: 83.0, 99.0), specificity of 25.5 percent (95 percent CI: 20.0, 32.0), and NPV of 96.1 percent (95 percent CI: 85.4, 99.3).

A recent study,48 compared the ability of C-reactive protein, and procalcitonin (PCT) to predict SBI in 347 febrile infants younger than 3 months of age. Serious bacterial infection (bacteremia; meningitis; sepsis such as hemodynamic instability, tissue perfusion; UTI; pneumonia by chest x ray; gastroenteritis; cellulitis) was diagnosed in 82 (23.6 percent) of infants (65 UTI, 4 UTI + bacteremia, 5 bacteremia, 2 cellulitis, 4 sepsis, 1 acute bacterial gastroenteritis, and 1 pneumonia). In this study, the area under the ROC curve (AUC) for PCT was 0.77 (95 percent CI: 0.72, 0.81) and for CRP it was 0.79 (95 percent CI: 0.75, 0.84). In 15 infants with more invasive infection (sepsis, bacteremia, bacterial meningitis), the diagnostic value of PCT (AUC 0.84, 95 percent CI: 0.79, 0.88) was higher than CRP (AUC 0.68, 95 percent CI: 0.63, 0.73).

Cerebrospinal fluid (CSF). In two studies, the presence of CSF pleocytosis as a criterion was evaluated to predict total SBI, bacteremia and bacterial meningitis in neonates63 and infants aged 0–3 months.69 The definition of CSF pleocytosis for neonates differed in these studies. In the first study,63 the definition of pleocytosis was ≥ 20 WBC/mm^3^ and > 1 WBC per 500 red blood cells/mm^3^.63 In the second study,69 the WBC thresholds used in neonates was ≥ 25 cells/ μL, and in infants aged 29 days–3 months was ≥ 10 cells/μL The sensitivity values for detecting total SBI in the two studies were 31.1 percent63 and 12.5 percent.69 Since one of these studies69 reported sensitivity for the entire group of infants (0–3 months), these results were not comparable. In both studies the use of CSF pleocytosis resulted in a better sensitivity for detecting bacteremia (range: 28.0 percent- 34.5 percent) and bacterial meningitis (71.4 percent- 91.6 percent) compared to total SBI (12.5 percent- 31.1 percent). In these two studies,63,69 three of 19 cases of bacterial meningitis had no CSF pleocytosis.

Urine analysis (UA). The ranges of sensitivity and specificity values of UA (dipstick; the presence of LE or nitrite, or both) for identifying infants with UTI across the studies were 81.0 percent49- 85.0 percent13 and 63.6 percent50– 94.0 percent,52 respectively.5,13,49,50,52 In one study, the sensitivity of urine dipstick was lower in identifying UTI in neonates (73.2 percent) with NPV of 94.1 percent (95 percent CI: 91.7, 96.3).37 For three studies, the microscopy of spun urine (WBC ≥ 5/hpf) yielded sensitivity of 59.0 percent,53 65.0 percent,13 and 40.0 percent.54 The specificity values for the same studies were 92.4 percent13 93.0 percent,53 and 85.0 percent.54

In one study,5,51 two methods of urine collection (gold standard of >100 000 cfu/mL for a bag specimen; >20 000 cfu/mL for catheterization specimen), catheterization and bag were compared in terms of specificity and sensitivity of UA (the presence of LE or nitrite) in identifying infants with UTI. Regardless of the criteria used (LE or nitrites), the UA of urine collected by catheterization had a better sensitivity (86.0 percent or 43.0 percent) and specificity (94.0 percent or 99.0 percent) compared to sensitivity (76.0 percent or 25.0 percent) and specificity (84.0 percent or 99.0 percent) for urine collected with bag. In general, the presence of nitrites taken as a criterion had a lower sensitivity for both collection methods (catheterization: 43.0 percent and bag: 25.0 percent) than LE taken alone (catheterization: 94.0 percent and bag: 84.0 percent). Similarly, the area under the curve (AUC) of ROC based on sensitivity and specificity values for different thresholds of urine microscopy (WBC: 0-2, 3-5, 6-10, 11-20, > 20/hpf) was numerically greater for the collection method using catheterization (AUC: 86.0 percent, 95 percent CI: 82.0, 91.0) vs. bag (AUC: 71.0 percent, 95 percent CI: 61.0, 82.0).5,51In another study,30 the use of urine dipstick result (leukocyturia and/or nitrituria vs. normal) yielded a sensitivity of 43.5 percent and specificity of 82.8 percent in correctly identifying bacteremia in 1,018 febrile infants (≥ 38.0°C) aged 3 months or younger.

## KQ1b How do these findings vary by age within the age range 0 to 3 months?

The diagnostic test accuracy characteristics for criteria were compared qualitatively within and across studies where possible.

### Key Findings

Overall most combined clinical and laboratory criteria demonstrated higher sensitivity for SBI in older infants (28–90 days) compared to neonates with the exception of Rochester criteria which is designed for younger infants and therefore had better sensitivity for SBI in neonates compared with older infants (four studies). The false positive rate for SBI tended to be higher for neonates compared to older infants.

Similarly, one study using laboratory criterion alone (PCT) demonstrated better diagnostic accuracy for older infants compared with neonates in predicting SBI. The Philadelphia protocol demonstrated lower specificity for correctly identifying infants without SBI when applied to older infants (1–2 months) compared to neonates. Combined clinical and laboratory (ill appearance and WBC > 15,000 mm^3^) criteria and laboratory criteria alone (WBC > 15,000 mm^3^) demonstrated greater sensitivity in identifying infants with bacteremia among older infants (1–3 months) compared to neonates. Clinical appearance alone or combined with WBC ≥ 15,000/mm^3^ across two studies demonstrated better sensitivity in infants aged 2–3 months (75.0 percent and 100.0 percent) compared to neonates (28.5 percent and 85.7 percent).We found no evidence relating to other possibly relevant factors such as the clinical history of the mother.

### Detailed Presentation

The diagnostic test characteristics were compared for selected criteria across age groups (neonates vs. older infants) using the data from 15 studies (Table 6). 9-12,22,24,28,34,38,52,55-57,59,61

Table 6 Test characteristic variations within age range 0–3 months

Study ID | N/n^*^ Age range | N (%) with SBI | Sensitivity (%) [95% CI] | Specificity (%) [95% CI] | PPV (%) [95% CI] | NPV (%) [95% CI] | Other
Boston Criteria
Kadish (2000)22 | 394/372 1–28 d | SBI: 45 (12.1) | 82.0 [67.4, 91.5] | 68.0 [62.8, 73.1] | 26.0 [19.4, 34.4] | 97.0 [93.0, 98.4] | LR^+^=2.58 LR-= 0.26
Kadish (2000)22 | 394/372 1–28 d | Bacteremia: 12 | 75.0 [42.8, 93.3] | 63.3 [58.1, 68.3] | 6.4 [3.1, 12.1] | 98.7 [96.0, 99.6] | LR^+^=2.04 LR-= 0.39
Kaplan (2000)55 | 3,166/2,190 28–90 d | SBI: 191 (8.7) | 88.5 [82.8, 92.5] | 56.2 [54.0, 58.4] | 16.2 [14.0, 18.6] | 98.1 [97.0, 98.7] | LR^+^= 2.02 LR-= 0.20
Philadelphia Protocol
Baker (1999)11 | 254/254 3–28 d | SBI: 32 (12.5) | 84.4 [67.0, 95.0] | 46.8 [40.0, 53.0] | 18.6 [12.0, 25.0] | 95.4 [90.0, 99.0] | LR^+^=1.58 LR-= 0.33
Baker (1999)11 | 254/254 3–28 d | Bacteremia: 8 | 75.0 [35.6, 95.5] | 43.5 [37.2, 49.9] | 4.1 [1.7, 9.1] | 98.1 [92.7, 99.7] | LR^+^=1.32 LR-= 0.57
Baker (1999)11 | 254/254 3–28 d | Meningitis: 4 | 100.0 [39.6, 100.0] | 43.6 [37.4, 49.9] | 2.7 [0.9, 7.3] | 100.0 [95.7, 100.0] | LR^+^=1.77 LR-= 0
Baker (1993)12 | 747/747 29–56 d | SBI: 65 (8.7) | 98.0 [92.0, 100.0] 100.0^‡^ [93.0, 100.0] | 42.0 [38.0, 46.0] 42.0^‡^ [38.3, 45.9] | 14.0 [11.0, 17.0] 14.1^‡^ [11.1, 17.7] | 99.7 [98.0, 100.0] 100.0^‡^ [98.3, 100.0] | LR^+^=1.69 LR-= 0.03 LR^+^=1.72 LR-= 0
Baker (1993)12 | 747/747 29–56 d | Bacteremia: 19 | 100.0^‡^ [79.0, 100.0] | 39.4^‡^ [35.8, 43.0] | 4.1^‡^ [2.5, 6.5] | 100.0^‡^ [98.3, 100.0] | LR^+^=1.65 LR-= 0
Baker (1993)12 | 747/747 29–56 d | Meningitis: 9 | 100.0^‡^ [62.8, 100.0] | 38.9^‡^ [35.4, 42.5] | 2.0^‡^ [0.9, 3.8] | 100.0^‡^ [98.3, 100.0] | LR^+^=1.63 LR-= 0
Baker (1999)9 | 422/422 29–60 d | SBI: 43 (10.2) | 100.0 [89.7, 100.0] | 26.6 [22.3, 31.4] | 14.0 [10.0, 17.7] | 100.0 [96.0, 100.0] | LR+= 1.36 LR-= 0
Baker (1999)9 | 422/422 29–60 d | Bacteremia: 9 | 100.0 [62.9, 100.0] | 24.4 [20.4, 28.9] | 2.8 [1.4, 5.4] | 100.0 [95.4, 100.0] | LR+= 1.32 LR-= 0
Baker (1999)9 | 422/422 29–60 d | Meningitis: 5 | 100.0 [46.3, 100.0] | 24.2 [20.3, 28.7] | 1.5 [0.6, 3.8] | 100.0 [95.4, 100.0] | LR+= 1.31 LR-= 0
Condra (2010) 59 | 1,672/240 29–60 d | Data on low risk infants (n=62) UTI: 2 (NR) | NR | NR | NR | 96.7 [NR] | NR
Kadish (2000)22 | 394/372 1–28 d | SBI: 45 (12.1) | 87.0 [72.5, 94.4] | 55.0 [49.5, 60.5] | 21.0 [15.5, 27.6] | 97.0 [92.8, 98.7] | LR+=1.92 LR-= 0.24
Kadish (2000)22 | 394/372 1–28 d | Bacteremia: 12 | 83.3 [50.8, 97.0] | 51.1 [45.8, 56.3] | 5.3 [2.7, 9.9] | 98.9 [95.6, 99.8] | LR+=1.70 LR-= 0.32
Kadish (2000)22 | 394/372 1–28 d | Meningitis: 5 | 100.0 [46.3, 100.0] | 50.7 [45.5, 55.9] | 2.6 [0.9, 6.5] | 100.0 [97.4, 100.0] | LR+=2.03 LR-= 0
Rochester Criteria
Baskin (1992)56 | 503/501 28 - 89 d | SBI: 27 (5.4) | 52.0 [31.7, 71.6] | NR | NR | NR | NR
Baskin (1992)56 | 503/501 28 - 89 d | Bacteremia: 8 | 55.5 [22.6, 84.6] | NC | NC | NC | NC
Bonadio (1993)10 | 534/532 29–60 d | SBI: 22 (4.1) | 59.0 [36.6, 78.5] | 26.3 [22.5, 30.3] | 3.3 [1.9, 5.8] | 93.7 [88.0, 96.9] | LR+=0.80 LR-= 1.55
Bonadio (1993)10 | 534/532 29–60 d | Bacteremia: 6 | 33.3 [6.0, 75.9] | 26.3 [22.5, 30.3] | 0.5 [0.09, 2.1] | 97.1 [92.3, 99.0] | LR+=0.45 LR-= 2.53
Bonadio (1993)10 | 534/532 29–60 d | Meningitis: 4 | 50.0 [9.1, 90.8] | 26.7 [23.0, 30.7] | 0.5 [0.08, 2.1] | 98.6 [94.5, 99.7] | LR+=0.68 LR-= 1.87
Chiu (1997)57 | 250/250 4–28 d | SBI: 41 (16.4) | 97.6 [92.9, 100.0] | 62.2 [55.6, 68.8] | 33.6 [25.1, 42.1] | 99.2 [97.7, 100.0] | LR+= 2.58 LR-= 0.04
Chiu (1997)57 | 250/250 4–28 d | Bacteremia/Meningitis: 7 Bacteremia/Enteritis: 3 Bacteremia/Osteomyelitis: 1 | 100.0 [67.8, 100.0] | 54.8 [48.2, 61.2] | 9.2 [4.9, 21.2] | 100.0 [96.4, 100.0] | LR+= 2.21 LR-= 0
Ferrera (1997)24 | 188/134 0–28 d | SBI: 22 (16.4) | 86.4 [64.0, 96.4] | 46.4 [36.3, 56.7] | 26.8 [17.2, 38.8] | 93.8 [81.8, 98.4] | LR+=1.61 LR-= 0.29
Ferrera (1997)24 | 188/134 0–28 d | Bacteremia: 4 | 100.0 [39.5, 100.0] | 41.7 [32.7, 51.3] | 5.6 [1.8, 14.3] | 100.0 [90.2, 100.0] | LR+=1.71 LR-= 0
Herr (2001)28 | 434/344 < 59 d | SBI: 41 (12.0) | 68.3 [51.7, 81.4] | 37.6 [32.2, 43.3] | 12.9 [8.8, 18.2] | 89.7 [82.8, 94.2] | LR^+^=1.09 LR^-^=0.84
Herr (2001)28 | 434/42 0–14 d | SBI: 3 (7.1) | 100.0 [31.0, 100.0] | 28.2 [15.5, 45.1] | 9.6 [2.5, 26.9] | 100.0 [67.8, 100.0] | LR^+^=1.39 LR^-^=0
Herr (2001)28 | 434/104 15–28 d | SBI: 9 (8.6) | 100.0 [62.8, 100.0] | 26.3 [18.0, 36.5] | 11.3 [5.6, 21.0] | 100.0 [83.0, 100.0] | LR^+^=1.35 LR^-^=0
Herr (2001)28 | 434/138 29–45 d | SBI: 19 (13.7) | 100.0 [79.0, 100.0] | 39.5 [30.7, 48.9] | 20.8 [13.3, 30.9] | 100.0 [90.5, 100.0] | LR^+^=1.65 LR^-^=0
Herr (2001)28 | 434/113 46–59 d | SBI: 10 (8.7) | 100.0 [65.5, 100.0] | 35.9 [26.8, 46.0] | 13.1 [6.8, 23.3] | 100.0 [88.2, 100.0] | LR^+^=1.56 LR^-^=0
Clinical Criteria Alone: Ill Appearance
Bonadio (1994)38 | 367/356 60–90 d | SBI: 33 (9.3) | 33.3 [18.5, 51.9] | NR | NR | NR | NR
Bonadio (1994)38 | 367/356 60–90 d | Bacteremia: 8 (2.2) | 37.5 [10.2, 74.1] | NR | NR | NR | NR
Caspe (1983)34 | 305/305 0–90 d | Bacteremia: 11 (3.6) | 91.0 [57.1, 99.5] | 56.6 [49.3, 63.5] | 10.4 [5.4, 18.7] | 99.1 [94.4, 99.9] | LR^+^=2.10 LR^-^=0.16
Caspe (1983)34 | 305/107 0–30 d | Bacteremia: 7 (6.5) | 85.7 [42.0, 99.2] | 73.2 [63.4, 81.3] | 18.2 [76.1, 36.0] | 98.6 [91.8, 99.9] | LR^+^=3.20 LR^-^=0.19
Caspe (1983)34 | 305/198 30–60 d | Bacteremia:: 4 (2.0) | 100.0 [39.6,100.0] | 69.6 [62.5, 75.9] | 6.3 [2.0, 16.2] | 100.0 [96.5, 100.0] | LR^+^=3.28 LR^-^=0
Caspe (1983)34 | 305/305 0–90 d | UTI: 7 (2.3) | 42.8 [11.8, 79.8] | NR | NR | NR | NR
Laboratory Criteria Alone: WBC > 15,000/mm^3^
Caspe (1983)34 | 305/107 0–30 d | Bacteremia: 7 (6.5) | 28.6 [5.1, 69.7] | NR | NR | NR | NR
Caspe (1983)34 | 305/107 30 - 60 d | Bacteremia: 4 (2.0) | 75 [21.9, 98.7] | NR | NR | NR | NR

d = day(s); LR = likelihood ratio; mm^3^ = millimeter; NPV = negative predictive value; NR = not reported; UTI = urinary tract infection; PPV = positive predictive value; WBC = white blood cell count

* N/n: number of infants enrolled/ number of infants with test and culture results

‡ Values based on Philadelphia protocol + no immunodeficiency syndrome, band-to-neutrophil ratio < 0.2

Combined clinical and laboratory criteria. For the Boston criteria,22 the estimates of sensitivity, specificity, PPV, and NPV for total SBI in neonates were 82.0 percent (95 percent CI: 67.4, 91.5), 68.0 percent (95 percent CI: 62.8, 73.1), 26.0 percent (95 percent CI: 19.4, 34.4), and 97.0 percent (95 percent CI: 93.0, 98.4), respectively. In infants aged 28 - 90 days, these parameters had the following values: 88.5 percent (95 percent CI: 82.8, 92.5), 56.2 percent (95 percent CI: 54.0, 58.4), 16.2 percent (95 percent CI: 14.0, 18.6), and 98.1 percent (95 percent CI: 97.0, 98.7), respectively.55

With respect to total SBI, the Philadelphia protocol in neonates,11,22 sensitivity values were 84.4 percent11 and 87.9 percent22 and specificity values were 46.8 percent11 and 55.0 percent 22). In infants aged 29–60 days,9,12 higher sensitivity (98.0 percent and 100.0 percent) and lower specificity values (26.6 percent and42.0 percent) were reported. For detecting bacteremia, the Philadelphia protocol demonstrated higher sensitivity (i.e., 100.0 percent) in older infants (age: 29-60 days)9,12 compared to sensitivity of 75.0 percent and 83.3 percent in neonates (age: 0-28 days).11,22

The two studies that tested Rochester criteria for total SBI in infants 28 days or younger,24,57 showed the following estimates of sensitivity (97.6 percent and 86.4 percent), specificity (62.2 percent and 46.4 percent), PPV (33.6 percent and 26.8 percent), and NPV (99.2 percent and 93.8 percent). In two other studies the application of Rochester criteria in infants aged 28 days–90 days56 and 28 days–60 days10 yielded sensitivities of 52.0 percent (95 percent CI: 31.7, 71.6) and 59.0 percent (95 percent CI: 36.6, 78.5), respectively. The corresponding specificity value was reported only for one study (26.3, 95 percent CI: 22.5, 30.3).10 In identifying bacteremia, the Rochester criteria in neonates demonstrated sensitivity of 86.4 percent24 as opposed to 55.5 percent in older infants (age: 28 days-90 days).56

The results for combined criteria (clinical and laboratory) for predicting total SBI in neonates and older infants were reported in two studies.28,34 The authors in the first study28 examined the effect of age on the accuracy indices of the criteria in correctly identifying total SBI. Overall, there was no discernable numerical trend in the values of sensitivity and specificity across the age groups (0–14, 15–28, 29–45, and 46 - 59 days). In the second study,34 the classification of infants aged 0–1 month and 1–2 months with respect to risk of bacteremia, using a similar criteria of ill appearance and WBC ≥ 15,000/mm^3^, resulted in sensitivity values of 28.5 percent (95 percent CI: 5.1, 69.7) and 75.0 percent (95 percent CI: 21.9, 98.6), respectively.

Clinical criteria alone. One study reported the result for identifying risk of bacteremia using ill appearance as a criterion in neonates with sensitivity of 85.7 percent (95 percent CI: 42.0, 99.2) and specificity of 73.2 percent (95 percent CI: 63.4, 81.3).34 The value for sensitivity in another study in infants 2–3 months using the same criteria for predicting bacteremia was 37.5 percent (95 percent CI: 10.2, 74.1).38 No specificity was reported for the latter study.

Laboratory criteria alone. In one study,34 the application of WBC ≥ 15,000/mm^3^ for identifying bacteremia in neonates was associated with a sensitivity value of 28.6 percent. In the same study, the sensitivity was 75.0 percent when the criterion WBC ≥ 15,000/mm^3^ was used in older infants aged 1-2 months.

One study reported sensitivity of 82.0 percent (95 percent CI: 71.0, 90.0) and specificity of 92.0 percent (95 CI: 90.0, 94.0) for urinalysis (dipstick, microscopy) in detecting UTI in neonates.52 In the same study this test criteria was applied to older infants (29–89 days) and yielded similar estimates of sensitivity (82.0 percent, 95 percent CI: 75.0, 87.0) and specificity (94.0 percent, 95 percent CI: 93.0, 95.0).

In one study,61 nine of 30 infants with SBI were younger than 28 days of age. The overall performance of Procalcitonin (PCT) levels in this study to identify SBI (definite and possible SBI) in ROC curve analysis had an AUC of 0.85 for patients >28 days of age compared with an AUC of 0.73 for patients ≤ 28 days of age.

## KQ1c In infants < 3 months old who present with a fever, what are the sensitivity, specificity and predictive values of individual or combinations of clinical features (history including information on the mother's history and previous testing, risk factors, findings on clinical exam, laboratory tests, and formal scoring instruments based on clinical features) for identifying those with invasive herpes simplex virus infection (HSV)? How do these findings vary by age within the age range 0 to 3 months?

The reported data on the presence of Herpes Simplex Virus (HSV) in febrile infants 3 months or younger was very scarce. For example, there were only four studies 39,60,62,63 in which the prevalence of Herpes Simplex Virus (HSV) was reported. In total, there were seven infants diagnosed with HSV in these studies and none of them had a concurrent bacterial infection. The prevalence of HSV amongst the febrile infants admitted across these studies (period range: 2 years62-6 years60) were 2.0 percent,60 1.7 percent,62 and 0.3 percent.39,63 The diagnostic accuracy of any given criteria in predicting the risk of HSV could be calculated only for one study.63 In this study, CSF pleocytosis (defined as ≥ 20 WBCs/mm^3^ and > 1 WBC per 500 red blood cells s/mm^3^ ) predicted the risk of HSV in neonates with sensitivity of 66.6 percent (95 percent CI: 12.5, 98.2) and specificity of 74.6 percent (95 percent CI: 71.4, 77.6). The Positive and negative predictive values in this study were 1.0 percent (95 percent CI: 0.2, 3.9) and 99.8 percent (95 percent CI: 98.9, 99.9), respectively. There were insufficient data to compare the findings in neonates and infants in older age groups.

## KQ 2a What is the evidence that clinical features alone, basic laboratory tests alone or the combination are sufficient to identify febrile infants < 3 months who are at low risk of having a serious bacterial illness (i.e., have a high negative predictive value)?

The evidence indicated that the reviewed criteria/protocols were able to correctly classify most or all of the infants truly without SBI into low-risk groups (Tables 2–5).

Generally, all combined clinical and laboratory criteria (Boston,22,55 Rochester,10,23-26,57,60 Milwaukee,10 Philadelphia,9,11,12,22,25,58,59 YIOS,21 Yale,64,65 and other combined criteria28-30,37,49,66-68) as well as clinical criteria alone (not well appearing infants, age < 1 month, gender, fever > 40 ° C)30 demonstrated high NPVs (> 90.0 percent) in correctly identifying infants without SBI, UTI, bacteremia, and bacterial meningitis. In other words, the proportion of infants misclassified to the low risk category (missed SBI cases) in these studies was 10.0 percent or less.

The evidence regarding NPV for identifying infants without SBI using laboratory criteria alone was available for eight studies.30,43,44,47,48,61,63,69 Of these, several criteria (WBC < 5000 - >15,000/mm^3^47, PCT ≥ 0.5 ng/mL,48 CRP ≥ 30 mg/L,48 and presence of CSF-pleocytosis,63,69) showed relatively lower NPVs (78.1 percent- 91.0 percent).

## KQ 2b What is the evidence for the potential risks resulting from a delay in the diagnosis and treatment of patients who appear low risk but have a serious bacterial illness?

### Key Findings

Nine studies reported that all low risk infants later found to have SBI were subsequently hospitalized and treated with full term antibiotics without adverse events or complications.

### Detailed Presentation

We identified nine studies reporting outcomes related to delayed treatment of febrile infants initially classified as low risk and later diagnosed with SBI. 5,10,23,47,55,57,58,67,70 Studies reporting immediate antibiotic treatment for management of low risk infants29,72 as well as studies in which none of the low risk infants was diagnosed with SBI were excluded.9,12,26,84

Nine studies reported on management of 4,497 infants 0–3 months of age managed according to low risk criteria (Table 7).5,23,47,55,57,58,67 In these studies, 32 infants from those initially classified at low risk (0.70 percent) had SBI. All infants with SBI were eventually treated with antibiotics after the diagnoses were made. Outcomes on recovery or complications of six neonates initially classified as low risk and later diagnosed with SBI were not reported in two studies.47,57 The infants in the remaining five studies were aged 0–3 months.

Table 7 Management and outcomes of delayed diagnosis and treatment of SBI infants initially classified as low risk of having SBI

Author (year) | Criteria Age of Infants | Early management detail | n/N (delayed SBI diagnosis/total infant at low risk) | Complications
Bonadio, WA (1993)10 | Combined clinical and laboratory (Milwaukee protocol) 28–56 d | Discharged after injection of ceftriaxon (50mg/kg) | 1/143 (0.7%) Bacteremia | None occurred
Bressan, S (2010)47 | Well appearing + repeated lab test > 12 hrs of fever neonates | All infants were hospitalized upon admission. | 5/62 (8.1%) 3 bacteremia; 2 meningitis | No data
Brik, R (1997)58 | Combined clinical and laboratory (Philadelphia protocol) 0 - 30 d | Low risk infants were treated as outpatient treatment without antibiotics | 9/296 (3.04%) 1 bacteremia; 7 UTI | No data
Chiu C (1997)57 | Combined clinical and laboratory (Rochester criteria) neonates | All low risk infants were hospitalized and closely monitored without antibiotics; 44.3% of infants were reclassified as high risk on 2^nd^ or 3^rd^ day and were given antibiotics | 1/131 (0.8%) UTI | 7 day course antibiotics Recovered with no complications
Jaskiewicz, J (1994)23 Combined clinical and laboratory | Combined clinical and laboratory criteria (Rochester criteria) 0 - 60 d | 203 (39.7%) of infants were treated without antibiotics (this included 4/5 infants with SBI) Remaining infants were treated with IM ceftriaxone and discharged home | 5/437 (1.1%) 2 bacteremia; 3 UTI | None occurred
Kaplan, R (2000)55 | Combined clinical and laboratory criteria (Boston criteria) 28 - 90 d | NR | 3/1146 (0.3%) | None occurred
McCarthy, CA (1990)70 | Combined clinical and laboratory 11–59 d | Discharged after injection of ceftriaxon (50mg/kg) | 1/86 (1.2%) | No data
Pantell, R (2005)5 The PROS study (office setting) | Laboratory (75%) and clinical criteria (PROS practitioner guidelines) 0 - 90 d | 1264 (64%) were treated as outpatients; initially treated 57% of infants with antibiotics unclear how many of these infants had SBI; | 2/1975 (0.1 %) | None occurred
Wasserman, G (1990)67 | Combined clinical and laboratory criteria 0 - 30 d | All infants were hospitalized, 222 (high risk) were treated with antibiotics and 221 (low risk) received no antibiotics | 5/221 (2.3%) 3 infants < 2 weeks of age with Bacteremia or bacterial meningitis 2 infants > 2 weeks of age | None occurred

d = day(s); hr(s) = hours; NR = not reported; PROS = Pediatric Research in Office Settings; UTI = urinary tract infection

In two studies, majority of infants were monitored as outpatients in accordance with Philadelphia protocol,58 and a combined clinical and laboratory criteria (not ill appearing, no bacterial illness, undefined benign laboratory screening findings).67 In these studies, 14 out of 517 infants (2.7 percent) initially classified as low risk and later diagnosed with SBI were subsequently treated with full dose antibiotics, and recovered without any complications. In one study,23 various management strategies (initial treatment with or without antimicrobial agents; hospitalization with or without parenteral antimicrobial agents) were used. In this study, a total of five infants initially classified as low risk using Rochester criteria were diagnosed with SBI, four of whom were not initially treated with antibiotics. All four infants recovered without complications.

In the PROS study,5 using practitioner guidelines two of the total of 63 infants with SBI were initially treated as low risk and later received delayed diagnosis/treatment. None of these infants had complications.

In the remaining one study,55 three infants (age 28 days–3 months) out of 1,146 initially classified as low risk using Boston criteria were subsequently diagnosed with SBI, treated with antibiotics and recovered without complications.

In the study by Bonadio, 10 26.8 percent (143/534) of the included infants were considered low risk.10 The low risk infants according to Milwaukee protocol were managed by injection of ceftriaxon (50mg/kg) before being discharged. Eight of them were hospitalized within 72 hours due to bacteremia (n=1), gastroenteritis (n=4), and paediatrician's preference (n=3). Only 0.7 percent (1/143) of the infants were diagnosed as having SBI (Moraxella catarrhalis bacteremia with a negative repeat blood culture) and were treated with parenteral antibiotics for 72 hours. No complications occurred in these infants.

In the study by McCarthy, 70 86 low risk (well appearing with WBC: 5,000-15,000/mm3, ABC ≤ 1,500/mm3, UA ≤ 10 WBC/hpf, and stool ≤ 5 WBC/hpf) for SBI infants younger than 2 months were enrolled and treated as outpatients with cefriaxone (50 mg/kg). All infants returned at day 2 (24 hours for follow up). There were no serious complications. Twelve (14.0%) infants developed transient problems possibly related to intramuscular cefriaxone therapy. Six infants were hospitalized, one for SBI (Neisseria meningitidis bacteremia) and five others for medical and social reasons. The infant with SBI was a 4 week-old female who received ceftriaxone for 7 days. No further data were reported.

## KQ3a What is the evidence that clinical features alone, basic laboratory tests alone or the combination are sufficient to identify febrile infants < 3 months who are at high risk of having a serious bacterial illness (i.e., have a high positive predictive value)?

### Key Findings

Generally, the reviewed criteria tended to show poor predictive values in identifying the presence of SBI (or other sub-types of SBI) amongst high risk infants. This was demonstrated by low positive predictive values (PPVs) across the studies. The PPVs for total SBI varied markedly and ranged from 3.3 percent to 71.4 percent.

### Detailed Presentation

For majority of the criteria (combined clinical and laboratory, clinical only, and laboratory only), the probability for a ‘High Risk’ infant (< 3 months old) of having total SBI (i.e., PPV) was low. The low PPVs are indicative of high false positive rates or low specificity for SBI (i.e., high percentage of febrile infants without SBI classified as high risk).

SBI. The PPVs for total SBI across the combined clinical and laboratory criteria ranged from 3.3 percent10 to 71.4 percent.47 Only the minority of the criteria demonstrated PPVs greater than 50.0 percent.47,48,68,71 These criteria were combined (lack of mild upper respiratory tract infection symptoms in infants or siblings and CRP ≥ 1.87 mg/dL, 68 clinical alone (ill appearance)71 laboratory alone criteria (ANC, CRP, PCT-Q).47,48

The remaining combined clinical and laboratory criteria such as Boston, Milwaukee, Philadelphia, Rochester, YIOS, Yale observational scale (Table 2), and other combined criteria (Table 3) showed PPVs below 50.0 percent (range 3.3 percent10–48.6 percent29)9-12,21-26,28,29,37,49,55,58,60,64,66-68 The PPVs for laboratory criteria alone were similar to those of the combined criteria, ranging from 6.3 percent (CRP at 20 g/L)30 to 43.8 percent (WBC 5,000–15,000/mm^3^47).30,43,44,47,48,63 The corresponding PPVs for clinical alone criteria were lower than those for combined or laboratory only criteria, ranging from 3.3 percent (age ≤ 1 month versus > 1 month) 30 to 17.5 percent (rapid influenza test results).30

Bacteremia/Bacterial meningitis. In general, the PPVs for predicting bacteremia were low, ranging from 0.5 percent (Rochester Criteria in age range 29-60)10 to 40.0 percent (ESR ≥ 30 mm/h).33

Bacterial Meningitis. The PPV for predicting meningitis across the combined clinical and laboratory criteria ranged from 0.5 percent10 to 5.4 percent.63

## KQ 3b What are the benefits and harms of immediate antibacterial, antiviral therapy, and/or hospitalization (vs. delaying until diagnostic workup is complete) in patients at high risk of serious bacterial illness?

### Key Findings

The amount of data on harms of immediate antibiotics was limited. In one study, three deaths occurred in neonates with enteroviral infection (two infants) and viral infection (one infant). In two studies, minor intravenous access problems or drug related rash occurred following administration of antibiotics. We found no data on other possibly relevant outcomes such as loss of work time, or effects on quality of life of caregivers.

### Detailed Presentation

There was no evidence directly comparing outcomes in the immediate versus delayed treatment groups. We identified 10 studies reporting on immediate antibiotic (or antiviral) therapy administered to infants at high risk of SBI (or HSV) (Table 8). No treatment outcomes were reported for three studies.10,47,56 The remaining studies reported that febrile infants classified as being at high risk for SBI were administered immediate antibiotic therapy (versus delaying until diagnostic workup is complete). In one study, 0.4 percent of the included infants developed drug-related rash and 18.9 percent had infiltration of an intravenous line.12 In another study,32 immediate intravenous antibiotic therapy administered to 13 toxic appearing infants 2 months or younger was reported to be without any complications. Another study reported minor intravenous access problems that had occurred in 15.6 percent of the 51 high risk infants (most of them diagnosed with UTI) treated with intravenous antibiotics for 4 days. About 67.0 percent of these infants were transferred to an outpatient day treatment centre to complete their antibiotic treatment course.72

Table 8 Effects of immediate antibacterial/antiviral therapy in infants at high risk for SBI

Author (year) | Criteria Age of Infants | Management strategy | N/n at high risk n with SBI or HSV | Effect of antibiotic therapy (AEs)
Baker (1993)12 | Yale Observation Scale 29–56 days | High risk infants were treated with antibiotics for 72 hours | HR: 460/747 SBI: 65/460 (14.1%) | Infiltration of intravenous line 87 (18.9%) Suspected drug-related rash 2 (0.4%)
Baker (1999)9 | Philadelphia protocol 29–60 days | High risk infants were treated with unspecified antibiotics as inpatients | HR: 321/422 (21/422 pts also at high risk were treated without antibiotics, 3 had SBI) SBI: 43/321 (13.4%) | No complications occurred
Baskin (1991)56 | Rochester Criteria 28–90 d | All infants were treated with intramuscular ceftriaxone (50 mg/kg) and discharged. infants were followed for 2 to 7 days | HR: NR (13/25 with SBI were at high risk) SBI: 25/NR | NR
Bonadio (1993)10 | Milwaukee Protocol 29–60 d | High risk infants were treated with ampicillin 50 mg/kg/day or cefotaxime 50 mg/kg/day | HR: 391/534 SBI: 22/391 (5.6%) | NR
Bressan (2010)47 | Clinical criteria (ill appearance and laboratory tests) 7–28 days | High risk infants were treated with antibiotics (69/156) - but not included in the analysis immediately after admission | HR: 69/156 SBI: 38/69 (55.0%) | NR
Broner (1990)32 | Clinical (toxic appearance) 4–56 days | High risk infants were treated with intravenous antibiotics | HR: 13 (toxic appearance)/52 SBI: NR (5 total SBI) | No complications occurred
Dore-Bergeron (2009)72 | Combined clinical and laboratory criteria 30–90 days | High risk infants were treated with intravenous antibiotics | 51/NR | Minor intravenous access problems 7 (15.6%)
Dore-Bergeron (2008)72 | Clinical and laboratory criteria 0–90 days | High risk infants were hospitalized and treated with intravenous antibiotics | HR: 51/118 SBI: 45/51 (88.2%) (UTI) | Minor intravenous access problems occurred in 7/51 (13.7%)
Jordan (2009)83 | NR 3–28 days | Parenteral antibiotics for all febrile infants upon admission (no information on antiviral treatment was provided) | NR (this was not a diagnostic accuracy study and the number of infants with high or low risk was not determined) SBI: 62/328 (18.9%) Enterovirus infection (EI): 10/328 (0.3%); 50% of EI infants were < 10 days of age | Death 3/328 (< 0.1%) One with fulminant S. agalactiae sepsis (SBI) 2 with enteroviral infection: one developed severe meningitis (PCR testing of CSF for enterovirus) and cardiomyopathy; the other infant with EI was confirmed for positive enterovirus on liver biopsy with molecular diagnostic method
Kneen (2010)108 | NA 0–28 days (infants under treatment with antiviral agent acyclovir) | Antiviral treatment with intravenous acyclovir; 26 (51%) were admitted to the intensive care unit | NA HSV: 2/51 (3.9%) | No death occurred. No renal dysfunction occurred in 47/51 infants tested for renal function

AE= adverse effects; HR= high risk; HSV= herpes simplex virus infection; NA= not applicable; NR= not reported; SBI=serious bacterial infection; UTI= urinary tract infection

In one study,83 the immediate antibiotic treatment was administered to six infants aged 28 days or younger, of whom three infants had enterovirus and three infants had sepsis/meningitis. Two of the six infants with enterovirus died. None of the two infants who died had SBI. In one study,47 51 infants with suspected viral encephalitis (based on clinical findings) were treated with intravenous acyclovir (antiviral drug primary used for treatment of HSV). At admission, none of the tested 47 infants had renal dysfunction. Fifty infants were prescribed antibiotics (cefotaxime). No death and no clinical relapses occurred.

## KQ 4 What is the evidence that the presence of an identified viral infection predicts against a serious bacterial infection?

This review identified and included 11 studies in which the association between the status of viral infection and the risk of SBI in febrile infants was explored (Table 9).5,27,41,60,65,73-75,77,78,86

Table 9 Concurrent viral and bacterial infection

Study ID | Viral Infection [SBI] | Viral infection ^+^ | | | Viral infection ^-^ | | | Prevalence ratio (%) [95% CI] | OR^*^ [95% CI]
Study ID | Viral Infection [SBI] | SBI^+^ n | Total N | Prevalence (%) [95% CI] | SBI^+^ n | Total N | Prevalence (%) [95% CI] | Prevalence ratio (%) [95% CI] | OR^*^ [95% CI]
Neonates 0–28 days
Smitherman (2005)86 | Influenza A | NR | 13 | NA | NR | 49 | NA | NA | NR
Infants 0–60 days
Kuppermann (1997)78 | RSV [Bacteremia] | 0 | 36 | 0 | 1 | 50 | 2.00 [1.88, 5.88] | - | -
Kuppermann (1997)78 | RSV [UTI] | 0 | 33 | 0 | 6 | 50 | 12.0 [3.00, 21.00] | - | -
Krief (2009)80 | RSV, influenza [SBI] | 3 | 119 | 2.5 [0.5, 7.2] | 92 | 690 | 13.3 [10.9, 16.1] | 0.19 [0.06, 0.59] | 0.16 [0.04, 0.56]
Krief (2009)80 | RSV, influenza [UTI] | 3 | 123 | 2.4 [0.5, 6.9] | 77 | 712 | 10.8 [8.6, 13.3] | 0.23 [0.07, 0.70] | 0.20 [0.05, 0.69]
Krief (2009)80 | RSV, influenza [Bacteremia] | 0 | 123 | 0 | 16 | 715 | 2.2 [1.3, 3.6] | - | p=0.15
Krief (2009)80 | RSV, influenza [Meningitis] | 0 | 119 | 0 | 6 | 698 | 0.9 [0.3, 1.9] | - | p=0.6
Levine (2004)65 | RSV [SBI] | 17 | 244 | 7.00 [4.10, 10.90] | 116 | 925 | 12.50 [10.50, 14.80] | 0.60 [0.30, 0.90] | 0.58 [0.33, 0.99] ζ δ
Levine (2004)65 | RSV [UTI] | 14 | 261 | 5.4 [3.0, 8.8] | 98 | 966 | 10.1 [8.3, 12.2] | 0.50 [0.30, 0.90] | -
Levine (2004)65 | RSV [Bacteremia] | 3 | 267 | 1.1 [0.2, 3.2] | 22 | 968 | 2.3 [1.4, 3.4] | 0.5 [0.1, 1.6] | -
Levine (2004)65 | RSV [Meningitis] | 0 | 251 | 0 | 8 | 938 | 0.9 [0.4, 1.7] | - | -
Titus (2003)77 | RSV [SBI] | 2 | 174 | 1.15 [0.43, 2.73] | 22 | 174 | 12.60 [7.70, 17.60] | 0.09 [0.02, 0.38] | 0.08 [0.01, 0.36]
Infants 29–90 days
Smitherman (2005)86 | Influenza A [SBI] | NR | 45 | NA | NR | 185 | NA | NA | 0.21 [0.05, 0.93] ψ 0.19 [0.03, 1.44] ζ
Infants 0–90 days
Bilavsky (2008)75 | RSV [SBI] | 3 | 136 | 2.20 [0.60, 6.00] | 30 | 312 | 9.62 [6.35, 12.89] | 0.23 [0.05, 0.76] θ | 0.21 [0.05, 0.74]
Byington (1999)74 | Nonpolio EV [SBI] | 6 | 89 | 6.70 [2.8, 13.3] | 38 | 256 | 14.84 [10.5, 19.20] | 0.45 [0.17, 0.96] | 0.41 [0.15, 0.95]
Byington (2004)60 | EV, RSV, Influenza A/B, parainfluenza, rotavirus [SBI] | 21 | 491 | 4.30 [2.80, 6.20] | 110 | 894 | 12.30 [10.15, 14.45] | 0.34 [0.21, 0.55] | 0.32 [0.19, 0.52]
Dagan (1985)27 | Nonpolio EV RSV, influenza [SBI] | 4 | 137 | 2.92 [0.10, 5.34] | 19 | 96 | 19.79 [11.82, 27.76] | 0.14 [0.04, 0.44] | 0.12 [0.03, 0.40]
Luginbuhl (2008)5,76 | RSV [SBI] | 0 | 125 | 0 | 212 | 1933 | 10.96 [9.62, 12.46] | - | -
Mintegi (2009)41 | Influenza A/B [SBI] | 3 | 113 | 2.65 [0.0, 5.6] | 47 | 268 | 17.5 [13.0, 22.0] | 0.15 [0.04, 0.48] | 0.13 [0.03, 0.44]
Rittichier (2005)73 | EV [SBI] | 15 | 214 | 7.00 [3.59, 10.43] | NR | 847 | NA | NA | NA
Smitherman (2005)86 | Influenza A [SBI] | NR | 58 | NA | NR | 234 | NA | NA | 0.28 [0.16, 0.48] ψ 0.14 [0.04, 0.46] ζ

EV = enterovirus; NA = not applicable; NR = not reported; RSV = respiratory syncytial virus; SBI = serious bacterial infection; UTI = urinary tract infection; WBC = white blood cell; YOS = Yale Observation Score;

* The odds of SBI in viral infection-positive infants divided by the odds of SBI in viral infection-negative infants

ψ including pneumonia

ζ excluding pneumonia

δ adjusted for age, temperature, YOS, and WBC count

θ relative risk (i.e., rate ratio)

### Key Findings

There was a reduced risk of SBI amongst infants who tested positive for the presence of viral infection or clinical bronchiolitis compared to infants who tested negative for the presence of viral infection or bronchiolitis. This finding may not be applicable to neonates.

### Detailed Presentation

There was no evidence to assess the probability of having SBI with respect to the presence of HSV infection in febrile infants. We identified four studies reporting prevalence of HSV in febrile infants, however, none of these studies reported concurrent SBI.39,60,62,63

The most frequent types of SBI across the reviewed studies were UTI (range: 5.6 percent73 - 11.3 percent41) and bacteremia (range: 1.4 percent73–3.8 percent27). The types of virus studied were: influenza A/B,41,60,80,86 RSV,5,27,60,65,75,77,78,80 nonpolio EV,27,74 and EV.60,73 In these studies, the prevalence (or odds) of SBI were compared between the two groups of virus-positive and virus-negative infants. For two studies,73,86 the number of infants with SBI was not reported for one or two groups, and therefore the prevalence ratios (or risk ratios) could not be calculated. The authors of one study, however, provided the estimates of odds ratio by age groups (Table 9).86

Overall, based on the study results, there was an inverse statistically significant association between the status of viral infection and the prevalence (or risk) of SBI. Specifically, there were higher prevalence (or risk) of SBI in infants without viral infection or clinically diagnosed bronchiolitis compared to infants with viral infection or clinically diagnosed bronchiolitis. The observed differences were statistically significant,27,41,60,65,74,75,77,79,86 regardless of relatively smaller samples and event counts for some of these studies. The prevalence of SBI in virus-positive infants across the studies ranged from 0 percent78 to 7.0 percent.65,73,79 The prevalence of SBI in virus-negative infants ranged from 9.6 percent75 to 19.8 percent.27 The estimate of odds ratio ranged from 0.08^77^ to 0.41^74^(Table 9).

In the study by Byington and colleagues, the prevalence of SBI in low and high risk groups (classified using Rochester criteria) was compared in febrile infants with and without viral infections.60 All infants in this study were tested for at least one virus. Of the 1,385 infants, 491 (35 percent) were found to have one or more viral infections (EV, RSV, Influenza A or B, Parainfluenza 1, 2, or 3, Rotovirus, Adernovirus, HSV, and Varicella). The rate of concurrent SBI in infants with viral infection was 21/491 (4.2 percent) compared with 110/894 (12.3 percent) in infants without a viral infection. The lowest prevalence of SBI was in the low risk group with a documented viral infection (1.8 percent). In the high risk group, the prevalence of SBI was 5.5 percent when a viral infection was present compared to 16.7 percent when there was negative viral testing.

For infants with RSV,27,60,65,77,79 the odds ratios for having an SBI ranged from 0.08^77^ to 0.58.^65^ The odds ratios for those with influenza A/B,41,60,86 were similar: 0.28 (95 percent CI: 0.16, 0.48),86 0.32 (95 percent CI: 0.19, 0.52),60 and 0.13 (95 percent CI: 0.03, 0.44).41 Levine and colleagues reported on a prospective 3 year multicentre study on SBI in infants 0–2 months of life who presented to the emergency department with fever. Based on rapid Respiratory Syncytial Virus (RSV) testing they were able to assess the impact of RSV status on the prevalence of SBI. Consistent with all the viral studies, there was a significant overall decrease in prevalence of SBI when RSV was identified (7.0 percent vs. 12.5 percent; risk difference 5.5 percent: 1.7, 9.4). Although the majority of the SBI were UTI, bacteremia did occur in the RSV positive group. Only 38.0 percent of RSV positive infants had clinical bronchiolitis. The most important observation from this study was the fact that in the young infant subpopulation (<or equal to 28 days) the prevalence of SBI did not differ between RSV positive or negative groups (10.1 percent vs. 14.2 percent; RR: 0.71; 95 percent CI: 0.35, 1.5).65 In the same study (analyzed data from 5 centers),80 the prevalence of both SBI (RR=0.19, 95 percent CI: 0.06, 0.59) and UTI (RR=0.23, 95 percent CI: 0.07, 0.70) were significantly lower amongst infants with influenza- or RSV-positive test as compared to those with negative test result. There were no significant differences between the two groups of infants with regards to bacteremia (0 percent vs. 2.2 percent, p=0.15) and meningitis (0 percent vs. 0.9 percent, p=0.6).

Clinical bronchiolitis was also found to be a significant predictor against SBI in three studies.5,75,78 In the PROS research network study 0/125 (0 percent) cases of SBI in infants with bronchiolitis versus 212/1933 (10.9 percent) in infants without bronchiolitis were reported.5,76 This study did not provide specific data for the various age groups (within 0-3 months), so it was not clear whether the observed prediction against SBI would apply to the neonatal age group. These results were consistent with data from one study reporting higher prevalence of bacteremia and UTI in infants without bronchiolitis (2.0 percent and 12.0 percent respectively) compared to infants with bronchiolitis (0 percent). Similar results were reported in another prospective study in two pediatric departments from 2005-2007, infants less than 3 months of age who had clinical bronchiolitis versus no clinical bronchiolitis had a significantly decreased chance of SBI 3/136 (2.2 percent) versus 30/312 (9.6 percent) (p = 0.005).75 The three cases of SBI in the clinical bronchiolitis group were UTI, which clinically resolved with antimicrobial therapy.75

In two studies27,74 of infants with nonpolio EV, the odds of having an SBI relative to those without this virus were 0.41 (95 percent CI: 0.15, 0.95)74 and 0.12 (95 percent CI: 0.03, 0.40).27

## KQ 5 What is the evidence that the prevalence of SBI varies among febrile infants presenting to primary care and emergency practice? What is the evidence that prevalence affects the predictive value of clinical and laboratory findings?

### Key Findings

The majority of studies were conducted in North American emergency department settings. The prevalence of SBI tended to be higher in the emergency departments versus primary care setting offices. The effect of prevalence of total SBI on the PPVs was possible to be examined only for the Philadelphia protocol and the Rochester criteria. For the Philadelphia protocol, the prevalence of total SBI did not appear to affect the observed PPVs. For the Rochester criteria, higher prevalence of total SBI corresponded to higher PPVs.

### Detailed Presentation

In order to assess whether the prevalence of total SBI (and/or HSV) varied depending on the setting (i.e., emergency department vs. primary care) of the study, the included studies reporting the prevalence of total SBI (and/or HSV) were divided by the setting and were matched by the country of conduct. Overall, there were 70 studies included in this section.

Although in one study conducted in the U.S., nine SBI cases had been identified amongst infants 3 months or younger, the prevalence of SBI could not be calculated due to lack of the appropriate denominator (i.e., the number of infants with culture results).113 There was insufficient data to compare the prevalence of bacteremia or meningitis between emergency and primary care settings.

For the studies conducted in North America (Table 10), the prevalence of total SBI in the emergency departments ranged from 4.1 percent10 to 25.1 percent.25 More than half of the studies conducted in emergency departments of North America reported the prevalence of total SBI ≥10.0 percent. One U.S. study,81 reported an increase in the rate of SBI for the period of 2002–2006 compared to 1997–2001 (14.4 percent 6.5 percent, p = 0.001). This increase was reported to be due to an increase in E. coli UTI particularly in infants 31–3 months of age. Of the 3 primary care setting study reports,5,27,34 two reported the prevalence of total SBI of 9.9 percent27 and 10.3 percent.5

Table 10 Prevalence of serious bacterial infection by setting for studies across North America

Author (year) | Study Period | Age Range | Prevalence n/ N (%) SBI (or SBI type) | PPV (%) [95% CI]
Emergency Setting
Andreola (2007)87 | 2004- 2005 | < 30 d | 6/52 (11.5) SBI | NR
Andreola (2007)87 | 2004- 2005 | < 90 d | 20/175 (11.4) SBI | NR
Bachur (2001)49 | 1993–1999 | 0–90 d | 373/5,279 (7.0) SBI | 21.0 [19.0, 23.0]
Bachur (2001)52 | 1993–1999 | 0–29 d | 73/868 (8.4) UTI | 48.4 [39.4, 57.5]
Baker (1993)12 | 1987–1992 | 29–56 d | 65/747 (8.7) SBI | 14.0 [11.0, 17.0]
Baker (1999)9 | 1994–1996 | 29–60 d | 43/422 (10.2) SBI | 14.0 [10.0, 17.7]
Baker (1999)11 | 1994–1996 | 3–28 d | 32/254 (12.5) SBI | 18.6 [12.0, 25.0]
Baker (1990)64 | 1987–1988 | 29–56 d | 12/126 (9.5) SBI | 11.4 [3.7, 27.6]
Baskin (1992)56 | 1987–1990 | 28–89 d | 27/501 (5.4) SBI | NR
Berkowitz (1985)109 | 1978–1979 | < 60 d | 10/239 (4.2) sepsis/meningitis | NR
Bonadio (1993)10 | 1991–1992 | 29–60 d | 22/532 (4.1) SBI | 5.9 [3.6, 8.2]
Bonadio (1993)21 | 1991–1992 | 0–29 d | 29/233 (12.4) SBI | 37.3 [25.3, 50.8]
Bonadio (1991)36 | 1986–1990 | 30–60 d | 34/683 (5.0) SBI | 26.0 [11.8, 46.6]
Bonadio (1987)112 | 1986–1987 | 0–28 d | 8/55 (14.5) SBI | NR
Bonadio (1994)38 | 1989–1993 | 60–90 d | 33/356 (9.3) SBI | NR
Bonadio (1992)44 | 1985–1991 | 4–60 d | 81/1,009 (8.0) SBI | NR
Bonadio (1987)114 | 1984–1985 | 0–60 d | 12/159 (7.5) UTI | NR
Bonadio (1991)88 | January–November 1990 | 28–60 d | 18/161 (11.2) SBI | NR
Bonsu (2007)50 | 1993–1999 | 0–89 d | 307/3,765 (8.1) UTI/sepsis | 17.0 [15.1, 19.0]
Bonsu (2003)111 | 1992–1999 | 0–89 d | 38/3,810 (1.0) bacteremia | 2.0 [1.2, 3.2]
Broner (1990)32 | NR | 4- 56 d | 5/52 (9.6) Bacteremia | 10.0 [0.5, 45.8]
Brown (2005)43 | 1999–2002 | < 28 d | 8/66 (12.0) SBI | 21.0 [7.8, 50.2]
Byington (2004)60 | 1996-2002 | 1- 90 d | 109/888 (12.3) SBI | 16.6 [13.8, 20.0]
Byington (2003)93 | 1999-2002 | 1- 90 d | 105/1,298 (8.0) SBI | NR
Byington (1999)74 | 1996–1997 | 0–90 d | 44/345 (12.8) SBI | NR
Caviness (2008)63 | 2001–2005 | 0–28 d | 119/800 (14.8) SBI | 18.1 [13.2, 24.2]
Crain (1988)31 | NR | 0- 15 d | 3/35 (8.5) sepsis/meningitis | 27.3 [7.3, 60.7]
Crain (1990)85 | 1982–1987 | 8- 57 d | 33/442 (7.4) UTI | 64.0 [42.6, 81.3]
Crain (1982)33 | 1979–1981 | 0–60 d | 5/134 (3.7) bacteremia | 4.5 [1.6, 10.6]
Dayan (2002)13 | 1998–2000 | 1–60 d | 27/193 (14.0) UTI | 56.6 [37.6, 74.0]
DeAngelis (1983)115 | 1978–1981 | 0–60 d | 39 /290 (13.4) SBI | NR
Ferguson (2008)116 | 2004–2005 | 30–60 d | 9/90 (10.0) SBI | NR
Ferguson (2008)116 | 2004–2005 | 60–90 d | 10/100 (10.0) SBI | NR
Ferrera (1997)24 | 1990–1994 | 0–28 d | 22/134 (16.4) SBI | 26.8 [17.2, 38.8]
Filippine (2001)62 | 1995–1997 | 0–30 d | 27/113 (23.8) SBI | NR
Garra (2005)25 | 1998–2004 | 0–56 d | 65/259 (25.1) SBI | 13.9 [11.0, 17.0]
Gomez (2010) 30 | 2003–2008 | 0–90 d | 198/1,018 (19.4) SBI | NR
Gomez (2010) 30 | 2003–2008 | 0–90 d | 23/1,018 (2.2) bacteremia | 12.5 [5.4, 22.6]
Grover (1999)117 | 1992–1993 | 0–60 d | 7/48 (14.6) SBI | NR
Herr (2001)28 | 1999–2000 | < 59 d | 41/344 (12.0) SBI | 12.9 [8.8, 18.2]
Hoberman (1993)91 | 1990-1991 | 0–59 d | 306/14 (4.6) UTI | NR
Hsiao (2006)118 | 2003-2004 | 57–90 d | NR (8.8) SBI | NR
Jaskiewicz (1994)23 | 1984–1992 | 0–60 d | 66/931 (7.0) SBI | 12.3 [9.6, 15.6]
Kadish (2000)22 | 1993–1996 | 1–28 d | 45/372 (12.1) SBI | 21.0 [15.5, 27.6]
Kaplan (2000)55 | 1993–1997 | 28–90 d | 191/2,190 (8.7) SBI | 16.2 [14.0, 18.6]
King (1987)39 | 1978–1982 | < 60 d | 4/97 (5.4) bacteremia or meningitis | 5.5 [0.2, 29.3]
Kuppermann (1997)78 | 1993–1995 | 0–60 d | 6/86 (7.0) UTI | NR
Kuppermann (1999)119 | 1994–1995 | 0–60 d | 7/30 (23.3) SBI | NR
Krief (2009) 80 Levine (2004)65 | 1998–2001 | 0–60 d | 123/1,169 (11.4) SBI | NR
Maniaci (2008)61 | 2005–2007 | 0–90 d | 30/234 (12.8) | NR
Meehan (2008)69 | NR (4 Years study) | 0–90 d | 192/2003 (9.6%) SBI | 4.9 [2.5, 9.1]
Rittichier (2005)73 | 1996-2002 | 0–90 d | 15/214 (7.0) SBI | NR
Rosenberg (1985)40 | 1981–1982 | 0–60 d | 5/122 (4.1) bacteremia | NR
Stanley (2005)35 | 1993–2000 | 0–90 d | 480/5,279 (9.1) SBI | NR
Titus (2003)77 | 1997–2001 | 0–60 d | 24/348 (6.9) SBI | NR
Wasserman (1990)67 | NR | < 60 d | 22/236 (9.3) SBI | 21.6 [16.5, 27.7]
Watt (2010)81 | 2002–2006 | 0–90 d | 52/361 (14.4) SBI [UTI: 45/52 (86.0%); 38 cases in infants 31-90 d] | NR
Watt (2010)81 | 1997–2001 | 0–90 d | 20/307 (6.5) SBI [UTI: 13/20 (65%), 9 cases in infants 31–90 d] | NR
Wolff (2009) 42 | 2000–2007 | 45–90 d | 130/1,950 (6.6) SBI | 7.1 [6.7, 7.3]
Zorc (2005)65 | 1999–2001 | 1–60 d | 91/995 (9.0) UTI | 5.6 [1.8, 14.5]
Primary Care Setting
Caspe (1983)34 | 1974–1979 | 0–30 d | 7/107 (6.5) bacteremia | NR
Caspe (1983)34 | 1974–1979 | 30–60 d | 4/198 (2.0) bacteremia | 27.3 [7.3, 60.6]
Dagan (1985)27 | 1982–1984 | 0–90 d | 23/233 (9.9) SBI | 24.7 [16.4, 35.2]
Pantell (2004)5 | PROS Study: 1995–1998 | 0–90 d | 63/3066 (3.6) bacteremia/meningitis | NR
Pantell (2004)5 | PROS Study: 1995–1998 | 0–90 d | 212/2058 (10.3) SBI (excluding Gastroenteritis) | NR

d=days; PPV = positive predictive value; PROS = Pediatric Research in Office Setting; SBI = Serious Bacterial Infection; UTI= urinary tract infection;

For Taiwanese studies (Table 11), the prevalence of total SBI was numerically similar in emergency departments versus primary care setting (17.7 percent–25.2 percent vs. 16.4 percent).57,66

Table 11 Prevalence of serious bacterial infection by setting for studies conducted in other countries (Taiwan, Israel, Spain)

Study ID | Study period | Age range | Prevalence n/ N (%) SBI (or SBI type) | PPV(%) [95% CI]
Emergency Setting In Taiwan
Chen (2009)82 | 2003–2004 | 0–90 d | 34/135 (25.2) SBI | NR
Chiu (1994)66 | 1992–1993 | 4–31 d | 45/254 (17.7) SBI | 30.8 [22.9, 40.0]
Lin (2000)53 | 1997–1998 | < 60 d | 22/162 (13.5) UTI | 34.0 [21.3, 49.4]
Emergency Setting In Israel
Jordan (2008)83 | 2003–2004 | 0–29 d | 62/328 (18.9) SBI | NA
Mintegi (2009)41 | 2003–2008 | 0–90 d | 50/381 (13.1) SBI | 2.7 [0.7, 7.5]
Mintegi (2010)84 | 2003–2007 | 0–29 d | 26/124 (20.1) SBI (UTI, bacteremia, pneumonia) | NA
Mintegi (2010)84 | 2003–2007 | 30 d–90 d | 71/561 (12.6) SBI | NA
Emergency Setting In Spain
Bilavsky (2009) 46 | 2005–2008 | 0–90 d | 102/892 (11.3) SBI | NR
Yarden-Bilavsky (2009/2010) 45 | 2006–2008 | 0–60 d | 134/1257 (10.7) SBI | NA
Yarden-Bilavsky (2009/2010) 45 | 2006–2008 | 0–60 d | 68/833 (8.1) UTI | NA
Yarden-Bilavsky (2009/2010) 45 | 2006–2008 | 0–60 d | 11/833 (1.3) bacteremia | NA
Yarden-Bilavsky (2009/2010) 45 | 2006–2008 | 0–60 d | 10/833 (1.2) pneumonia | NA
Shwartz (2008) 37 | 1997–2006 | < 28 d | 87/449 (19.4) SBI | 32.7 [29.5, 35.1]
Primary Care Setting (only for Taiwan)
Chiu (1997)57 | 1994–1995 | 4–28 d | 41/250 (16.4) SBI | 33.6 [25.1, 42.1]

d=days; PPV = positive predictive value; SBI = serious bacterial infection; UTI= urinary tract infection;

The prevalence of total SBI in the two Spanish studies (both emergency departments) were 13.1 percent41 and 18.9 percent (Table 11).83 In the third Spanish study, the prevalence of SBI was significantly higher in infants younger than 29 days than in those older than 29 days (20.1 percent vs. 12.6 percent, p=0.04).84 This study did not report the crude prevalence of SBI based on the total sample.

In two prospective studies conducted at a hospital emergency department in Israel (Table 11), the prevalence of total SBI were 10.8 percent (infant age: 0 - 2 months)45 and 11.3 percent (infant age: 0–3 months).46 In one of these studies,45 the prevalence of UTI, bacteremia, and pneumonia amongst febrile infants 2 months or younger were 10.8 percent (90/833), 8.1 percent (68/833), 1.3 percent (11/833), and 1.2 percent (10/833), respectively. Another Israeli study,37 reported an estimate of the prevalence of SBI in neonates (0–28 days) of 19.4 percent The prevalence of SBI in this study did not differ for infants aged 3–7 days (21.6 percent), 8–18 days (26.1 percent), 15–21 days (17.9 percent), and 22–28 days (12.1 percent).37

In one Italian study,47 the prevalence of SBI amongst neonates (0–28 days of age) admitted to emergency departments was 25.3 percent.

Across all studies, the prevalence of total SBI was higher in the neonates (age: 0–28 days) ranging from 11.5 percent87 to 25.3 percent47 compared to the older infants (age: > 28 days) in whom it ranged from 4.1 percent10 to 13.0 percent.113

The effect of prevalence of total SBI on the PPVs was possible to be examined only for the Philadelphia protocol9,11,12,22,25 and the Rochester criteria23,24,27,56,57,60 regardless whether a study was conducted in an emergency department or primary care setting in North America or Taiwan (Tables 10–11). For the Philadelphia protocol, the prevalence of total SBI did not appear to contribute to the difference observed in the PPVs. For the Rochester criteria, higher prevalence of total SBI corresponded to higher PPVs. The enrollment rate (n analyzed/N enrolled) in the 11 studies of Philadelphia protocol 9,11,12,22,25 and Rochester criteria 23,24,27,56,57,60 was uniformly high (> 70.0 percent). For example, the enrollment rate in six studies was 100.0 percent,9,11,12,27,56,57 and in four studies > 80.0 percent.22,23,25,60 The enrollment rate was less likely to affect the differences in prevalence of SBI across studies.

## KQ6 Clinicians base decisions about initial diagnostic work-up and treatment of febrile infants not solely on the infants' medical status but also on their assessments of nonclinical factors (e.g., parental understanding, parents' ability to monitor the patient, access to care). A strategy of initial observation without extensive diagnostic tests or hospitalization depends on confidence that parents will reliably bring the baby back for a timely followup appointment if conditions warrant. How likely are parents whose infants are less than 6 months of age and have fever or other potentially serious medical condition to comply with a provider's recommendation that the parent bring the infant back (to that provider or another) for a return appointment to reassess the condition(s) of concern?

### KQ6a and KQ6b What is the evidence that identifiable parental factors (e.g., education, insurance status, living situation, history of previous visits with the provider, time/distance required to travel to an appointment, etc.) allow a provider to judge the likelihood that a parent will adhere to treatment recommendations such as returning for follow-up if circumstances warrant? What is the evidence that the clinical setting (community practice vs. emergency department and/or hospital outpatient clinic) in which care is sought independently influences the likelihood of compliance with a return appointment?

#### Key Findings

Four studies conducted in North America that included children 0–3 months of age reported the degree of parental compliance to the followup visits/telephone calls which ranged from 77.4 percent to 99.8 percent. There was no evidence on parental compliance to the followup visits/telephone calls for infants 3–6 months. Similarly, there was a lack of evidence regarding the influence of parental factors or clinical setting on the degree of parental compliance to the followup visits/telephone calls.

#### Detailed Presentation

Four studies were included in this section.56,59,72,80 The study by Krief,et al., was reported in 3 publications.65,79,80 Three studies were conducted in the United States (1987–2001),56,59,80 and one study was conducted in Canada (2005)72 (Table 12). All studies were prospective in design and included 4,593 children aged of 0–3 months.56,59,72,80

Table 12 KQ6 Factors influencing the likelihood of parental adherence to followup schedule and treatment recommendations for febrile infants 0–6 months of age

Author, (year) RefID Country | Study Design/objective Setting Study period | Population characteristics | Treatment characteristics | Followup details | Results
Baskin, MN (1992)56 US | - Prospective; - ED; - 1987–1997 | N=503 infants 28–89 d (67% 28-60 d, 33% 61-89 d); with fever without a source–476 were treated as outpatients and were followed Age: mean 55 (SD 17) d No other characteristic reported | IMI of Ceftriaxone (2 doses within 24 hrs) pending culture results | 3 phone calls (1–12 hrs; 2–48 hrs; 3–7 d post discharge) and 1 return visit to the ED in 24 hrs post initial visit | Infants with fu at 24 hrs: 494 (98%) who had a 2^nd^ dose of ceftriaxone Infants with fu at 48 hrs: 482 (96%) There was concern about 2/476 (0.42%) parents of infants without SBI about parental supervision —These infants were hospitalized > 24 hrs of initial entry
Condra SC (2010)59 US | Prospective observation/ evaluation of cost and complications in inpatient treatment of febrile infants 29-60 d of age Period: NR – total length of study was 16 months | N = 62 infants 29–60 d; fever without a source; met a criteria derived from Philadelphia for Low Risk for SBI 55% male median age: 44 d 39 (63%) White; 18 (29%) African American, 5 (8%) Hispanic (range 29 -60 d) White (63%), African American (29%), Hispanic (8%). 8 (12.9%) Group B Streptococcus +ve or unknown (the mothers treated with peripartum antibiotics) | Despite meeting LR criteria, 56/62 (90.3%) infants were admitted and received IVI antibiotics 6/62 (9.7%) were LRI and discharged from the ED after a full sepsis workup. | 3 phone followups with parent and primary care provider (PCP) within the 2 wks after discharge + contact with PCP at 14 d post discharge Questionnaire on 1-Intants' health status 2-compliance 3-hospital charges | Compliance with phone calls after initial discharge (reported for FI who were managed as inpatients 56 (90.32%)]: d 2: 77.4%; d 7: 85.4%; d 14: 83.9% All 6 subjects (100%) discharged directly from the ED did have medical followup within 48 hours with PCP Parents preferred discharge to admission (66%-70%) 5/6 (83.3%) discharged infants required reevaluation and 2/6 (33.3%) were hospitalization within 24 hrs of discharge-one for a +ve blood culture (later determined to be a contaminant) and one for continued fever & newly documented pneumonia. Complications in outpatients:
Dore-Bergeron, MJ (2009)72 (10351 commentary) Canada | Prospective cohort/ to investigate feasibility of ambulatory tx at day treatment centre (DTC) One tertiary-care pediatric ED Period: 2005 | N=118 FI 30–90 d with presumed UTI Age: median age for 67 FI admitted to DTC = 66 d (range: 33– 85 d) | Inpatient tx (protocol not described) if any: abnormal CSF, toxic appearance, underlying medical problems, abnormal creatinine levels, parental refusal to fu in DTC, or outpatients tx Ambulatory tx protocol: single IVI gentamicin (5 or 2.5 mg/kg)+ 1 dose IVI ampicillin, & 2 or 3 doses oral amoxicillin, to be taken until the 1^st^ visit to DTC in 24 hrs. At DCT IVI gentamicin daily until the child was afebrile. If UTI was confirmed tx with antibiotics were started. | In outpatient tx, monitoring the fever every 4 hrs + return the child after 24 hrs | 67/118 (56.8%) of FI were admitted to DTC. Rate of parental compliance with DTC visits: 98.3%. Successful tx in the DTC (attendance at all visits, normalization of temperature within 48 hrs, -ve control urine & BC results, & absence of hospitalization): 86.2% of pts with confirmed UTI Compliance with guidelines of antibiotic tx: 80.4%; hospitalization during the course of tx in DTC: 12.1% Adherence of ED physicians to patient referral to the appropriate setting (DTC or hospital ward): lower but not statistically-significant for younger infants, [crude OR, comparing < 60-day-old children with older children: 0.5 (95% CI: 0.2, 1.5)]
Krief (2008)65,79,80 US | Prospective cross sectional/ to determine the risk of SBIs in FI with or without influenza virus infections 5 pediatric ED clinics (original report of this trial include 8 ED hospitals) 3 consecutive influenza seasons 1998-2001 | N=844 FI ≤ 60 d, n=844 FI +ve for influenza virus (original report included 1025 infants) Age: mean 35.8 d, 55% male, median YOS score (IQR 6-8) | Yale Observation Scale (YOS) was used as a tool to determine infants' status. Antibiotic therapy and/or hospitalization, were at the discretion of the responsible physician & not determined by study protocol | One telephone fu on patients discharged from the ED within 4 to 7 d | Compliance with phone fu: 103/132 (78.0%) of discharged infants. 7 (1%) (patients without CSF cultures were determined not to have bacterial meningitis by telephone fu) No information about characteristics of compliant or noncompliant parents/infants was reported.

BC= blood culture; CPT-4=Current Procedural Terminology, Forth Revision CSF=cerebrospinal fluid; d=day/s; FI=febrile infant; fu=follow up; HR= high risk for SBI; hr/s = hour/s; ICD-9-CM=International Classification of Diseases, Ninth Revision, Clinical Modification; IMI = intramuscular injection; IQR=interquartile range; IVI=intravenous injection; LP=lumbar puncture; LR= low risk for SBI; LRI=low risk infants; mo/s= month/s; N = number of participants; #, n, N=number; NR= not reported; RefID=Reference Identification; SBI= serious bacterial infection; tx=treatment; US = United States; UTI= urinary tract infection; wks = weeks; YOS= Yale Observational Scale; yrs = years;

None of the studies reported any evidence regarding the influence of parental factors (e.g., age, education, distance/time to travel to an appointment, living situation) or clinical settings (emergency department vs. primary care office) on rates of parental compliance to telephone or return visit followups.

In the study by Baskin (1992) conducted in the U.S.,56 outpatient treatment of febrile infants (28–89 days) and adherence to strict follow up protocol was investigated as an alternative to hospital admission during the period of 39 months (1987–1988). The included 503 infants were febrile well appearing (≥ 38° C) with peripheral leukocyte count < 20 × 109 cells/L, cerebrospinal fluid leukocyte count < 10 ×106/L, and without any urinary leukocyte esterase. All infants were required to have a caretaker available by telephone. Follow up was obtained for all except one infant (99.8 percent). Infants were initially treated with intramuscular injection of ceftriaxone (50 mg/kg) and then discharged from the emergency department. A second injection of ceftriaxone was administered on return visit in 24 hours. Follow up calls were conducted at 12 hours, 2 days, and 7 days later after first entry to ED. When culture results became available, patients with bacterial growth in cultures of blood, CSF, urine, or stool were immediately recalled to the emergency department for appropriate antimicrobial therapy.

Twenty seven of 503 (5.4 percent) infants were identified with SBI. A 24 hour visit and administration of 2nd dose of ceftriaxone was documented for 494 (98.0 percent) of infants. A 48 hour telephone call was made for 475 (94.0 percent) and a 7 day call for 482 (96.0 percent). Overall some follow up was obtained for all but one infant. All infants without SBI 453 (95.2 percent) were treated successfully as outpatient. Twenty three infants without SBI (4.8 percent) were hospitalized due to concerns documented during follow ups. Two of these infants were hospitalized more than 24 hours due to concerns about parental supervision.

In a prospective multicenter U.S. study by Krief et al (2009)65 during the period of 1998 - 2001, the risk of SBI in infants with or without influenza virus infections in 1091 infants ≤ 2 months of age was compared. The Yale observation scale (YOS) score was determined by the examining physician upon admission to ED (prior to laboratory evaluations). Eighty five percent (n=712) of infants tested for influenza virus were admitted to the hospital. Telephone follow ups on patients discharged from the ED (n=132) within 4–7 days were performed and were successfully completed for 103 (78.0 percent) infants. No other information about noncompliant infants was reported.

In one Canadian study by Dore-Bergeron (2008),72 the feasibility of ambulatory treatment of 67 febrile infants (aged 33-85 days) with presumed UTI presented to ED of a tertiary hospital was investigated. The diagnosis of UTI was confirmed for 86.6 percent of infants treated in a Day Treatment Center (DTC). Seven infants were subsequently admitted to hospital due to confirmed bacteremia or other complications. The treatment protocol for ambulatory patients included a single dose of intravenous gentamicin, a single dose of ampicillin and 2 or 3 doses of oral amoxicillin until the next visit to DTC in 24 hours. Parents were instructed to monitor the fever every 4 hours during 24 hours after initial visit to ED. Daily administration of intravenous antibiotics was continued at DTC until the infant was afebrile or diagnosed with SBI (UTI) in which case full course of antibiotic treatment would follow. Four infants were hospitalized because of parents' refusal to follow up with the DTC protocol. Parental compliance with DTC visits and with antibiotic treatment at home was 98.3 percent and 80.4 percent, respectively. There were no differences in rate of compliance with DTC treatment between parents of younger infants (≤ 2 months) and those of older infants (2-3 months).

Adherence of ED physicians to patient referral to the appropriate setting (DTC or hospital ward) was somewhat lower for younger infants, but this association was not statistically significant (comparing <2 month -old children with older children: crude OR: 0.5; 95 percent CI: 0.2–1.5). The authors conclude that ambulatory treatment of infants 1-3 months of age with febrile UTI is a feasible option.

One U.S. study by Condra (2010),59 investigated the costs and complications involved in the inpatient treatment with antibiotic therapy for 62 febrile infants aged 29–60 days. This study included infants meeting Philadelphia criteria for low risk for SBIs during a 16 months study period. Six (9.7 percent) of the 62 low risk subjects were discharged from the ED by the physician after a full evaluation for sepsis. Five (83.3 percent) discharged infants required reevaluation, and two (33.3 percent) required reevaluation and hospitalization within 24 hours of discharge (one for an erroneous positive blood culture and one for continued fever and newly documented pneumonia). Despite meeting low-risk criteria, all remaining 56 febrile infants were hospitalized and received intravenous antibiotics.

Followup calls were scheduled and were successful on days 2 (77.4 percent), 7 (85.4 percent), and 14 (83.9 percent) after discharge. All six subjects (100.0 percent) discharged directly from the ED did have medical followups within 48 hours. Medical followup with primary care provider was not made for one third (27.4 percent) of infants discharged after hospitalization. This study also reported that after the experience of hospitalization most parents preferred discharge rather than admission.

There was a lack of evidence regarding the influence of parental factors or clinical setting on the degree of parental compliance to the followup visits/telephone calls.

#### Excluded Studies- Qualitative Description

Nine studies reported somewhat relevant outcomes in pediatric population (age 0–6 months) but data was not stratified by age.120-128 A brief summary of these studies is provided in this section.

In a U.S. quasi-experimental study by O'Neill-Murphy (2001),124 education (interactive fever education program and the standard written fever pamphlet) on fever and its effect on parental anxiety in parents of febrile (> 38.4° C) children 3 months to 5 years of age was investigated. Outcomes included correct use of a thermometer, fever home management skills, and appropriate fever telephone follow up. Both intervention programs were equally effective in improving all outcomes. This information was not reported for parents of children less than 6 months of age.

In another study by Sarrell (2003),123 impact of a single session education program on parental knowledge and approach to low grade childhood fever (< 38.5° C) was investigated. This study included parents of children with a broad age range (mean age of youngest child 53.5 months). This study indicates that parental knowledge of fever management in children can be improved by reinforced educational session. The outcomes were not stratified by age groups.

One study by Hemphill (1998),125 reported compliance rates in 423 febrile children aged 3 months - 10 years. In this study, the follow up rates during the period of 1993-1994 were compared between two medical systems in U.S. with preset appointments after ED release and free medical care (WHMC); or one in which parents must arrange follow up appointments after ED release (FFX). One to 7 days telephone follow ups were conducted. Variables associated with poor followup compliance for the entire study population were: Hispanic children (OR: 2.5, 95 percent CI 1.3-4.8), children within the FFX system of follow ups (OR: 2.5, 95 percent CI: 1.1-5.3), children whose parents did not speak English (OR: 2.8, 95 percent CI 1.2-6.6), and children who were told to follow up in 2–3 days after the ED visit rather than in 1 day (OR 1.7, 95 percent CI 1.3-2.2). Compliance to follow up in the WHMC system was better compared with that in the FFX system (92.0 percent vs. 67.0 percent, p < 0.001). For FFX alone the following factors were associated with poor follow up: Hispanic ethnicity, self-payer status, lack of a primary physician for follow up, the diagnosis of otitis media, and follow up in > 24 hours.

In one study by Crane (2000)121 parents' compliance to after-hours telephone advice given by pediatric residents in a continuity clinic in U.S. was investigated. Study population consisted of 412 consecutive patients enrolled in the resident-staffed pediatric continuity clinic with access to a telephone triage system. Only 21.0 percent of chief complaint of children was fever. No specific outcomes for the febrile children were reported. Overall 412 (87.0 percent) of caregivers complied with the advice given over the telephone by resident. The study reports no discrepancy in caregiver compliance based on the child's age. Most of the 474 calls were about children younger than 1 year. Only slightly higher levels of compliance were noted among parents of children younger than 3 months, whereas lower levels of compliance were found in parents of children aged 1–3 years.

In one U.S. study by Baker (2009),122 the impact of a brief educational video shown to parents during an emergency department visit for minor febrile illness was investigated. 280 caregivers of febrile children 3–36 months were enrolled into two intervention groups (either an 11 minutes fever education video or a control child safety video). There was no difference between the rates of return visit to ED for fever for intervention or control groups. The consensus among the three blinded independent ED physician reviewers was that 30/81 visits (37.0 percent) were medically necessary in the intervention group compared with 21/81 (25.9 percent) in the control group (statistically not significant, p = 0.07). The overall rate of medical necessity was found to be 31.5 percent.

In a prospective cohort study by Gauthier (2004),126 feasibility and complications of outpatient management with IV antibiotics among 212/291 episodes of UTI (72.9 percent) in 275 febrile infants and children (3 months to 5 years) treated at a day treatment center of a tertiary care pediatric hospital was investigated. This study was conducted in the U.S. in 2002-2003. In this study children who appeared nontoxic were treated with IV ampicillin and three doses of oral amoxicillin to be taken until the visit at the day treatment centre within the next 24 hrs. Parents were asked to measure the child's temperature every 4-6 hrs during IV treatment. In total there were 202 children treated at the DTC, 65 children treated as inpatient, and eight who were discharged from the ED with oral treatment. In 9/71 hospital admissions, the child was admitted due to parents refusal or inability to comply with day treatment center treatment protocol. Overall, the adherence to protocol for both physicians and parents were described as excellent. The data for infants and children under 6 months of age was not presented.

Baker (1999),127 in a U.S. survey of three private practices, and one urban hospital based nonprivate practice during a 2 week period in 1996 compared compliance with recommended ED or office visit referrals in the two settings. Pediatric telephone triage and advice system (developed by Barton D. Schmitt) was used to evaluate medical complaints and suggest appropriate management including referral for physician evaluation (immediate, 4 hours, 24 hours, 48 hours, 72 hours, 2 weeks) and/or advice for caregiver for management in the home. In total 663 calls were received from 377 nonprivate practice patients (age range 1–192 months; mean 39 months) and 286 for private practice patients (age range 1–242 months; mean age 58 months). Only six percent of all calls were based on a primary complaint of fever. Other complaints included respiratory complaints (21.0 percent), trauma (14.0 percent), rash (10.0 percent) and miscellaneous (36.0 percent). Significantly more nonprivate practice patients were referred to their primary care physician for an office visit (p = 0.005) or were referred to an ED or urgent care facility for immediate evaluation (p=0.01). There were no differences between compliance rates of the two settings. Data was not stratified for infants with fever.

In one retrospective study by Vidwan, G (2010),128 conducted in U.S. at an urban academic tertiary care pediatric hospital ED during the period of 2000-2005, management and outcome of focal bacterial infections in nontoxic infants under 2 months of age was investigated. In this study febrile (39) and afebrile infants (158) were included. Twenty-three (59.0 percent) of the febrile infants were discharged home from the ED. Two (8.7 percent) of these infants were returned to the ED within 72 hours; both were initially diagnosed with acute otitis (AOM) media and had planned followups as no primary care was available. No other information regarding the follow up visits or mode of contact was provided.