# References

1 Vachvanichsanong P. Urinary tract infection: one lingering effect of childhood kidney diseases--review of the literature. [Review] [78 refs]. JN. J. Jan. 2007;20(1):21-8. [pmid: 17347969].
2 Hsieh WB, Chiu NC, Hu KC, et al. Outcome of herpes simplex encephalitis in children. J Microbiol Immunol Infect. Feb. 2007;40(1):34-8. [pmid: 17332904].
3 Chang SL, Caruso TJ, Shortliffe LD. Magnetic resonance imaging detected renal volume reduction in refluxing and nonrefluxing kidneys. J Urol. Dec. 2007;178(6):2550-4. [pmid: 17937957].
4 McCarthy PL, Sharpe MR, Spiesel SZ, et al. Observation scales to identify serious illness in febrile children. Pediatrics. Nov. 1982;70(5):802-9. [pmid: 7133831].
5 Pantell RH, Newman TB, Bernzweig J, et al. Management and outcomes of care of fever in early infancy. JAMA. Mar. 10. 2004;291(10):1203-12. [pmid: 15010441].
6 Maayan-Metzger A, Mazkereth R, Shani A, et al. Risk factors for maternal intrapartum fever and short-term neonatal outcome. Fetal Pediatr Pathol. May. 2006;25(3):169-77. [pmid: 17060193].
7 Lagos RM, Munoz AE, Levine MM. Prevalence of pneumococcal bacteremia among children <36 months of age presenting with moderate fever to pediatric emergency rooms of the Metropolitan Region (Santiago), Chile. Hum. May. 2006;2(3):129-33. [pmid: 17012904].
8 Baraff LJ. Management of fever without source in infants and children. Ann Emerg Med. Dec. 2000;36(6):602-14. [pmid: 11097701].
9 Baker MD, Bell LM, Avner JR. The efficacy of routine outpatient management without antibiotics of fever in selected infants. Pediatrics. Mar. 1999;103(3):627-31. [pmid: 10049967].
10 Bonadio WA, Hagen E, Rucka J, et al. Efficacy of a protocol to distinguish risk of serious bacterial infection in the outpatient evaluation of febrile young infants. Clin Pediatr (Phila). Jul. 1993;32(7):401-4. [pmid: 8365074].
11 Baker MD, Bell LM. Unpredictability of serious bacterial illness in febrile infants from birth to 1 month of age. Arch Pediatr Adolesc Med. May. 1999;153(5):508-11. [pmid: 10323632].
12 Baker MD, Bell LM, Avner JR. Outpatient management without antibiotics of fever in selected infants. N Engl J Med. Nov. 11. 1993;329(20):1437-41. [pmid: 8413453].
13 Dayan PS, Bennett J, Best R, et al. Test characteristics of the urine Gram stain in infants <or= 60 days of age with fever. Pediatr Emerg Care. Feb. 2002;18(1):12-4. [pmid: 11862130].
14 Evidence based clinical practice guideline for fever of uncertain source in infants 60 days of age or less. Available at: National Guideline Clearing House. www.ngc.gov/content.aspx?id=24529. 12-12-2011.
15 Baraff LJ, Bass JW, Fleisher GR, et al. Practice guideline for the management of infants and children 0 to 36 months of age with fever without source. Agency for Health Care Policy and Research. Ann Emerg Med. Jul. 1993;22(7):1198-210. [pmid: 8517575].
16 Luszczak M. Evaluation and management of infants and young children with fever. Am Fam Physician. Oct. 1. 2001;64(7):1219-26. [pmid: 11601804].
17 Kimberlin DW. Neonatal herpes simplex infection. Clin Microbiol Rev. Jan. 2004;17(1):1-13. [pmid: 14726453].
18 Chawes BL, Rechnitzer C, Schmiegelow K, et al. [Procalcitonin for early diagnosis of bacteraemia in children with cancer]. [Danish]. Ugeskr Laeger. Jan. 8. 2007;169(2):138-42. [pmid: 17227662].
19 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
20 Cochrane Handbook for Systematic Reviews of Interventions. [updated September 2008]. www.cochrane-handbook.org. 3-2-2009.
21 Bonadio WA, Hennes H, Smith D, et al. Reliability of observation variables in distinguishing infectious outcome of febrile young infants. Pediatr Infect Dis J. Feb. 1993;12(2):111-4. [pmid: 8426766].
22 Kadish HA, Loveridge B, Tobey J, et al. Applying outpatient protocols in febrile infants 1-28 days of age: can the threshold be lowered?. Clin Pediatr (Phila). Feb. 2000;39(2):81-8. [pmid: 10696544].
23 Jaskiewicz JA, McCarthy CA, Richardson AC, et al. Febrile infants at low risk for serious bacterial infection--an appraisal of the Rochester criteria and implications for management. Febrile Infant Collaborative Study Group. Pediatrics. Sep. 1994;94(3):390-6. [pmid: 8065869].
24 Ferrera PC, Bartfield JM, Snyder HS. Neonatal fever: utility of the Rochester criteria in determining low risk for serious bacterial infections. Am J Emerg Med. May. 1997;15(3):299-302. [pmid: 9148992].
25 Garra G, Cunningham SJ, Crain EF. Reappraisal of criteria used to predict serious bacterial illness in febrile infants less than 8 weeks of age. Acad Emerg Med. Oct. 2005;12(10):921-5. [pmid: 16204135].
26 Dagan R, Sofer S, Phillip M, et al. Ambulatory care of febrile infants younger than 2 months of age classified as being at low risk for having serious bacterial infections. J Pediatr. Mar. 1988;112(3):355-60. [pmid: 3346773].
27 Dagan R, Powell KR, Hall CB, et al. Identification of infants unlikely to have serious bacterial infection although hospitalized for suspected sepsis. J Pediatr. Dec. 1985;107(6):855-60. [pmid: 4067741].
28 Herr SM, Wald ER, Pitetti RD, et al. Enhanced urinalysis improves identification of febrile infants ages 60 days and younger at low risk for serious bacterial illness. [see comment]. Pediatrics. Oct. 2001;108(4):866-71. [pmid: 11581437].
29 Marom R, Sakran W, Antonelli J, et al. Quick identification of febrile neonates with low risk for serious bacterial infection: an observational study. [see comment]. Arch Dis Child Fetal Neonatal Ed. Jan. 2007;92(1):F15-F18. [pmid: 17185424].
30 Gomez B, Mintegi S, Benito J, et al. Blood culture and bacteremia predictors in infants less than three months of age with fever without source. Pediatr Infect Dis J. Jan. 2010;29(1):43-7. [pmid: 19934784].
31 Crain EF, Gershel JC. Which febrile infants younger than two weeks of age are likely to have sepsis? A pilot study. Pediatr Infect Dis J. Aug. 1988;7(8):561-4. [pmid: 3174300].
32 Broner CW, Polk SA, Sherman JM. Febrile infants less than eight weeks old. Predictors of infection. Clin Pediatr (Phila). Aug. 1990;29(8):438-43. [pmid: 2208902].
33 Crain EF, Shelov SP. Febrile infants: predictors of bacteremia. J Pediatr. Nov. 1982;101(5):686-9. [pmid: 7131141].
34 Caspe WB, Chamudes O, Louie B. The evaluation and treatment of the febrile infant. Pediatr Infect Dis. Mar. 1983;2(2):131-5. [pmid: 6856491].
35 Stanley R, Pagon Z, Bachur R. Hyperpyrexia among infants younger than 3 months. Pediatr Emerg Care. May. 2005;21(5):291-4. [pmid: 15874809].
36 Bonadio WA, McElroy K, Jacoby PL, et al. Relationship of fever magnitude to rate of serious bacterial infections in infants aged 4-8 weeks. Clin Pediatr (Phila). Aug. 1991;30(8):478-80. [pmid: 1914347].
37 Schwartz S, Raveh D, Toker O, et al. A week-by-week analysis of the low-risk criteria for serious bacterial infection in febrile neonates. Arch Dis Child. Apr. 2009;94(4):287-92. [pmid: 18977786].
38 Bonadio WA, Smith DS, Sabnis S. The clinical characteristics and infectious outcomes of febrile infants aged 8 to 12 weeks. Clin Pediatr (Phila). Feb. 1994;33(2):95-9. [pmid: 8200162].
39 King JC Jr., Berman ED, Wright PF. Evaluation of fever in infants less than 8 weeks old. South Med J. Aug. 1987;80(8):948-52. [pmid: 3303362].
40 Rosenberg N, Vranesich P, Cohen S. Incidence of serious infection in infants under age two months with fever. Pediatr Emerg Care. Jun. 1985;1(2):54-6. [pmid: 3843433].
41 Mintegi S, Garcia-Garcia JJ, Benito J, et al. Rapid influenza test in young febrile infants for the identification of low-risk patients. Pediatr Infect Dis J. Nov. 2009;28(11):1026-8. [pmid: 19654567].
42 Wolff M, Bachur R. Serious bacterial infection in recently immunized young febrile infants. Acad Emerg Med. Dec. 2009;16(12):1284-9. [pmid: 20053249].
43 Brown L, Shaw T, Wittlake WA. Does leucocytosis identify bacterial infections in febrile neonates presenting to the emergency department?. Emerg Med J. Apr. 2005;22(4):256-9. [pmid: 15788823].
44 Bonadio WA, Smith D, Carmody J. Correlating CBC profile and infectious outcome. A study of febrile infants evaluated for sepsis. [Review] [10 refs]. Clin Pediatr (Phila). Oct. 1992;31(10):578-82. [pmid: 1395363].
45 Bilavsky E, Yarden-Bilavsky H, Amir J, et al. Should complete blood count be part of the evaluation of febrile infants aged <=2 months?. Acta Paediatr. 2010;99(9):1380-4. [pmid: 20367618].
46 Bilavsky E, Yarden-Bilavsky H, Ashkenazi S, et al. C-reactive protein as a marker of serious bacterial infections in hospitalized febrile infants. Acta Paediatr. 2009;98(11):1776-80. [pmid: 19664100].
47 Bressan S, Andreola B, Cattelan F, et al. Predicting severe bacterial infections in well-appearing febrile neonates: Laboratory markers accuracy and duration of fever. Pediatr Infect Dis J. 2010;29(3):227-32. [pmid: 19949364].
48 Olaciregui EI, Hernandez U, Munoz JA, et al. Markers that predict serious bacterial infection in infants under 3 months of age presenting with fever of unknown origin. Arch Dis Child. 2009;94(7):501-5. [pmid: 19158133].
49 Bachur RG, Harper MB. Predictive model for serious bacterial infections among infants younger than 3 months of age. Pediatrics. Aug. 2001;108(2):311-6. [pmid: 11483793].
50 Bonsu BK, Harper MB. Leukocyte counts in urine reflect the risk of concomitant sepsis in bacteriuric infants: a retrospective cohort study. BMC Pediatr. 2007;7:24. [pmid: 17567901].
51 Schroeder AR, Newman TB, Wasserman RC, et al. Choice of urine collection methods for the diagnosis of urinary tract infection in young, febrile infants. Arch Pediatr Adolesc Med. Oct. 2005;159(10):915-22. [pmid: 16203935].
52 Bachur R, Harper MB. Reliability of the urinalysis for predicting urinary tract infections in young febrile children. Arch Pediatr Adolesc Med. Jan. 2001;155(1):60-5. [pmid: 11177064].
53 Lin DS, Huang SH, Lin CC, et al. Urinary tract infection in febrile infants younger than eight weeks of Age. Pediatrics. Feb. 2000;105(2):E20. [pmid: 10654980].
54 Reardon JM, Carstairs KL, Rudinsky SL, et al. Urinalysis is not reliable to detect a urinary tract infection in febrile infants presenting to the ED. Am J Emerg Med. 2009;27(8):930-2. [pmid: 19857409].
55 Kaplan RL, Harper MB, Baskin MN, et al. Time to detection of positive cultures in 28- to 90-day-old febrile infants. Pediatrics. Dec. 2000;106(6):E74. [pmid: 11099617].
56 Baskin MN, O'Rourke EJ, Fleisher GR. Outpatient treatment of febrile infants 28 to 89 days of age with intramuscular administration of ceftriaxone. J Pediatr. Jan. 1992;120(1):22-7. [pmid: 1731019].
57 Chiu CH, Lin TY, Bullard MJ. Identification of febrile neonates unlikely to have bacterial infections. Pediatr Infect Dis J. Jan. 1997;16(1):59-63. [pmid: 9002103].
58 Brik R, Hamissah R, Shehada N, et al. Evaluation of febrile infants under 3 months of age: is routine lumbar puncture warranted?. Isr J Med Sci. Feb. 1997;33(2):93-7. [pmid: 9254869].
59 Condra CS, Parbhu B, Lorenz D, et al. Charges and complications associated with the medical evaluation of febrile young infants. Pediatr Emerg Care. 2010;26(3):186-91. [pmid: 20179660].
60 Byington CL, Enriquez FR, Hoff C, et al. Serious bacterial infections in febrile infants 1 to 90 days old with and without viral infections. Pediatrics. Jun. 2004;113(6 Part 1):1662-6. [pmid: 15173488].
61 Maniaci V, Dauber A, Weiss S, et al. Procalcitonin in young febrile infants for the detection of serious bacterial infections. Pediatrics. Oct. 2008;122(4):701-10. [pmid: 18829791].
62 Filippine MM, Katz BZ. Neonatal herpes simplex virus infection presenting with fever alone. J Hum Virol. Jul. 2001;4(4):223-5. [pmid: 11694851].
63 Caviness AC, Demmler GJ, Almendarez Y, et al. The prevalence of neonatal herpes simplex virus infection compared with serious bacterial illness in hospitalized neonates. J Pediatr. Aug. 2008;153(2):164-9. [pmid: 18534225].
64 Baker MD, Avner JR, Bell LM. Failure of infant observation scales in detecting serious illness in febrile, 4- to 8-week-old infants. Pediatrics. Jun. 1990;85(6):1040-3. [pmid: 2339027].
65 Zorc JJ, Levine DA, Platt SL, et al. Clinical and demographic factors associated with urinary tract infection in young febrile infants. Pediatrics. Sep. 2005;116(3):644-8. [pmid: 16140703].
66 Chiu CH, Lin TY, Bullard MJ. Application of criteria identifying febrile outpatient neonates at low risk for bacterial infections. Pediatr Infect Dis J. Nov. 1994;13(11):946-9. [pmid: 7845745].
67 Wasserman GM, White CB. Evaluation of the necessity for hospitalization of the febrile infant less than three months of age. Pediatr Infect Dis J. Mar. 1990;9(3):163-9. [pmid: 2336297].
68 Shin SH, Choi CW, Lee JA, et al. Risk factors for serious bacterial infection in febrile young infants in a community referral hospital. J Korean Med Sci. 2009;24(5):844-8. [pmid: 19794981].
69 Meehan WP III, Bachur RG. Predictors of cerebrospinal fluid pleocytosis in febrile infants aged 0 to 90 days. Pediatr Emerg Care. May. 2008;(5):287-93. [pmid: 18496111].
70 McCarthy CA, Powell KR, Jaskiewicz JA, et al. Outpatient management of selected infants younger than two months of age evaluated for possible sepsis. Pediatr Infect Dis J. Jun. 1990;9(6):385-9. [pmid: 2367158].
71 Chen HL, Hung CH, Tseng HI, et al. Soluble form of triggering receptor expressed on myeloid cells-1 (sTREM-1) as a diagnostic marker of serious bacterial infection in febrile infants less than three months of age. Jpn J Infect Dis. Jan. 2008;61(1):31-5. [pmid: 18219131].
72 Dore-Bergeron MJ, Gauthier M, Chevalier I, et al. Urinary tract infections in 1- to 3-month-old infants: ambulatory treatment with intravenous antibiotics. Pediatrics. Jul. 2009;124(1):16-22. [pmid: 19564278].
73 Rittichier KR, Bryan PA, Bassett KE, et al. Diagnosis and outcomes of enterovirus infections in young infants. Pediatr Infect Dis J. Jun. 2005;24(6):546-50. [pmid: 15933567].
74 Byington CL, Taggart EW, Carroll KC, et al. A polymerase chain reaction-based epidemiologic investigation of the incidence of nonpolio enteroviral infections in febrile and afebrile infants 90 days and younger. Pediatrics. Mar. 1999;103(3):E27. [pmid: 10049983].
75 Bilavsky E, Shouval DS, Yarden-Bilavsky H, et al. A prospective study of the risk for serious bacterial infections in hospitalized febrile infants with or without bronchiolitis. Pediatr Infect Dis J. Mar. 2008;27(3):269-70. [pmid: 18277919].
76 Luginbuhl LM, Newman TB, Pantell RH, et al. Office-based treatment and outcomes for febrile infants with clinically diagnosed bronchiolitis. Pediatrics. Nov. 2008;122(5):947-54. [pmid: 18977972].
77 Titus MO, Wright SW. Prevalence of serious bacterial infections in febrile infants with respiratory syncytial virus infection. Pediatrics. Aug. 2003;112(2):282-4. [pmid: 12897274].
78 Kuppermann N, Bank DE, Walton EA, et al. Risks for bacteremia and urinary tract infections in young febrile children with bronchiolitis. Arch Pediatr Adolesc Med. Dec. 1997;151(12):1207-14. [pmid: 9412595].
79 Levine DA, Platt SL, Dayan PS, et al. Risk of serious bacterial infection in young febrile infants with respiratory syncytial virus infections. Pediatrics. Jun. 2004;113(6):1728-34. [pmid: 15173498].
80 Krief WI, Levine DA, Platt SL, et al. Influenza virus infection and the risk of serious bacterial infections in young febrile infants. Pediatrics. Jul. 2009;124(1):30-9. [pmid: 19564280].
81 Watt K, Waddle E, Jhaveri R. Changing epidemiology of serious bacterial infections in febrile infants without localizing signs. PLoS One. 2010;5(8):e12448. [pmid: 20805983].
82 Chen CJ, Lo YF, Huang MC, et al. A model for predicting risk of serious bacterial infection in febrile infants younger than 3 months of age. J Chin Med Assoc. Oct. 2009;72(10):521-6. [pmid: 19837646].
83 Jordan I, Esteva C, Esteban E, et al. Severe enterovirus disease in febrile neonates. Enferm Infecc Microbiol Clin. Aug. 2009;27(7):399-402. [pmid: 19409661].
84 Mintegi S, Benito J, Astobiza E, et al. Well appearing young infants with fever without known source in the Emergency Department: Are lumbar punctures always necessary?. Eur J Emerg Med. 2010;17(3):167-9. [pmid: 19820403].
85 Crain EF, Gershel JC. Urinary tract infections in febrile infants younger than 8 weeks of age. [see comment]. Pediatrics. Sep. 1990;86(3):363-7. [pmid: 2388785].
86 Smitherman HF, Caviness AC, Macias CG. Retrospective review of serious bacterial infections in infants who are 0 to 36 months of age and have influenza A infection. Pediatrics. Mar. 2005;115(3):710-8. [pmid: 15741376].
87 Andreola B, Bressan S, Callegaro S, et al. Procalcitonin and C-reactive protein as diagnostic markers of severe bacterial infections in febrile infants and children in the emergency department. Pediatr Infect Dis J. Aug. 2007;26(8):672-7. [pmid: 17848876].
88 Bonadio WA, Lehrmann M, Hennes H, et al. Relationship of temperature pattern and serious bacterial infections in infants 4 to 8 weeks old 24 to 48 hours after antibiotic treatment. Ann Emerg Med. Sep. 1991;20(9):1006-8. [pmid: 1877764].
89 Avner JR, Baker MD. Management of fever in infants and children. [Review] [64 refs]. Emerg Med Clin North Am. Feb. 2002;20(1):49-67. [pmid: 11826637].
90 Ishimine P. Fever without source in children 0 to 36 months of age. Pediatr Clin North Am. 2006;53(2):167-94. [pmid: 16574521].
91 Hoberman A, Chao HP, Keller DM, et al. Prevalence of urinary tract infection in febrile infants. J Pediatr. Jul. 1993;123(1):17-23. [pmid: 8320616].
92 Bonadio WA, Webster H, Wolfe A, et al. Correlating infectious outcome with clinical parameters of 1130 consecutive febrile infants aged zero to eight weeks. Pediatr Emerg Care. Apr. 1993;9(2):84-6. [pmid: 8483786].
93 Byington CL, Rittichier KK, Bassett KE, et al. Serious bacterial infections in febrile infants younger than 90 days of age: the importance of ampicillin-resistant pathogens. Pediatrics. May. 2003;111(5 Pt 1):964-8. [pmid: 12728072].
94 Kropp RY, Wong T, Cormier L, et al. Neonatal herpes simplex virus infections in Canada: results of a 3-year national prospective study. Pediatrics. Jun. 2006;117(6):1955-62. [pmid: 16740836].
95 Brown ZA, Wald A, Morrow RA, et al. Effect of serologic status and cesarean delivery on transmission rates of herpes simplex virus from mother to infant. JAMA. Jan. 8. 2003;289(2):203-9. [pmid: 12517231].
96 Huppler AR, Eickhoff JC, Wald ER. Performance of low-risk criteria in the evaluation of young infants with fever: Review of the literature. Pediatrics. 2010;125(2):228-33. [pmid: 20083517].
97 Young PC. The management of febrile infants by primary-care pediatricians in Utah: comparison with published practice guidelines. Pediatrics. May. 1995;95(5):623-7. [pmid: 7724295].
98 Bergman DA, Mayer ML, Pantell RH, et al. Does clinical presentation explain practice variability in the treatment of febrile infants?. Pediatrics. Mar. 2006;117(3):787-95. [pmid: 16510659].
99 McGowan JE Jr., Bratton L, Klein JO, et al. Bacteremia in febrile children seen in a “walk-in” pediatric clinic. N Engl J Med. Jun. 21. 1973;288(25):1309-12. [pmid: 4145198].
100 Sampson M, McGowan J, Lefebvre C, et al. PRESS: Peer Review of Electronic Search Strategies. H0477. Ottawa, Ont. Canadian Agency for Drugs and Technologies in Health. 2008.
101 Moher D, Horsley T, Morgan K, et al. Clin Pediatr (Phila) (Protocol). Cochrane Database Syst Rev. 2007;(4).
102 Zamora J, Abraira V, Muriel A, et al. Meta-DiSc: a software for meta-analysis of test accuracy data. BMC Med Res Methodol. 2006;6:31. [pmid: 16836745].
103 Yarden-Bilavsky H, Bilavsky E, Amir J, et al. The relationship between fever magnitude and serious bacterial infections in febrile infants less than two-months-old--a prospective study. Harefuah. 794. 148(11):752-5. 794. [pmid: 20027975].
104 Dauber A, Weiss S, Maniaci V, et al. Procalcitonin levels in febrile infants after recent immunization. Pediatrics. Nov. 2008;122(5):e1119-e1122. [pmid: 18977961].
105 Chen HL, Hung CH, Tseng HI, et al. Circulating chemokine levels in febrile infants with serious bacterial infections. Kaohsiung J Med Sci. Dec. 2009;25(12):633-9. [pmid: 19951848].
106 Newman TB, Bernzweig JA, Takayama JI, et al. Urine testing and urinary tract infections in febrile infants seen in office settings: the Pediatric Research in Office Settings' Febrile Infant Study. Arch Pediatr Adolesc Med. Jan. 2002;156(1):44-54. [pmid: 11772190].
107 Unkel JH, McKibben DH, Fenton SJ, et al. Comparison of odontogenic and nonodontogenic facial cellulitis in a pediatric hospital population. Pediatr Dent. Nov. 1997;19(8):476-9. [pmid: 9442541].
108 Kneen R, Jakka S, Mithyantha R, et al. The management of infants and children treated with aciclovir for suspected viral encephalitis. Arch Dis Child. 2010;95(2):100-6. [pmid: 19457882].
109 Berkowitz CD, Uchiyama N, Tully SB, et al. Fever in infants less than two months of age: spectrum of disease and predictors of outcome. Pediatr Emerg Care. Sep. 1985;1(3):128-35. [pmid: 3842882].
110 Bilavsky E, Shouval DS, Yarden-Bilavsky H, et al. Are grunting respirations a sign of serious bacterial infection in children?. Acta Paediatr. Aug. 2008;97(8):1086-9. [pmid: 18460043].
111 Bonsu BK, Chb M, Harper MB. Identifying febrile young infants with bacteremia: is the peripheral white blood cell count an accurate screen?. Ann Emerg Med. Aug. 2003;42(2):216-25. [pmid: 12883509].
112 Bonadio WA. Incidence of serious infections in afebrile neonates with a history of fever. Pediatr Infect Dis J. Oct. 1987;6(10):911-4. [pmid: 3696822].
113 Rudinsky SL, Carstairs KL, Reardon JM, et al. Serious bacterial infections in febrile infants in the post-pneumococcal conjugate vaccine era. Acad Emerg Med. Jul. 2009;16(7):585-90. [pmid: 19538500].
114 Bonadio WA. Urine culturing technique in febrile infants. Pediatr Emerg Care. Jun. 1987;3(2):75-8. [pmid: 3615238].
115 DeAngelis C, Joffe A, Wilson M, et al. Iatrogenic risks and financial costs of hospitalizing febrile infants. Am J Dis Child. Dec. 1983;137(12):1146-9. [pmid: 6416058].
116 Ferguson C, Roosevelt G, Bajaj L. Practice patterns in the evaluation of febrile infants (30-90 days) with fever during wintertime. Pediatric Academic Societies' Annual Meeting. 2007 May 05. 2008.
117 Grover G, Berkowitz CD, Lewis RJ. The clinical utility of the rectal-skin temperature difference in the assessment of young infants. Acad Emerg Med. 1999;6(9):900-5. [pmid: 10490251].
118 Hsiao AL, Chen L, Baker MD. Incidence and predictors of serious bacterial infections among 57- to 180-day-old infants. Pediatrics. May. 2006;117(5):1695-701. [pmid: 16651326].
119 Kuppermann N, Walton EA. Immature neutrophils in the blood smears of young febrile children. Arch Pediatr Adolesc Med. Mar. 1999;153(3):261-6. [pmid: 10086403].
120 Cohen AL, Rivara FP, Davis R, et al. Compliance with guidelines for the medical care of first urinary tract infections in infants: a population-based study. Pediatrics. Jun. 2005;115(6):1474-8. [pmid: 15930206].
121 Crane JD, Benjamin JT. Pediatric residents' telephone triage experience: do parents really follow telephone advice?. Arch Pediatr Adolesc Med. Jan. 2000;154(1):71-4. [pmid: 10632254].
122 Baker MD, Monroe KW, King WD, et al. Effectiveness of fever education in a pediatric emergency department. Pediatr Emerg Care. Sep. 2009;25(9):565-8. [pmid: 19755888].
123 Sarrell M, Kahan E. Impact of a single-session education program on parental knowledge of and approach to childhood fever. Patient Educ Couns. Sep. 2003;51(1):59-63. [pmid: 12915281].
124 O'Neill-Murphy K, Liebman M, Barnsteiner JH. Fever education: does it reduce parent fever anxiety?. Pediatr Emerg Care. Feb. 2001;17(1):47-51. [pmid: 11265909].
125 Hemphill RR, Santen SA, Howell JM, et al. Follow-up compliance in febrile children: a comparison of two systems. Acad Emerg Med. Oct. 1998;5(10):996-1001. [pmid: 9862592].
126 Gauthier M, Chevalier I, Sterescu A, et al. Treatment of urinary tract infections among febrile young children with daily intravenous antibiotic therapy at a day treatment center. Pediatrics. 2004;114(4):e469-e476. [pmid: 15466073].
127 Baker RC, Schubert CJ, Kirwan KA, et al. After-hours telephone triage and advice in private and nonprivate pediatric populations. Arch Pediatr Adolesc Med. Mar. 1999;153(3):292-6. [pmid: 10086408].
128 Vidwan G, Geis GL. Evaluation, management, and outcome of focal bacterial infections (FBIs) in nontoxic infants under two months of age. J Hosp Med. Feb. 2010;5(2):76-82. [pmid: 20104632].
129 Kimberlin DW, Lin CY, Jacobs RF, et al. Natural history of neonatal herpes simplex virus infections in the acyclovir era. Pediatrics. Aug. 2001;108(2):223-9. [pmid: 11483781].
130 Caviness C, Demmler C, Swint M, et al. Cost-effectiveness analysis of herpes simplex virus testing and treatment strategies in febrile neonates. [epub ahead of print]. Arch Pediatr Adolesc Med. 2008;162(7).
131 Mark KE, Kim HN, Wald A, et al. Targeted prenatal herpes simplex virus testing: can we identify women at risk of transmission to the neonate?. Am J Obstet Gynecol. Feb. 2006;194(2):408-14. [pmid: 16458638].
132 Kimberlin DW. When should you initiate acyclovir therapy in a neonate?. J Pediatr. Aug. 2008;153(2):155-6. [pmid: 18639724].
133 Paxton RD, Byington CL. An examination of the unintended consequences of the rule-out sepsis evaluation: a parental perspective. Clin Pediatr (Phila). Feb. 2001;40(2):71-7. [pmid: 11261453].
134 Oray-Schrom P, Phoenix C, St M D, et al. Sepsis workup in febrile infants 0-90 days of age with respiratory syncytial virus infection. [Review] [25 refs]. Pediatr Emerg Care. Oct. 2003;19(5):314-9. [pmid: 14578830].
135 Liebelt EL, Qi K, Harvey K. Diagnostic testing for serious bacterial infections in infants aged 90 days or younger with bronchiolitis. Arch Pediatr Adolesc Med. May. 1999;153(5):525-30. [pmid: 10323635].
136 Antonow JA, Hansen K, McKinstry CA, et al. Sepsis evaluations in hospitalized infants with bronchiolitis. Pediatr Infect Dis J. Mar. 1998;17(3):231-6. [pmid: 9535251].
137 Hall CB, Powell KR, Schnabel KC, et al. Risk of secondary bacterial infection in infants hospitalized with respiratory syncytial viral infection. J Pediatr. Aug. 1988;113(2):266-71. [pmid: 3397789].
138 Sadow KB, Derr R, Teach SJ. Bacterial infections in infants 60 days and younger: epidemiology, resistance, and implications for treatment. Arch Pediatr Adolesc Med. Jun. 1999;153(6):611-4. [pmid: 10357302].
139 Brown JC, Burns JL, Cummings P. Ampicillin use in infant fever: a systematic review. Arch Pediatr Adolesc Med. Jan. 2002;156(1):27-32. [pmid: 11772187].