# Introduction

The febrile infant is a common problem that accounts for a large number of ambulatory care visits. Young infants (0 to 3 months of age) often present with nonspecific symptoms, and it is difficult to distinguish between infants with a viral syndrome and those with bacterial diseases. In the majority of cases febrile illness in infancy is secondary to viral infections and is self-limited. Although serious bacterial illness (SBI) is relatively uncommon, if it is not promptly diagnosed and treated, serious consequences may result. The clinical dilemma that practitioners face is how to avoid missing a case of serious bacterial illness versus how to avoid the risks and harms of investigating, observing, and potentially treating a febrile infant with no SBI.

## Definitions

Fever in an infant is usually defined as a rectal temperature >38 degrees Celsius.89 For infants <3 months old, this value is approximately two standard deviations above the mean. The majority of studies that focus on the febrile infant have used this definition.

A young infant is an infant less than 3 months old. Neonates are infants from birth to 28 days of age.90

The definitions of SBI vary across published literature. The identification of SBI typically includes the diagnoses of meningitis, bacteremia, and urinary tract infection. Some studies have also included pneumonia, bone and joint infections, skin and soft tissue infections, and bacterial enteritis in the definition.

Invasive herpes simplex virus (HSV) infections are grouped into meningoencephalitis, disseminated, or skin, eyes and mouth. There is some overlap in these presentations.

## Epidemiology

The prevalence of SBI in young infants with fever is about 8.0 percent overall and is higher in infants aged 0–28 days (9.0 percent–13.0 percent) than in infants aged 2- 3 months (7.1 percent) 11,12,22,23,27,49 The prevalence of SBI is highest in infants < 2 weeks old (25.0 percent). The most common SBI is urinary tract infection, which is found in 3.0–11.0 percent of febrile infants in various reports.85,91,92

In the first month of life, the predominant bacterial infections involved are those acquired from the birth canal. The most common are Group B Streptococcus and Escherichia coli, with Staphylococcus aureus, Listeria monocytogenes and other Gram-negative enteric bacteria occurring less commonly. These organisms remain the common bacterial pathogens for the infant 1–3 months of age, but other organisms such as Streptococcus pneumoniae and Neisseria meningitidis may be seen in these older infants. Haemophilus influenzae type b infection is now uncommon due to widespread immunization. Escherichia coli is the most frequent pathogen in urinary tract infections. Salmonella spp. and Shigella spp. are the common causes of bacterial enteritis. In the past few years, the widespread use of intrapartum antibiotics prophylaxis led to decreased prevalence of Group B Streptococcal infections.93

The HSV infections are a major cause of morbidity and mortality among neonates with a case fatality rate of 15.5 percent.94 The prevalence of neonatal HSV infection has been reported to be between 25 and 50 per 100,000 live births in the United States.2 The prevalence of HSV infection in a febrile neonate is 0.3 percent, which is similar to that of bacterial meningitis in this age group.3 95 The HSV is transmitted to the newborn infant at the time of delivery and symptoms usually develop within the first 2 weeks of life. The risk of transmission is highest if the mother has primary disease, however the majority of women are asymptomatic at the time of delivery. Other risk factors include vaginal delivery, prolonged rupture of membranes, and the use of fetal scalp monitors. The HSV type 1 and type 2 are causes of disease in 30.0 percent and 70.0 percent of the infants, respectively.95

## Clinical Assessment

The history and physical examination is the first step in the evaluation of the febrile infant. The initial clinical assessment of the infant involves deciding if the child appears unwell or “toxic.” The clinical features that define toxicity include irritability, lethargy, and decreased social interaction. There may be signs of compromised circulation with poor perfusion and cyanosis or respiratory distress.

The clinical diagnosis of SBI in young infants is difficult; infants at this age may have SBI in the absence of signs of toxicity. There is a limited range of behavior in the young infant and signs of serious bacterial infection may be subtle. In addition, in the young infant with meningitis, there are often nonspecific symptoms with no meningeal signs.

Several studies have used observation scales to help predict SBI. In young infants, clinical observation scales have low sensitivity for the diagnosis of SBI. Although clinical assessment cannot adequately predict SBI, it may help define a group of infants who are at low risk for SBI due to their high sensitivity in identifying SBI.4-7

There are several published protocols which combine clinical and laboratory criteria in an attempt to identify young infants at low risk of SBI who can be safely managed as outpatients. Laboratory testing includes blood testing with white blood cell count, absolute band count or band to neutrophil ratio and blood culture. Urine testing is performed by catheterization or suprapubic aspiration with urinalysis and urine culture obtained. If the infant has diarrhea, stool microscopic testing and cultures are added. Some of the protocols include cerebrospinal fluid testing. Although this is the only test that will diagnose meningitis, lumbar puncture is the most invasive test.

The most commonly used criteria in practice are the Rochester criteria. Two modified versions of the Rochester criteria have been subsequently developed with the addition of either stool white blood cell (in presence of diarrhea) or normal inflammatory markers (erythrocyte sedimentation rate or C-reactive protein levels).96 The Rochester criteria aims to identify a low-risk group of infants who are well appearing, previously healthy, with no evidence of bacterial illness on examination, and with normal laboratory testing. In the Rochester criteria, if the infant is considered low risk, no lumbar puncture is performed and antibiotics are not routinely used.

Other commonly used low risk criteria are the Boston criteria 8 and the Philadelphia protocol (original and modified versions).9,96 For these criteria, all infants require to have an analysis of cerebrospinal fluid as part of the laboratory criteria. Low risk infants identified with these criteria receive intramuscular ceftriaxone and are treated as outpatients. Other criteria- the Milwaukee 10 also include lumbar puncture as part of the assessment but no antibiotics are given. See Appendix F.

The use of above-mentioned criteria are recommended for different age groups of infants (Philadelphia: 29–60 days; Rochester: 60 days or younger; Boston: 28–89 days).25

Infants who present with a recognizable viral illness or who have a confirmed viral infection by laboratory testing may have a different rate of serious bacterial illness than those with no viral symptoms. The various low risk protocols do not include viral testing in the assessment of the febrile infant.

Large studies have not been performed on the diagnostic accuracy of clinical assessment for invasive HSV infection in an infant who presents with fever. The literature has been focused on patients with confirmed infections, thereby not allowing better understanding of the diagnostic accuracy of clinical and/or laboratory assessments.

## Historical Context and Current Practice

As techniques for administering antibiotics to infants and for culturing bacteria from clinical specimens improved during the 1950s to 1970s, it became orthodox pediatric practice that all febrile infants <3 months of age undergo a complete evaluation for sepsis, including lumbar puncture, be admitted to hospital, and receive intravenous antibiotics for at least 48 hours as a precaution pending culture results.15 The rationale for this approach is based on the high prevalence of SBI in this group and the difficulty with the clinical assessment for sepsis in the young infant where clinical signs of sepsis are often subtle.4 Although this conservative approach minimizes the risk of infectious complications, it leads to unnecessary hospitalization and treatment, with potential for iatrogenic harm to many infants. In recent decades increasing awareness of these trade-offs has led to efforts to discriminate better which young infants with fever might really need more versus less intensive management. Technical advances have been part of the impetus. For example, with the availability of longer-acting antibiotics that can be administered intramuscularly (e.g., ceftriaxone in the 1980s) and newer diagnostic tests that do not require 48-hour incubation, the reasons for the “rule-out sepsis” hospitalization may seem less compelling, and practice patterns may have evolved.

In the well appearing infant with no clear source of infection, the current approach is to use a combination of clinical and laboratory criteria to decide which infants are likely at low risk for infection and can be managed as outpatients with or without antibiotics. With this approach there will be a small number of infants classified as low risk but who would subsequently be found to have serious bacterial illness. The delay in diagnosis and treatment may be potentially harmful for these infants.

The recommended management of febrile neonates, infants under 28 days of age, is controversial. Given that the overall prevalence of SBI is higher in the neonate, most experts would advocate for a full sepsis evaluation and hospitalization.14,15 There are studies that have attempted to apply low risk criteria in infants less than 1 month of age but because of the higher baseline rates of serious bacterial illness in the neonate the overall rates of SBI in the low risk group are higher than in older infants. 10,16,17

Regardless of guidelines or published protocols, a considerable number of clinicians do not adhere to them and manage the patient based on their own clinical judgment.5,76,97,98 Many infants are managed by community pediatricians and are not seen in the emergency department where most of the studies are based. It is not clear if infants seen in the emergency department have a different risk of infection than those managed in the office. In the community practice setting, clinicians who are familiar with the families may be better able to predict the parents who are likely to comply with followup instructions.

The current recommendations for the evaluation and management of the young febrile infant are based on studies conducted in the late 1980's and early 1990's. An up to date systematic review of the diagnostic tests and harms of the management strategies for febrile infants is warranted. This evidence report is designed to review the literature to answer Key Questions about the management of the febrile infant and to identify needs for future research.