# Peer Reviewers

Carrie Byington, M.D.

Department of Pediatrics

University of Utah Health Sciences Center

Salt Lake City, UT

Robert Pantell, M.D.

Department of Pediatrics

University of California, San Francisco

San Francisco, CA

Charles Woods, M.D., M.S.

Department of Pediatrics

University of Louisville

Louisville, KY

Thomas Newman, M.D., M.P.H.

Department of Epidemiology & Biostatistics

University of California, San Francisco

San Francisco, CA

Paul Young, M.D.

Department of Pediatrics

University of Utah Health Sciences Center

Salt Lake City, UT

Louis Bell, M.D.

Department of Pediatrics

University of Pennsylvania

Philadelphia, PA