# Technical Expert Panel

Carrie Byington, M.D.

Department of Pediatrics

University of Utah Health Sciences Center

Salt Lake City, UT

Terry Klassen M.D., MSc.

Department of Pediatrics

University of Alberta

Edmonton, Alberta, Canada

Nathan Kuppermann, M.D., M.P.H.

Department of Emergency Medicine

University of California, Davis

Sacramento, CA

Robert Pantell, M.D.

Department of Pediatrics

University of California, San Francisco

San Francisco, CA

Charles Woods, M.D., M.S.

Department of Pediatrics

University of Louisville

Louisville, KY