# Appendixes

Appendix A Search Strategies

Appendix B Data Extraction Forms

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Quality Assessment Forms

Appendix F Protocols and Criteria

Appendix G Quality Assessment of Included Studies