# Quality Assessment of Included Studies

Appendix G lists all of the questions and answers and tabulated total score for each included study using the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) tool.

Table 1 Quality assessment on all QUADAS questions for each included study

Study ID | Q1. Spectrum of patients | Q2. Selection criteria | Q3. Ref stand & index test length of time | Q4. Ref stand vs. index test period of time | Q5. Reference standard? | Q6. Same ref. standard? | Q7. Ref. stand independent of index test | Q8. Details of index test described | Q9. Replication | Q10. Index test interpreted without knowledge of RS | Q11. Ref. stand interpreted without knowledge of RS | Q12. Same Clinical Data Available | Q13. Uninterpretable Test Results Reported | Q14. Withdrawals Explained | Total Score
Andreola B, (2007)25 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Not clear | Yes | 12
Bachur R, (2001) 36 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Not clear | Not clear | Yes | Not clear | Not clear | 8
Bachur RG, (2001)1 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | 12
Baker MD, (1990)54 | Yes | no | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | No | no | 8
Baker MD, (1993)55 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | Yes | 11
Baker MD, (1999)56 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | 13
Baker MD, (1999)57 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 14
Baskin (1992)58 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | Yes | 11
Berkowitz CD, (1985)37 | Not clear | Yes | Not clear | Not clear | No | Not clear | Not clear | No | Yes | Not clear | Not clear | Yes | Not clear | Not clear | 3
Bilavsky E, (2008)15 | Not clear | Not clear | Yes | Not clear | Not clear | Yes | Not clear | No | No | Not clear | Yes | Not clear | No | No | 3
Bilavsky E, (2009)26 | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | No | Not clear | 8
Bilavsky E, (2010)38 | Yes | Yes | Yes | Not clear | No | Yes | Yes | Yes | Not clear | Not clear | Not clear | Yes | Yes | Yes | 9
Bilavsky E, (2008)74 | Not clear | Yes | Not clear | Not clear | Yes | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Yes | 3
Bonadio WA, (1991)16 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | Yes | Not clear | Yes | 12
Bonadio WA, (1992)40 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | Not clear | Not clear | 10
Bonadio WA, (1993)60 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | 13
Bonadio WA, (1994)17 | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | Not clear | Not clear | 9
Bonadio WA. (1987)39 | Yes | Yes | Not clear | Not clear | Yes | Yes | Not clear | No | Yes | Not clear | Not clear | Yes | Not clear | Yes | 7
Bonsu BK, (2003)41 | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Not clear | Not clear | Yes | Not clear | Yes | 9
Bonsu BK, (2007)42 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Not clear | Not clear | 11
Bressan S, (2010)43 | No | Yes | Yes | Not clear | No | Yes | Yes | Yes | Yes | Not clear | Not clear | Not clear | No | Yes | 7
Brik R, (1997)61 | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | 12
Broner CW, (1990)2 | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Not clear | Yes | Not clear | Not clear | 9
Brown L, (2005)44 | Not clear | Not clear | Yes | Not clear | No | Not clear | Not clear | No | No | Not clear | Not clear | Yes | Not clear | Yes | 3
Byington CL, (1999)75 | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | Yes | Not clear | Yes | Not clear | Yes | 8
Byington CL, (2004)62 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Not clear | Yes | Not clear | No | 9
Caspe WB, (1983)3 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Not clear | Yes | Not clear | Yes | 11
Caviness AC, (2008)45 | Yes | Yes | Yes | Not clear | No | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | No | no | 8
Chen C-J, (2009)81 | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | Not clear | Not clear | No | Not clear | 6
Chiu CH, (1994)82 | No | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Not clear | Not clear | Not clear | Yes | Yes | 9
Chiu CH, (1997)63 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | Yes | 12
Condra CS, (2010)4 | No | Yes | Yes | Not clear | No | Yes | Yes | Yes | Yes | Not clear | Not clear | No | No | Yes | 7
Crain EF, (1982)19 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | Not clear | 11
Crain EF, (1988)5 | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | Not clear | Not clear | 9
Crain EF, (1990)6 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | 12
Dagan R, (1985)7 | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | No | No | Not clear | Not clear | Yes | Not clear | Not clear | 6
Dagan R, (1988)8 | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | Yes | 11
Dayan PS, (2002)46 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Not clear | Yes | Yes | No | Yes | 11
Ferrera PC, (1997)64 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | Yes | 12
Garra G, (2005)65 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | No | 12
Gomez B, (2010)9 | Yes | Yes | Yes | Not clear | No | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | No | Yes | 9
Herr SM, (2001)10 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | 13
Hoberman A, (1993)47 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | Not clear | Yes | 11
Hsiao AL,(2006)32 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | No | Yes | 12
Jaskiewicz JA, (1994)66 | Not clear | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | Yes | Yes | 10
Jordan I, (2009)71 | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | Not clear | No | Not clear | Not clear | Yes | No | Not clear | 6
Kadish HA, (2000)67 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Not clear | Yes | 12
Kaplan RL, (2000) 68 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | 13
King JC, Jr., (1987)20 | Not clear | Yes | Not clear | Yes | Yes | Yes | No | Yes | No | Not clear | Not clear | Yes | Not clear | Not clear | 6
Kuppermann N, (1997)76 | Yes | Yes | Yes | Not clear | Yes | Not clear | Not clear | No | Yes | Not clear | Not clear | Yes | Not clear | Yes | 7
Levine DA, (2004)83 | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | No | Yes | 11
Lin DS, (2000) 48 | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Not clear | Not clear | Yes | Not clear | Yes | 10
Maniaci V, (2008)49 | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | No | Yes | 11
Marom R, (2007)11 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | Not clear | Yes | 10
McCarthy CA, (1990)72 | no | Yes | Not clear | Not clear | Not clear | v | Yes | Yes | no | Not clear | Not clear | Yes | no | no | 5
Meehan WP, (2008)51 | Yes | Yes | Yes | Not clear | No | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | No | Yes | 9
Mintegi S, (2009)21 | Not clear | Not clear | Not clear | Not clear | No | Not clear | Not clear | Yes | No | Not clear | Not clear | Yes | No | Yes | 3
Olaciregui E, I, (2009)52 | Yes | Yes | Yes | Not clear | No | Yes | Yes | Yes | Yes | Not clear | Yes | Yes | No | Yes | 10
Pantell RH, (2004)12 | Yes | Yes | Yes | Not clear | Yes | Not clear | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | Yes | 10
Reardon JM, (2009)53 | Not clear | No | Yes | Not clear | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Not clear | 8
Rittichier KR, (2005)77 | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Not clear | Not clear | 8
Rosenberg N, (1985)22 | Not clear | Yes | Yes | Yes | Yes | No | No | Yes | No | Not clear | Not clear | Yes | Not clear | Not clear | 6
Rudinsky SL, (2009)35 | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | No | No | 8
Schwartz S, (2009)13 | Yes | Yes | Yes | Not clear | No | Yes | Yes | Yes | Yes | No | Not clear | Yes | No | Yes | 9
Shin SH, (2009)84 | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | Yes | Not clear | No | Not clear | 7
Smitherman HF, (2005)78 | No | Yes | Yes | Yes | Yes | Yes | Not clear | No | Yes | Not clear | Not clear | Yes | Not clear | Yes | 8
Stanley R, (2005)23 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | Yes | Yes | Yes | 13
Titus MO, (2003)79 | No | Yes | Yes | Yes | Yes | Yes | Not clear | No | Yes | Not clear | Not clear | Yes | Not clear | No | 7
Wasserman GM, (1990)14 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 14
Watt K, (2010)73 | Yes | Yes | Yes | Not clear | Yes | Not clear | Yes | Yes | Yes | Not clear | Yes | Yes | No | No | 9
Wolff M, (2009)24 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Not clear | Not clear | No | Yes | 10

## References

1 Bachur RG, Harper MB. Predictive model for serious bacterial infections among infants younger than 3 months of age. Pediatrics. Aug. 2001;108(2):311-6. [pmid: 11483793].
2 Broner CW, Polk SA, Sherman JM. Febrile infants less than eight weeks old. Predictors of infection. Clin Pediatr (Phila). Aug. 1990;29(8):438-43. [pmid: 2208902].
3 Caspe WB, Chamudes O, Louie B. The evaluation and treatment of the febrile infant. Pediatr Infect Dis. Mar. 1983;2(2):131-5. [pmid: 6856491].
4 Condra CS, Parbhu B, Lorenz D, et al. Charges and complications associated with the medical evaluation of febrile young infants. Pediatr Emerg Care. 2010;26(3):186-91. [pmid: 20179660].
5 Crain EF, Gershel JC. Which febrile infants younger than two weeks of age are likely to have sepsis? A pilot study. Pediatr Infect Dis J. Aug. 1988;7(8):561-4. [pmid: 3174300].
6 Crain EF, Gershel JC. Urinary tract infections in febrile infants younger than 8 weeks of age. [see comment]. Pediatrics. Sep. 1990;86(3):363-7. [pmid: 2388785].
7 Dagan R, Powell KR, Hall CB, et al. Identification of infants unlikely to have serious bacterial infection although hospitalized for suspected sepsis. J Pediatr. Dec. 1985;107(6):855-60. [pmid: 4067741].
8 Dagan R, Sofer S, Phillip M, et al. Ambulatory care of febrile infants younger than 2 months of age classified as being at low risk for having serious bacterial infections. J Pediatr. Mar. 1988;112(3):355-60. [pmid: 3346773].
9 Gomez B, Mintegi S, Benito J, et al. Blood culture and bacteremia predictors in infants less than three months of age with fever without source. Pediatr Infect Dis J. Jan. 2010;29(1):43-7. [pmid: 19934784].
10 Herr SM, Wald ER, Pitetti RD, et al. Enhanced urinalysis improves identification of febrile infants ages 60 days and younger at low risk for serious bacterial illness. [see comment]. Pediatrics. Oct. 2001;108(4):866-71. [pmid: 11581437].
11 Marom R, Sakran W, Antonelli J, et al. Quick identification of febrile neonates with low risk for serious bacterial infection: an observational study. [see comment]. Arch Dis Child Fetal Neonatal Ed. Jan. 2007;92(1):F15-F18. [pmid: 17185424].
12 Pantell RH, Newman TB, Bernzweig J, et al. Management and outcomes of care of fever in early infancy. JAMA. Mar. 10. 2004;291(10):1203-12. [pmid: 15010441].
13 Schwartz S, Raveh D, Toker O, et al. A week-by-week analysis of the low-risk criteria for serious bacterial infection in febrile neonates. Arch Dis Child. Apr. 2009;94(4):287-92. [pmid: 18977786].
14 Wasserman GM, White CB. Evaluation of the necessity for hospitalization of the febrile infant less than three months of age. Pediatr Infect Dis J. Mar. 1990;9(3):163-9. [pmid: 2336297].
15 Bilavsky E, Shouval DS, Yarden-Bilavsky H, et al. Are grunting respirations a sign of serious bacterial infection in children?. Acta Paediatr. Aug. 2008;97(8):1086-9. [pmid: 18460043].
16 Bonadio WA, McElroy K, Jacoby PL, et al. Relationship of fever magnitude to rate of serious bacterial infections in infants aged 4-8 weeks. Clin Pediatr (Phila). Aug. 1991;30(8):478-80. [pmid: 1914347].
17 Bonadio WA, Smith DS, Sabnis S. The clinical characteristics and infectious outcomes of febrile infants aged 8 to 12 weeks. Clin Pediatr (Phila). Feb. 1994;33(2):95-9. [pmid: 8200162].
18 Chen HL, Hung CH, Tseng HI, et al. Soluble form of triggering receptor expressed on myeloid cells-1 (sTREM-1) as a diagnostic marker of serious bacterial infection in febrile infants less than three months of age. Jpn J Infect Dis. Jan. 2008;61(1):31-5. [pmid: 18219131].
19 Crain EF, Shelov SP. Febrile infants: predictors of bacteremia. J Pediatr. Nov. 1982;101(5):686-9. [pmid: 7131141].
20 King JC Jr., Berman ED, Wright PF. Evaluation of fever in infants less than 8 weeks old. South Med J. Aug. 1987;80(8):948-52. [pmid: 3303362].
21 Mintegi S, Garcia-Garcia JJ, Benito J, et al. Rapid influenza test in young febrile infants for the identification of low-risk patients. Pediatr Infect Dis J. Nov. 2009;28(11):1026-8. [pmid: 19654567].
22 Rosenberg N, Vranesich P, Cohen S. Incidence of serious infection in infants under age two months with fever. Pediatr Emerg Care. Jun. 1985;1(2):54-6. [pmid: 3843433].
23 Stanley R, Pagon Z, Bachur R. Hyperpyrexia among infants younger than 3 months. Pediatr Emerg Care. May. 2005;21(5):291-4. [pmid: 15874809].
24 Wolff M, Bachur R. Serious bacterial infection in recently immunized young febrile infants. Acad Emerg Med. Dec. 2009;16(12):1284-9. [pmid: 20053249].
25 Andreola B, Bressan S, Callegaro S, et al. Procalcitonin and C-reactive protein as diagnostic markers of severe bacterial infections in febrile infants and children in the emergency department. Pediatr Infect Dis J. Aug. 2007;26(8):672-7. [pmid: 17848876].
26 Bilavsky E, Yarden-Bilavsky H, Ashkenazi S, et al. C-reactive protein as a marker of serious bacterial infections in hospitalized febrile infants. Acta Paediatr. 2009;98(11):1776-80. [pmid: 19664100].
27 Bonadio WA. Urine culturing technique in febrile infants. Pediatr Emerg Care. Jun. 1987;3(2):75-8. [pmid: 3615238].
28 DeAngelis C, Joffe A, Wilson M, et al. Iatrogenic risks and financial costs of hospitalizing febrile infants. Am J Dis Child. Dec. 1983;137(12):1146-9. [pmid: 6416058].
29 Ferguson C, Roosevelt G, Bajaj L. Practice patterns in the evaluation of febrile infants (30-90 days) with fever during wintertime. Pediatric Academic Societies' Annual Meeting. 2007 May 05. 2008.
30 Filippine MM, Katz BZ. Neonatal herpes simplex virus infection presenting with fever alone. J Hum Virol. Jul. 2001;4(4):223-5. [pmid: 11694851].
31 Grover G, Berkowitz CD, Lewis RJ. The clinical utility of the rectal-skin temperature difference in the assessment of young infants. Acad Emerg Med. 1999;6(9):900-5. [pmid: 10490251].
32 Hsiao AL, Chen L, Baker MD. Incidence and predictors of serious bacterial infections among 57- to 180-day-old infants. Pediatrics. May. 2006;117(5):1695-701. [pmid: 16651326].
33 Kuppermann N, Walton EA. Immature neutrophils in the blood smears of young febrile children. Arch Pediatr Adolesc Med. Mar. 1999;153(3):261-6. [pmid: 10086403].
34 Mintegi S, Benito J, Astobiza E, et al. Well appearing young infants with fever without known source in the Emergency Department: Are lumbar punctures always necessary?. Eur J Emerg Med. 2010;17(3):167-9. [pmid: 19820403].
35 Rudinsky SL, Carstairs KL, Reardon JM, et al. Serious bacterial infections in febrile infants in the post-pneumococcal conjugate vaccine era. Acad Emerg Med. Jul. 2009;16(7):585-90. [pmid: 19538500].
36 Bachur R, Harper MB. Reliability of the urinalysis for predicting urinary tract infections in young febrile children. Arch Pediatr Adolesc Med. Jan. 2001;155(1):60-5. [pmid: 11177064].
37 Berkowitz CD, Uchiyama N, Tully SB, et al. Fever in infants less than two months of age: spectrum of disease and predictors of outcome. Pediatr Emerg Care. Sep. 1985;1(3):128-35. [pmid: 3842882].
38 Bilavsky E, Yarden-Bilavsky H, Amir J, et al. Should complete blood count be part of the evaluation of febrile infants aged <=2 months?. Acta Paediatr. 2010;99(9):1380-4. [pmid: 20367618].
39 Bonadio WA. Incidence of serious infections in afebrile neonates with a history of fever. Pediatr Infect Dis J. Oct. 1987;6(10):911-4. [pmid: 3696822].
40 Bonadio WA, Smith D, Carmody J. Correlating CBC profile and infectious outcome. A study of febrile infants evaluated for sepsis. [Review] [10 refs]. Clin Pediatr (Phila). Oct. 1992;31(10):578-82. [pmid: 1395363].
41 Bonsu BK, Chb M, Harper MB. Identifying febrile young infants with bacteremia: is the peripheral white blood cell count an accurate screen?. Ann Emerg Med. Aug. 2003;42(2):216-25. [pmid: 12883509].
42 Bonsu BK, Harper MB. Leukocyte counts in urine reflect the risk of concomitant sepsis in bacteriuric infants: a retrospective cohort study. BMC Pediatr. 2007;7:24. [pmid: 17567901].
43 Bressan S, Andreola B, Cattelan F, et al. Predicting severe bacterial infections in well-appearing febrile neonates: Laboratory markers accuracy and duration of fever. Pediatr Infect Dis J. 2010;29(3):227-32. [pmid: 19949364].
44 Brown L, Shaw T, Wittlake WA. Does leucocytosis identify bacterial infections in febrile neonates presenting to the emergency department?. Emerg Med J. Apr. 2005;22(4):256-9. [pmid: 15788823].
45 Caviness AC, Demmler GJ, Almendarez Y, et al. The prevalence of neonatal herpes simplex virus infection compared with serious bacterial illness in hospitalized neonates. J Pediatr. Aug. 2008;153(2):164-9. [pmid: 18534225].
46 Dayan PS, Bennett J, Best R, et al. Test characteristics of the urine Gram stain in infants <or= 60 days of age with fever. Pediatr Emerg Care. Feb. 2002;18(1):12-4. [pmid: 11862130].
47 Hoberman A, Chao HP, Keller DM, et al. Prevalence of urinary tract infection in febrile infants. J Pediatr. Jul. 1993;123(1):17-23. [pmid: 8320616].
48 Lin DS, Huang SH, Lin CC, et al. Urinary tract infection in febrile infants younger than eight weeks of Age. Pediatrics. Feb. 2000;105(2):E20. [pmid: 10654980].
49 Maniaci V, Dauber A, Weiss S, et al. Procalcitonin in young febrile infants for the detection of serious bacterial infections. Pediatrics. Oct. 2008;122(4):701-10. [pmid: 18829791].
50 Dauber A, Weiss S, Maniaci V, et al. Procalcitonin levels in febrile infants after recent immunization. Pediatrics. Nov. 2008;122(5):e1119-e1122. [pmid: 18977961].
51 Meehan WP III, Bachur RG. Predictors of cerebrospinal fluid pleocytosis in febrile infants aged 0 to 90 days. Pediatr Emerg Care. May. 2008;(5):287-93. [pmid: 18496111].
52 Olaciregui EI, Hernandez U, Munoz JA, et al. Markers that predict serious bacterial infection in infants under 3 months of age presenting with fever of unknown origin. Arch Dis Child. 2009;94(7):501-5. [pmid: 19158133].
53 Reardon JM, Carstairs KL, Rudinsky SL, et al. Urinalysis is not reliable to detect a urinary tract infection in febrile infants presenting to the ED. Am J Emerg Med. 2009;27(8):930-2. [pmid: 19857409].
54 Baker MD, Avner JR, Bell LM. Failure of infant observation scales in detecting serious illness in febrile, 4- to 8-week-old infants. Pediatrics. Jun. 1990;85(6):1040-3. [pmid: 2339027].
55 Baker MD, Bell LM, Avner JR. Outpatient management without antibiotics of fever in selected infants. N Engl J Med. Nov. 11. 1993;329(20):1437-41. [pmid: 8413453].
56 Baker MD, Bell LM. Unpredictability of serious bacterial illness in febrile infants from birth to 1 month of age. Arch Pediatr Adolesc Med. May. 1999;153(5):508-11. [pmid: 10323632].
57 Baker MD, Bell LM, Avner JR. The efficacy of routine outpatient management without antibiotics of fever in selected infants. Pediatrics. Mar. 1999;103(3):627-31. [pmid: 10049967].
58 Baskin MN, O'Rourke EJ, Fleisher GR. Outpatient treatment of febrile infants 28 to 89 days of age with intramuscular administration of ceftriaxone. J Pediatr. Jan. 1992;120(1):22-7. [pmid: 1731019].
59 Bonadio WA, Hennes H, Smith D, et al. Reliability of observation variables in distinguishing infectious outcome of febrile young infants. Pediatr Infect Dis J. Feb. 1993;12(2):111-4. [pmid: 8426766].
60 Bonadio WA, Hagen E, Rucka J, et al. Efficacy of a protocol to distinguish risk of serious bacterial infection in the outpatient evaluation of febrile young infants. Clin Pediatr (Phila). Jul. 1993;32(7):401-4. [pmid: 8365074].
61 Brik R, Hamissah R, Shehada N, et al. Evaluation of febrile infants under 3 months of age: is routine lumbar puncture warranted?. Isr J Med Sci. Feb. 1997;33(2):93-7. [pmid: 9254869].
62 Byington CL, Enriquez FR, Hoff C, et al. Serious bacterial infections in febrile infants 1 to 90 days old with and without viral infections. Pediatrics. Jun. 2004;113(6 Part 1):1662-6. [pmid: 15173488].
63 Chiu CH, Lin TY, Bullard MJ. Identification of febrile neonates unlikely to have bacterial infections. Pediatr Infect Dis J. Jan. 1997;16(1):59-63. [pmid: 9002103].
64 Ferrera PC, Bartfield JM, Snyder HS. Neonatal fever: utility of the Rochester criteria in determining low risk for serious bacterial infections. Am J Emerg Med. May. 1997;15(3):299-302. [pmid: 9148992].
65 Garra G, Cunningham SJ, Crain EF. Reappraisal of criteria used to predict serious bacterial illness in febrile infants less than 8 weeks of age. Acad Emerg Med. Oct. 2005;12(10):921-5. [pmid: 16204135].
66 Jaskiewicz JA, McCarthy CA, Richardson AC, et al. Febrile infants at low risk for serious bacterial infection--an appraisal of the Rochester criteria and implications for management. Febrile Infant Collaborative Study Group. Pediatrics. Sep. 1994;94(3):390-6. [pmid: 8065869].
67 Kadish HA, Loveridge B, Tobey J, et al. Applying outpatient protocols in febrile infants 1-28 days of age: can the threshold be lowered?. Clin Pediatr (Phila). Feb. 2000;39(2):81-8. [pmid: 10696544].
68 Kaplan RL, Harper MB, Baskin MN, et al. Time to detection of positive cultures in 28- to 90-day-old febrile infants. Pediatrics. Dec. 2000;106(6):E74. [pmid: 11099617].
69 Zorc JJ, Levine DA, Platt SL, et al. Clinical and demographic factors associated with urinary tract infection in young febrile infants. Pediatrics. Sep. 2005;116(3):644-8. [pmid: 16140703].
70 Dore-Bergeron MJ, Gauthier M, Chevalier I, et al. Urinary tract infections in 1- to 3-month-old infants: ambulatory treatment with intravenous antibiotics. Pediatrics. Jul. 2009;124(1):16-22. [pmid: 19564278].
71 Jordan I, Esteva C, Esteban E, et al. Severe enterovirus disease in febrile neonates. Enferm Infecc Microbiol Clin. Aug. 2009;27(7):399-402. [pmid: 19409661].
72 McCarthy CA, Powell KR, Jaskiewicz JA, et al. Outpatient management of selected infants younger than two months of age evaluated for possible sepsis. Pediatr Infect Dis J. Jun. 1990;9(6):385-9. [pmid: 2367158].
73 Watt K, Waddle E, Jhaveri R. Changing epidemiology of serious bacterial infections in febrile infants without localizing signs. PLoS One. 2010;5(8):e12448. [pmid: 20805983].
74 Bilavsky E, Shouval DS, Yarden-Bilavsky H, et al. A prospective study of the risk for serious bacterial infections in hospitalized febrile infants with or without bronchiolitis. Pediatr Infect Dis J. Mar. 2008;27(3):269-70. [pmid: 18277919].
75 Byington CL, Taggart EW, Carroll KC, et al. A polymerase chain reaction-based epidemiologic investigation of the incidence of nonpolio enteroviral infections in febrile and afebrile infants 90 days and younger. Pediatrics. Mar. 1999;103(3):E27. [pmid: 10049983].
76 Kuppermann N, Bank DE, Walton EA, et al. Risks for bacteremia and urinary tract infections in young febrile children with bronchiolitis. Arch Pediatr Adolesc Med. Dec. 1997;151(12):1207-14. [pmid: 9412595].
77 Rittichier KR, Bryan PA, Bassett KE, et al. Diagnosis and outcomes of enterovirus infections in young infants. Pediatr Infect Dis J. Jun. 2005;24(6):546-50. [pmid: 15933567].
78 Smitherman HF, Caviness AC, Macias CG. Retrospective review of serious bacterial infections in infants who are 0 to 36 months of age and have influenza A infection. Pediatrics. Mar. 2005;115(3):710-8. [pmid: 15741376].
79 Titus MO, Wright SW. Prevalence of serious bacterial infections in febrile infants with respiratory syncytial virus infection. Pediatrics. Aug. 2003;112(2):282-4. [pmid: 12897274].
80 Collins KL. Ambulatory treatment of infants with presumed febrile urinary tract infection may be feasible. J Pediatr. 2010;156(1):166-7. [pmid: 20006777].
81 Chen CJ, Lo YF, Huang MC, et al. A model for predicting risk of serious bacterial infection in febrile infants younger than 3 months of age. J Chin Med Assoc. Oct. 2009;72(10):521-6. [pmid: 19837646].
82 Chiu CH, Lin TY, Bullard MJ. Application of criteria identifying febrile outpatient neonates at low risk for bacterial infections. Pediatr Infect Dis J. Nov. 1994;13(11):946-9. [pmid: 7845745].
83 Levine DA, Platt SL, Dayan PS, et al. Risk of serious bacterial infection in young febrile infants with respiratory syncytial virus infections. Pediatrics. Jun. 2004;113(6):1728-34. [pmid: 15173498].
84 Shin SH, Choi CW, Lee JA, et al. Risk factors for serious bacterial infection in febrile young infants in a community referral hospital. J Korean Med Sci. 2009;24(5):844-8. [pmid: 19794981].