# Protocols and Criteria

Appendix F lists less commonly used criteria (Yale, and Young Infant Observation Scales)

The Yale Observation Scale

Observation Variable | Normal (1) | Moderate Impairment (3) | Severe Impairment (5)
Quality of cry | Strong, normal tone or content, not crying | Whimpering, sobbing | Weak, moaning, high pitched
Reaction to Parents | Cries briefly, stops or content, not crying | Cries off and on | Continual cry or hardly responds
State Variation | If awake, stays awake If asleep, arouses easily | Eyes close briefly, awakes with prolonged stimulation | Falls to sleep, cannot be aroused
Color | Pink | Pale extremities Acrocyanosis | Pale, cyanotic mottled ,ashen
Hydration | Skin, eyes normal Mucous membranes moist | Skin, eyes normal Mouth slightly dry | Skin doughy, tented Mucous membranes dry, Sunken eyes
Response to Social Overtures | Smiles Becomes alert | Brief smile Alerts briefly | No smile, anxious, dull, expressionless Can't be alerted

McCarthy PL, Sharpe MR, Spiesel SZ, et al. Observation scales to identify serious illness in young children. Pediatrics 1982; 70: 802-809

The Young Infant Observation Scale

Affect | Smiles or not irritable (1) | Irritable, consolable (3) | Irritable, not consolable (5)
Respiratory status/effort | No impairment, vigorous (1) | Mild-moderate compromise (tachypnea, retractions, grunting) (3) | Respiratory distress or inadequate effort (apnea, resp failure) (5)
Peripheral perfusion | Pink, warm extremities (1) | Mottled, cool extremities (3) | Pale, shock (5)

Bonadio, W. A., Hennes, H., Smith, D., Ruffing, R., Melzer-Lange, M., Lye, P., and Isaacman, D., Reliability of observation variables in distinguishing infectious outcome of febrile young infants, Pediatric Infectious Disease Journal, 12(2), 1993, p.111 - 114