# Quality Assessment Forms

Appendix E lists the questions asked to conduct the quality assessment of the included studies using the QUADAS tool.

Quality Assessment of Diagnostic Accuracy Studies (QUADAS)