# Excluded Studies

Appendix D lists all of the studies that were excluded from this review, separated by the two main searches, and categorized by reason for exclusion and alphabetized.

## Key Questions 1–5

### Non-English publications

Bilavsky E, Singer-Harel D, Yarden-Bilavsky H, et al. Ill-appearing febrile 5-week-old infant: the rule of empiric treatment. Harefuah. 794. 148(11):759-60. 794. [pmid: 20027977].
Crouzet-Ozenda L, Haas H, Bingen E, et al. [Listeria monocytogenes meningitis in children in France]. [French]. Arch Pediatr. Dec. Suppl 3. 2008;15:S158-S160. [pmid: 19268247].
De LF. I. Procalcitonin and C-reactive protein as diagnostic markers of severe bacterial infections in febrile infants and children in the emergency department. Pediatria Integral. 2007;11(8):729-30.
Guesmi F, Zoghlami A, Sghaiier D, et al. Alimentary factors promoting colorectal cancer risk: A prospective epidemiologic study. Tunis Med. 2010;88(3):184-9. [pmid: 20415192].
Nouri-Merchaoui S, Methlouthi J, El GD, et al. Neonatal fever: Study of 134 cases at Sousse (Tunisia) neonatology department. Journal de Pediatrie et de Puericulture. 2009;22(4-5):182-92.
Pena DA, Viviani S, et al. Treatment of urinary tract infections in febrile infants: Experience of outpatient intravenous antibiotic treatment. Rev. 2009;26(4):350-4.
Tinsa F, El GA, Ncibi N, et al. Utility of lumbar puncture for febrile seizure among infant under oine year old. Tunis Med. 2010;88(3):178-83. [pmid: 20415191].

### Primary objective was not the diagnosis or the management of febrile infants aged 0–90 days

Adair CE, Kowalsky L, Quon H, et al. Risk factors for early-onset group B streptococcal disease in neonates: a population-based case-control study. CMAJ. Aug. 5. 2003;169(3):198-203. [pmid: 12900477].
Adams WG, Kinney JS, Schuchat A, et al. Outbreak of early onset group B streptococcal sepsis. Pediatr Infect Dis J. Jul. 1993;12(7):565-70. [pmid: 8345997].
Adcock PM, Paul RI, Marshall GS. Effect of urine latex agglutination tests on the treatment of children at risk for invasive bacterial infection. [see comment]. Pediatrics. Nov. 1995;96(5 Pt 1):951-4. [pmid: 7478842].
Adjei O, Opoku C. Urinary tract infections in African infants. Int J Antimicrob Agents. Sep. Suppl 1. 2004;24:S32-S34. [pmid: 15364303].
Afsharpaiman S, Mamishi S, Pourakbari B, et al. Diagnosis of bacteremia using universal pcr in febrile ill children. Acta Medica Iranica. 2007;45(2):131-8.
Ahmed A, Brito F, Goto C, et al. Clinical utility of the polymerase chain reaction for diagnosis of enteroviral meningitis in infancy. J Pediatr. Sep. 1997;131(3):393-7. [pmid: 9329415].
Alconcher LF, Meneguzzi MB, Buschiazzo R, et al. Could prophylactic antibiotics be stopped in patients with history of vesicoureteral reflux?. Journal of pediatric urology. 2009;5(5):383-8. Oct. [pmid: 19362059].
Al-Majali RM. White blood cell count, absolute neutrophil count, as predictors of hidden bacterial infections in febrile children 1-18 months of age without focus. Pakistan Journal of Medical Sciences. 2004;20(2):97-100.
Alpert G, Hibbert E, Fleisher GR. Case-control study of hyperpyrexia in children. Pediatr Infect Dis J. Mar. 1990;9(3):161-3. [pmid: 2336296].
Anand NK, Gupta AK, Mohan M, et al. Coagulase negative staphylococcal septicemia in newborns. Indian Pediatr. Nov. 1991;28(11):1241-8. [pmid: 1808044].
Andersen J, Christensen R, Hertel J. Clinical features and epidemiology of septicaemia and meningitis in neonates due to Streptococcus agalactiae in Copenhagen County, Denmark: a 10 year survey from 1992 to 2001. Acta Paediatr. Oct. 2004;93(10):1334-9. [pmid: 15499954].
Antonow JA, Hansen K, McKinstry CA, et al. Sepsis evaluations in hospitalized infants with bronchiolitis. Pediatr Infect Dis J. Mar. 1998;17(3):231-6. [pmid: 9535251].
Anttila M, Himberg JJ, Peltola H. Precise quantification of fever in childhood bacterial meningitis. Clin Pediatr (Phila). Apr. 1992;31(4):221-7. [pmid: 1563195].
Avner J, Crain E, Baker M. Failure to validate Rochester criteria for evaulation of febrile infants. Ambulatory Pediatric Association, 33rd annual meeting. 1993 Jun 04. 1993.
Bachur R, Harper MB. Reevaluation of outpatients with Streptococcus pneumoniae bacteremia. [see comment]. Pediatrics. Mar. 2000;105(3 Pt 1):502-9. [pmid: 10699100].
Bailis SA. More on procedures in the evaluation of the febrile pediatric patient. [comment]. Pediatr Ann. May. 1997;26(5):278. [pmid: 9150530].
Baker MD, Avner JR. The Febrile Infant: What's New?. Clinical Pediatric Emergency Medicine. 2008;9(4):213-20.
Baker RC, Seguin JH, Leslie N, et al. Fever and petechiae in children. Pediatrics. Dec. 1989;84(6):1051-5. [pmid: 2587134].
Baker RC, Tiller T, Bausher JC, et al. Severity of disease correlated with fever reduction in febrile infants. Pediatrics. Jun. 1989;83(6):1016-9. [pmid: 2786183].
Balter S, Zell ER, O'Brien KL, et al. Impact of intrapartum antibiotics on the care and evaluation of the neonate. Pediatr Infect Dis J. Oct. 2003;22(10):853-7. [pmid: 14551483].
Bandyopadhyay S, Bergholte J, Blackwell CD, et al. Risk of serious bacterial infection in children with fever without a source in the post-Haemophilus influenzae era when antibiotics are reserved for culture-proven bacteremia. [erratum appears in Arch Pediatr Adolesc Med 2002 Aug;156(8):749]. Arch Pediatr Adolesc Med. May. 2002;156(5):512-7. [pmid: 11980559].
Bang A, Chaturvedi P. Yale Observation Scale for prediction of bacteremia in febrile children. Indian Journal of Pediatrics. 2009;76(6):599-604. Jun. [pmid: 19390817].
Baraff LJ. Management of the febrile child: a survey of pediatric and emergency medicine residency directors. Pediatr Infect Dis J. Nov. 1991;10(11):795-800. [pmid: 1749690].
Barry H. What clinical variables predict the presence of a urinary tract infection in febrile young girls aged younger than 2 years?. Evid Based Pract. Jul. 2000;3(7):8. insert.
Bender JM, Ampofo K, Gesteland P, et al. Influenza virus infection in infants less than three months of age. Pediatr Infect Dis J. Jan. 2010;29(1):6-9. [pmid: 19915513].
Benito-Fernandez J, Mintegi-Raso S, Gonzalez-Balenciaga M, et al. Pneumococcal bacteremia among infants with fever without source before and after introduction of pnemococcal conjugate vaccine in Basque country (Spain). Pediatric Academic Societies' Annual Meeting. 2007 May 05. 2007.
Berger RM, Berger MY, van Steensel-Moll HA, et al. A predictive model to estimate the risk of serious bacterial infections in febrile infants. Eur J Pediatr. Jun. 1996;155(6):468-73. [pmid: 8789763].
Bergus G. Serious bacterial infection in children. J Fam Pract. Jun. 1997;44(6):531-2. [pmid: 9191620].
Berkley JA, Versteeg AC, Mwangi I, et al. Indicators of acute bacterial meningitis in children at a rural Kenyan district hospital. Pediatrics. Dec. 2004;114(6):e713-e719. [pmid: 15574603].
Bleeker SE, Moons KG, rksen-Lubsen G, et al. Predicting serious bacterial infection in young children with fever without apparent source. Acta Paediatr. Nov. 2001;90(11):1226-32. [pmid: 11808890].
Blumer J, Rodriguez A, Sanchez PJ, et al. Single-dose pharmacokinetics of famciclovir in infants and population pharmacokinetic analysis in infants and children. Antimicrob Agents Chemother. 2010;54(5):2032-41. [pmid: 20160046].
Bonadio WA, Bellomo T, Brady W, et al. Correlating changes in body temperature with infectious outcome in febrile children who receive acetaminophen. Clin Pediatr (Phila). Jun. 1993;32(6):343-6. [pmid: 8344044].
Bonadio WA. Bacteremia in febrile children with lobar pneumonia and leukocytosis. Pediatr Emerg Care. Dec. 1988;4(4):241-2. [pmid: 3231554].
Boyer KM, Gadzala CA, Kelly PD, et al. Selective intrapartum chemoprophylaxis of neonatal group B streptococcal early-onset disease. III. Interruption of mother-to-infant transmission. J Infect Dis. Nov. 1983;148(5):810-6. [pmid: 6355318].
Boyer KM, Gotoff SP. Prevention of early-onset neonatal group B streptococcal disease with selective intrapartum chemoprophylaxis. N Engl J Med. Jun. 26. 1986;314(26):1665-9. [pmid: 3520319].
Bramer S, van Wijk FH, Mol BW, et al. Risk indicators for neonatal early-onset GBS-related disease. A case-control study. J Perinat Med. 1997;25(6):469-75. [pmid: 9494918].
Bressan S, Andreola B, Zucchetta P, et al. Procalcitonin as a predictor of renal scarring in infants and young children. Pediatr Nephrol. 2009;24(6):1199-204. [pmid: 19205751].
Brook I, Gruenwald LD. Occurrence of bacteremia in febrile children seen in a hospital outpatient department and private practice. South Med J. Oct. 1984;77(10):1240-2. [pmid: 6333075].
Brown BJ, Asinobi AO, Fatunde OJ, et al. Antimicrobial sensitivity pattern of organisms causing urinary tract infection in children with sickle cell anaemia in Ibadan, Nigeria. West Afr J Med. Jun. 2003;22(2):110-3. [pmid: 14529216].
Buckingham SC, McCullers JA, Lujan-Zilbermann J, et al. Pneumococcal meningitis in children: relationship of antibiotic resistance to clinical characteristics and outcomes. Pediatr Infect Dis J. Sep. 2001;20(9):837-43. [pmid: 11734760].
Bulloch B, Bausher JC, Pomerantz WJ, et al. Can urine clarity exclude the diagnosis of urinary tract infection?. Pediatrics. Nov. 2000;106(5):E60. [pmid: 11061797].
Bunnag T, Kietkajornkul C. Out-patient antibiotics switch therapy in pediatric urinary tract infection. J Med Assoc Thai. Aug. Suppl 3. 2003;86:S543-S548. [pmid: 14700146].
Burstein JL, Fleisher GR. Does recent vaccination increase the risk of occult bacteremia?. Pediatr Emerg Care. Jun. 1994;10(3):138-40. [pmid: 8058555].
Buys H, Pead L, Hallett R, et al. Suprapubic aspiration under ultrasound guidance in children with fever of undiagnosed cause. BMJ. Mar. 12. 1994;308(6930):690-2. [pmid: 8142792].
Callanan D. Detecting fever in young infants: reliability of perceived, pacifier, and temporal artery temperatures in infants younger than 3 months of age. Pediatr Emerg Care. Aug. 2003;19(4):240-3. [pmid: 12972820].
Callegaro S, Titomanlio L, Donega S, et al. Implementation of a febrile seizure guideline in two pediatric emergency departments. Pediatric Neurology. 2009;40(2):78-83. Feb. [pmid: 19135618].
Camacho V, Estorch M, Fraga G, et al. DMSA study performed during febrile urinary tract infection: a predictor of patient outcome?. [see comment]. Eur J Nucl Med Mol Imaging. Jun. 2004;31(6):862-6. [pmid: 14758509].
Carroll AE, Silverstein M. C-reactive protein?. [comment]. Pediatrics. Aug. 2002;110(2 Pt 1):422. [pmid: 12165611].
Carstensen H, Henrichsen J, Jepsen OB. A national survey of severe group B streptococcal infections in neonates and young infants in Denmark, 1978-83. Acta Paediatr Scand. Nov. 1985;74(6):934-41. [pmid: 3911724].
Caviness AC, Demmler GJ, Swint JM, et al. Cost-effectiveness analysis of herpes simplex virus testing and treatment strategies in febrile neonates. Archives of Pediatrics & Adolescent Medicine. 2008;162(7):665-74. Jul. [pmid: 18606938].
Chartrand SA, McCracken GH Jr. Staphylococcal pneumonia in infants and children. Pediatr Infect Dis. Jan. 1982;1(1):19-23. [pmid: 7177890].
Chiou YY, Chiu NT, Chen MJ, et al. Role of beta 2-microglobulinuria and microalbuminuria in pediatric febrile urinary tract infection. Acta Paediatr Taiwan. Mar. 2001;42(2):84-9. [pmid: 11355070].
Chong CY, Tan AS, Ng W, et al. Treatment of urinary tract infection with gentamicin once or three times daily. Acta Paediatr. 2003;92(3):291-6. [pmid: 12725542].
Cimolai N, Roscoe DL. Contemporary context for early-onset group B streptococcal sepsis of the newborn. Am J Perinatol. Jan. 1995;12(1):46-9. [pmid: 7710577].
Claudius I, Baraff LJ. Pediatric Emergencies Associated with Fever. Emerg Med Clin North Am. 2010;28(1):67-84. [pmid: 19945599].
Cohen HA, Woloch B, Linder N, et al. Urine samples from disposable diapers: an accurate method for urine cultures. J Fam Pract. Mar. 1997;44(3):290-2. [pmid: 9071249].
Cohen M. The first urinary tract infection in male children. Am J Dis Child. Aug. 1976;130(8):810-3. [pmid: 782227].
Collins KL. Ambulatory treatment of infants with presumed febrile urinary tract infection may be feasible. J Pediatr. 2010;156(1):166-7. [pmid: 20006777].
Congeni BL. Comparison of ceftriaxone and traditional therapy of bacterial meningitis. Antimicrob Agents Chemother. Jan. 1984;25(1):40-4. [pmid: 6322681].
Connell H, de MP, Jodal U, et al. Lack of association between hemolysin production and acute inflammation in human urinary tract infection. Microb Pathog. Jun. 1993;14(6):463-72. [pmid: 7692210].
Corapcioglu F, Sarialioglu F, Olgun N, et al. Analysis of 136 febrile neutropenic episodes in children with cancer: evaluation of treatment effectiveness and cost. Pediatr Hematol Oncol. Sep. 2004;21(6):535-43. [pmid: 15552817].
Coulthard MG, Lambert HJ, Keir MJ. Do systemic symptoms predict the risk of kidney scarring after urinary tract infection?. Archives of Disease in Childhood. 2009;94(4):278-81. Apr. [pmid: 19015216].
Couture E, Labbe V, Cyr C. Clinical predictors of positive urine cultures in young children at risk for urinary tract infection. Paediatrics and Child Health. 2003;8(3):145-9. [pmid: 20020011].
Cox RD, Wagner M, Woolard DJ. Infants and children with fever without source. [comment]. Ann Emerg Med. Mar. 1994;23(3):598-600. [pmid: 8135443].
Craig JC, Abbott GD, Mogridge NB. Ceftriaxone for paediatric bacterial meningitis: a report of 62 children and a review of the literature. [Review] [24 refs]. N Z Med J. Nov. 11. 1992;105(945):441-4. [pmid: 1436855].
Craig JC, Williams GJ, Jones M, et al. The accuracy of clinical symptoms and signs for the diagnosis of serious bacterial infection in young febrile children: prospective cohort study of 15 781 febrile illnesses. BMJ. 2010;340:c1594. [pmid: 20406860].
Crocker PJ, Quick G, McCombs W. Occult bacteremia in the emergency department: diagnostic criteria for the young febrile child. Ann Emerg Med. Dec. 1985;14(12):1172-7. [pmid: 4061989].
Cunningham AM, Edwards A, Jones KV, et al. Evaluation of a service development to increase detection of urinary tract infections in children. J Eval Clin Pract. Feb. 2005;11(1):73-6. [pmid: 15660540].
Currie ML, Mitz L, Raasch CS, et al. Follow-up urine cultures and fever in children with urinary tract infection. [see comment]. Arch Pediatr Adolesc Med. Dec. 2003;157(12):1237-40. [pmid: 14662582].
Dagan R, Hall CB. Influenza A virus infection imitating bacterial sepsis in early infancy. Pediatr Infect Dis. May. 1984;3(3):218-21. [pmid: 6377255].
Davies D. Bag urine specimens still not appropriate in diagnosing urinary tract infections in infants. Canadian Journal of Infectious Diseases. 2004;15(4):210-1.
Davis KL, Shah SS, Frank G, et al. Why are young infants tested for herpes simplex virus?. Pediatr Emerg Care. Oct. 2008;24(10):673-8. [pmid: 19242136].
de MP, Jodal U, Svanborg C. Dependence among host response parameters used to diagnose urinary tract infection. J Infect Dis. Feb. 1991;163(2):331-5. [pmid: 1988517].
Dorfman D, Bauchner H. The impact of new diagnostic tests on the management of children with fever. Arch Pediatr Adolesc Med. Aug. 2000;154(8):761-2. [pmid: 10922270].
Durongpisitkul K, Gururaj VJ, Martin CF. The appropriateness of early discharge of hospitalized children with suspected sepsis. J Fam Pract. Jan. 1997;44(1):91-6. [pmid: 9010376].
Edelbroek MA, De Nef JJ, Rajnherc JR. Listeria meningitis presenting as enteritis in a previously healthy infant: a case report. Eur J Pediatr. Mar. 1994;153(3):179-80. [pmid: 8181501].
El-Mahallawy H, Sidhom I, El-Din NH, et al. Clinical and microbiologic determinants of serious bloodstream infections in Egyptian pediatric cancer patients: a one-year study. Int J Infect Dis. Jan. 2005;9(1):43-51. [pmid: 15603994].
Elmore JG. Acute meningitis with a negative gram's stain: Clinical and management outcomes in 171 episodes. Am J Med. 1996;100(1):78-84. [pmid: 8579091].
Fang SB, Lee HC, Yeung CY, et al. Urinary tract infections in young infants with prolonged jaundice. Acta Paediatr Taiwan. Nov. 2005;46(6):356-60. [pmid: 16640038].
Feder HM Jr. Can we screen febrile children for pneumonia and/or bacteremia without chest x-ray films and blood cultures?. Pediatrics. Feb. 1978;61(2):332-3. [pmid: 634705].
Fernandez LA, Luaces CC, Garcia Garcia JJ, et al. Procalcitonin in pediatric emergency departments for the early diagnosis of invasive bacterial infections in febrile infants: results of a multicenter study and utility of a rapid qualitative test for this marker. Pediatr Infect Dis J. Oct. 2003;22(10):895-903. [pmid: 14551491].
Fidler KJ, Pierce CM, Cubitt WD, et al. Could neonatal disseminated herpes simplex virus infections be treated earlier?. J Infect. 2004;49(2):141-6. [pmid: 15236921].
Friedland IR, Paris MM, Rinderknecht S, et al. Cranial computed tomographic scans have little impact on management of bacterial meningitis. Am J Dis Child. Dec. 1992;146(12):1484-7. [pmid: 1456265].
Galetto-Lacour A, Zamora SA, Gervaix A. Bedside procalcitonin and C-reactive protein tests in children with fever without localizing signs of infection seen in a referral center. Pediatrics. Nov. 2003;112(5):1054-60. [pmid: 14595045].
Gendrel D, Raymond J, Coste J, et al. Comparison of procalcitonin with C-reactive protein, interleukin 6 and interferon-alpha for differentiation of bacterial vs. viral infections. Pediatr Infect Dis J. Oct. 1999;18(10):875-81. [pmid: 10530583].
Gervaix A, Galetto-Lacour A, Gueron T, et al. Usefulness of procalcitonin and C-reactive protein rapid tests for the management of children with urinary tract infection. Pediatr Infect Dis J. May. 2001;20(5):507-11. [pmid: 11368108].
Gessler P, Martin F, Suter D, et al. Invasive pneumococcal disease in children prior to implementation of the conjugate vaccine in the Zurich region, Switzerland. Acta Paediatrica. 2010;99(7):1005-10. Jul. [pmid: 20219035].
Gilbert GL, Garland SM. Perinatal group B streptococcal infections. Med J Aust. Jun. 11. 1983;1(12):566-71. [pmid: 6343814].
Giorgi LJ Jr., Bratslavsky G, Kogan BA. Febrile urinary tract infections in infants: renal ultrasound remains necessary. J Urol. Feb. 2005;173(2):568-70. [pmid: 15643258].
Goldman RD, Matlow A, Linett L, et al. What is the risk of bacterial meningitis in infants who present to the emergency department with fever and pyuria?. Can J Emerg Med. Nov. 2003;5(6):394-9.
Goldraich NP, Manfroi A. Febrile urinary tract infection: Escherichia coli susceptibility to oral antimicrobials. [see comment]. Pediatr Nephrol. Mar. 2002;17(3):173-6. [pmid: 11956854].
Gombos MM, Bienkowski RS, Gochman RF, et al. The absolute neutrophil count: is it the best indicator for occult bacteremia in infants?. Am J Clin Pathol. Feb. 1998;109(2):221-5. [pmid: 9583895].
Gorelick MH, Hoberman A, Kearney D, et al. Validation of a decision rule identifying febrile young girls at high risk for urinary tract infection. Pediatr Emerg Care. Jun. 2003;19(3):162-4. [pmid: 12813300].
Gorelick MH, Shaw KN. Clinical decision rule to identify febrile young girls at risk for urinary tract infection. Arch Pediatr Adolesc Med. Apr. 2000;154(4):386-90. [pmid: 10768678].
Gratz S, Behr TM, Herrmann A, et al. Immunoscintigraphy (BW 250/183) in neonates and infants with fever of unknown origin. Nucl Med Commun. Nov. 1998;19(11):1037-45. [pmid: 9861620].
Greene JW, Hara C, O'Connor S, et al. Management of febrile outpatient neonates. Clin Pediatr (Phila). Jun. 1981;20(6):375-80. [pmid: 7226692].
Grenier D, Sgro M, Wong T, et al. 143 international comparison of severe neonatal Hyperbilirubinemia and neonatal herpes simplex infection. Canadian Pediatric Society 84^th^ Annual Conference. 2007.
Grisaru-Soen G, Goldman R, Barzilai A, et al. False-positive urine cultures using bag collection. [1]. Clin Pediatr (Phila). 2000;39(8):499-500. [pmid: 10961824].
Grubbauer HM, Dornbusch HJ, Dittrich P, et al. Ceftriaxone monotherapy for bacterial meningitis in children. Chemotherapy. 1990;36(6):441-7. [pmid: 2292206].
Haddon RA, Barnett PL, Grimwood K, et al. Bacteraemia in febrile children presenting to a pae3iatric emergency department. [see comment]. Med J Aust. May. 17. 1999;170(10):475-8. [pmid: 10376023].
Hara M, Takao S, Fukuda S, et al. Human metapneumovirus infection in febrile children with lower respiratory diseases in primary care settings in Hiroshima, Japan. Jpn J Infect Dis. Nov. 2008;61(6):500-2. [pmid: 19050367].
Harper MB, Bachur R, Fleisher GR. Effect of antibiotic therapy on the outcome of outpatients with unsuspected bacteremia. Pediatr Infect Dis J. Sep. 1995;14(9):760-7. [pmid: 8559624].
Herz DB. Editorial comment. Journal of Urology. 2010;184(1):297. Jul. [pmid: 20494370].
Hiraoka M, Hashimoto G, Tsuchida S, et al. Early treatment of urinary infection prevents renal damage on cortical scintigraphy. Pediatr Nephrol. Feb. 2003;18(2):115-8. [pmid: 12579399].
Hoberman A, Wald ER, Hickey RW, et al. Oral versus initial intravenous therapy for urinary tract infections in young febrile children. Pediatrics. Jul. 1999;104(1 Pt 1):79-86. [pmid: 10390264].
Hoberman A, Wald ER, Reynolds EA, et al. Is urine culture necessary to rule out urinary tract infection in young febrile children?. Pediatr Infect Dis J. Apr. 1996;15(4):304-9. [pmid: 8866798].
Hoberman A, Wald ER, Reynolds EA, et al. Pyuria and bacteriuria in urine specimens obtained by catheter from young children with fever. [see comment]. J Pediatr. Apr. 1994;124(4):513-9. [pmid: 8151463].
Hogg RJ. A search for the “elusive” urinary tract infection in febrile infants. Pediatr Infect Dis J. Mar. 1987;6(3):233-4. [pmid: 3575006].
Huang YS, Wang SM, Liu CC, et al. Invasive Escherichia coli infection in infancy: clinical manifestation, outcome, and antimicrobial susceptibility. J Microbiol Immunol Infect. Jun. 2002;35(2):103-8. [pmid: 12099330].
Its risk factors at mount sinai hospital. Canadian Pediatric Society 84^th^ Annual Conference. 2007 Jun 26. 2008.
Jacobs RF, Darville T, Parks JA, et al. Safety profile and efficacy of cefotaxime for the treatment of hospitalized children. [see comment]. Clin Infect Dis. Jan. 1992;14(1):56-65. [pmid: 1571464].
Jantausch BA, O'Donnell R, Wiedermann BL. Urinary interleukin-6 and interleukin-8 in children with urinary tract infection. Pediatr Nephrol. Dec. 2000;15(3-4):236-40. [pmid: 11149117].
Jantausch BA, Rifai N, Getson P, et al. Urinary N-acetyl-beta-glucosaminidase and beta-2-microglobulin in the diagnosis of urinary tract infection in febrile infants. Pediatr Infect Dis J. Apr. 1994;13(4):294-9. [pmid: 8036046].
Joffe M, Avner JR. Follow-up of patients with occult bacteremia in pediatric emergency departments. Pediatr Emerg Care. Oct. 1992;8(5):258-61. [pmid: 1408974].
Johnson CE, Whitwell JK, Pethe K, et al. Term newborns who are at risk for sepsis: are lumbar punctures necessary?. Pediatrics. Apr. 1997;99(4):E10. [pmid: 9099785].
Jones RG, Bass JW. Febrile children with no focus of infection: a survey of their management by primary care physicians. Pediatr Infect Dis J. Mar. 1993;12(3):179-83. [pmid: 8451092].
Kavaliotis J, Manios SG, Kansouzidou A, et al. Treatment of childhood bacterial meningitis with ceftriaxone once daily: open, prospective, randomized, comparative study of short-course versus standard-length therapy. Chemotherapy. 1989;35(4):296-303. [pmid: 2766869].
Kelly MJ, Vivier PM, Panken TM, et al. Bacteremia in febrile nonneutropenic pediatric oncology patients. Pediatr Blood Cancer. 2010;54(1):83-7. [pmid: 19774640].
Kimia A, Ben-Joseph EP, Rudloe T, et al. Yield of lumbar puncture among children who present with their first complex febrile seizure. Pediatrics. 2010;126(1):62-9. Jul. [pmid: 20566610].
Kiragu AW, Zier J, Cornfield DN. Utility of blood cultures in postoperative pediatric intensive care unit patients. Pediatr Crit Care Med. 2009;10(3):364-8. [pmid: 19325504].
Knight GJ, Carman PG. Primary staphylococcal pneumonia in childhood: a review of 69 cases. J Paediatr Child Health. Dec. 1992;28(6):447-50. [pmid: 1466941].
Kuo CH, Lee MS, Yang RC, et al. Cerebral venous sinus thrombosis in an infant with Pseudomonas aeruginosa sepsis. Pediatr Int. 2010;52(2):314-6. [pmid: 20500483].
Lacour AG, Gervaix A, Zamora SA, et al. Procalcitonin, IL-6, IL-8, IL-1 receptor antagonist and C-reactive protein as identificators of serious bacterial infections in children with fever without localising signs. Eur J Pediatr. Feb. 2001;160(2):95-100. [pmid: 11271398].
Lacour AG, Zamora SA, Gervaix A. A score identifying serious bacterial infections in children with fever without source. Pediatr Infect Dis J. Jul. 2008;27(7):654-6. [pmid: 18536624].
Landau D, Turner ME, Brennan J, et al. The value of urinalysis in differentiating acute pyelonephritis from lower urinary tract infection in febrile infants. Pediatr Infect Dis J. Sep. 1994;13(9):777-81. [pmid: 7808845].
Lavocat MP, Granjon D, Allard D, et al. Imaging of pyelonephritis. Pediatr Radiol. Feb. 1997;27(2):159-65. [pmid: 9028852].
Leape LL, McEachen WH. Office urine cultures in pediatric practice. Postgrad Med. Oct. 1974;56(4):177-82. [pmid: 4606867].
Lee HY, Hyun SB, Hee HC, et al. The efficacy of ultrasound and dimercaptosuccinic acid scan in predicting vesicoureteral reflux in children below the age of 2 years with their first febrile urinary tract infection. Pediatric Nephrology. 2009;24(10):2009-13. Oct. [pmid: 19593590].
Lee JW, Shim YH, Lee SJ. Lactobacillus colonization status in infants with urinary tract infection. Pediatr Nephrol. 2009;24(1):135-9. [pmid: 18781336].
Lee MD, Lin CC, Huang FY, et al. Screening young children with a first febrile urinary tract infection for high-grade vesicoureteral reflux with renal ultrasound scanning and technetium-99m-labeled dimercaptosuccinic acid scanning. Journal of Pediatrics. 2009;154(6):797-802. Jun. [pmid: 19230904].
Lembo RM, Marchant CD. Acute phase reactants and risk of bacterial meningitis among febrile infants and children. [see comment]. Ann Emerg Med. Jan. 1991;20(1):36-40. [pmid: 1984725].
Lembo RM, Rubin DH, Krowchuk DP, et al. Peripheral white blood cell counts and bacterial meningitis: Implications regarding diagnostic efficacy in febrile children. Pediatr Emerg Care. 1991;7(1):4-11. [pmid: 2027812].
Levy M, Wong E, Fried D. Diseases that mimic meningitis. Analysis of 650 lumbar punctures. [see comment]. Clin Pediatr (Phila). 258. May. 29(5):254-5. [pmid: 2340687].
Liao CH, Huang LM, Lu CY, et al. Group B streptococcus infection in infancy: 21-year experience. Acta Paediatr Taiwan. Nov. 2002;43(6):326-9. [pmid: 12632785].
Liebelt EL, Qi K, Harvey K. Diagnostic testing for serious bacterial infections in infants aged 90 days or younger with bronchiolitis. Arch Pediatr Adolesc Med. May. 1999;153(5):525-30. [pmid: 10323635].
Lieu TA, Mohle-Boetani JC, Ray GT, et al. Neonatal group B streptococcal infection in a managed care population. Perinatal Group B Streptococcal Infection Study Group. Obstet Gynecol. Jul. 1998;92(1):21-7. [pmid: 9649086].
Lin DS, Huang FY, Chiu NC, et al. Comparison of hemocytometer leukocyte counts and standard urinalyses for predicting urinary tract infections in febrile infants. Pediatr Infect Dis J. Mar. 2000;19(3):223-7. [pmid: 10749464].
Lin FY, Brenner RA, Johnson YR, et al. The effectiveness of risk-based intrapartum chemoprophylaxis for the prevention of early-onset neonatal group B streptococcal disease. Am J Obstet Gynecol. May. 2001;184(6):1204-10. [pmid: 11349189].
Lin SJ, Huang JL. Circulating interleukin (IL)-1 beta, IL-6 and tumor necrosis factor-alpha in children with febrile infection--a comparison with C-reactive protein. Asian Pac J Allergy Immunol. Jun. 1998;16(2-3):105-9. [pmid: 9876948].
Lin TY, Chrane DF, Nelson JD, et al. Seven days of ceftriaxone therapy is as effective as ten days' treatment for bacterial meningitis. JAMA. Jun. 28. 1985;253(24):3559-63. [pmid: 3889396].
Lin TY, Nelson JD, McCracken GH Jr. Fever during treatment for bacterial meningitis. Pediatr Infect Dis. Jul. 1984;3(4):319-22. [pmid: 6473134].
Linnemann CC, Steichen J, Sherman WG, et al. Febrile illness in early infancy associated with ECHO virus infection. J Pediatr. Jan. 1974;84(1):49-54. [pmid: 12119956].
Liu CC, Chen JS, Lin CH, et al. Bacterial meningitis in infants and children in southern Taiwan: emphasis on Haemophilus influenzae type B infection. J Formos Med Assoc. Oct. 1993;92(10):884-8. [pmid: 7908569].
Liu CH, Lehan C, Speer ME, et al. Early detection of bacteremia in an outpatient clinic. Pediatrics. May. 1985;75(5):827-31. [pmid: 3991267].
Liu ZH, Chen NY, Tu PH, et al. The treatment and outcome of postmeningitic subdural empyema in infants. Journal of Neurosurgery Pediatrics. 2010;6(1):38-42. Jul. [pmid: 20593986].
Long SS. Antibiotic therapy in febrile children: “best-laid schemes”. J Pediatr. Apr. 1994;124(4):585-8. [pmid: 8151473].
Lyytikainen O, Nuorti JP, Halmesmaki E, et al. Invasive group B streptococcal infections in Finland: a population-based study. Emerg Infect Dis. Apr. 2003;9(4):469-73. [pmid: 12702228].
Manzano S, Bailey B, Girodias JB, et al. Impact of procalcitonin on the management of children aged 1 to 36 months presenting with fever without source: a randomized controlled trial. American Journal of Emergency Medicine. 2010;28(6):647-53. Jul. [pmid: 20637377].
Marcinak JF. Evaluation of children with fever greater than or equal to 104 degrees F in an emergency department. Pediatr Emerg Care. Jun. 1988;4(2):92-6. [pmid: 3380752].
Marild S, J. Ceftibuten versus trimethoprim-sulfamethoxazole for oral treatment of febrile urinary tract infection in children. Pediatric nephrology (Berlin, Germany). Mar. 2009;24(3):6. 2009.
Marild S, Hellstrom M, Jodal U, et al. Fever, bacteriuria and concomitant disease in children with urinary tract infection. Pediatr Infect Dis J. Jan. 1989;8(1):36-41. [pmid: 2922235].
Marild S, Jodal U, Sandberg T. Ceftibuten versus trimethoprim-sulfamethoxazole for oral treatment of febrile urinary tract infection in children. Pediatric Nephrology. 2009;24(3):521-6. Mar. [pmid: 18818954].
Marild S, Wettergren B, Hellstrom M, et al. Bacterial virulence and inflammatory response in infants with febrile urinary tract infection or screening bacteriuria. J Pediatr. Mar. 1988;112(3):348-54. [pmid: 3279175].
Mazur LJ, Jones TM, Kozinetz CA. Temperature response to acetaminophen and risk of occult bacteremia: a case-control study. J Pediatr. Dec. 1989;115(6):888-91. [pmid: 2585223].
Mazur LJ, Kozinetz CA. Diagnostic tests for occult bacteremia: temperature response to acetaminophen versus WBC count. [see comment]. Am J Emerg Med. Jul. 1994;12(4):403-6. [pmid: 8031421].
McCarthy CA, Powell KR. Screening for serious bacterial infections in young febrile infants. Arch Pediatr Adolesc Med. Mar. 2000;154(3):315-6. [pmid: 10710038].
McCarthy PL, Grundy GW, Spiesel SZ, et al. Bacteremia in children: an outpatient clinical review. Pediatrics. Jun. 1976;57(6):861-8. [pmid: 934743].
McGowan JE Jr., Bratton L, Klein JO, et al. Bacteremia in febrile children seen in a “walk-in” pediatric clinic. N Engl J Med. Jun. 21. 1973;288(25):1309-12. [pmid: 4145198].
McWilliam S, Riordan A. How to use: C-reactive protein. Arch Dis Child. Education and practice edition. 2010;95(2):55-8. [pmid: 19531523].
Melendez E, Harper MB. Utility of sepsis evaluation in infants 90 days of age or younger with fever and clinical bronchiolitis. [see comment]. Pediatr Infect Dis J. Dec. 2003;22(12):1053-6. [pmid: 14688564].
Memmini G, Buggiani B, Ciulli L, et al. Study on 480 hospitalized febrile children: evaluation of the septic risk and results of the antibiotic and corticosteroid combined therapy. Pediatr Med Chir. May. 1999;21(3):119-23. [pmid: 10687160].
Messaritakis J, Anagnostakis D, Laskari H, et al. Rectal-skin temperature difference in septicaemic newborn infants. Arch Dis Child. Apr. 1990;65(4 Spec No):380-2. [pmid: 2337363].
Mifsud AJ, Efstratiou A, Charlett A, et al. Early-onset neonatal group B streptococcal infection in London: 1990-1999. BJOG. Sep. 2004;111(9):1006-11. [pmid: 15327618].
Mintegi S, Benito J, Sanchez J, et al. Predictors of occult bacteremia in young febrile children in the era of heptavalent pneumococcal conjugated vaccine. Eur J Emerg Med. Aug. 2009;16(4):199-205. [pmid: 19593900].
Miron D, Grossman Z. [The diagnosis and therapy of first community acquired urinary tract infection in children]. [Review] [23 refs] [Hebrew]. Harefuah. 792. 791. 2009;148(11):778-82. Nov. [pmid: 20027983].
Mishal J, Embon A, Darawshe A, et al. Community acquired acute bacterial meningitis in children and adults: an 11-year survey in a community hospital in Israel. EUR. Oct. 2008;19(6):421-6.
Mohanan N, Colhoun E, Puri P. Renal Parenchymal Damage in Intermediate and High Grade Infantile Vesicoureteral Reflux. J Urol. 2008;180(4 SUPPL.):1635-8. [pmid: 18708232].
Montini G, Rigon L, Zucchetta P, et al. Prophylaxis after first febrile urinary tract infection in children? A multicenter, randomized, controlled, noninferiority trial. Pediatrics. Nov. 2008;122(5):1064-71. [pmid: 18977988].
Montini G. Value of imaging studies after a first febrile urinary tract infection in young children: data from italian renal infection study 1. Pediatrics. Feb. 2009;123(2):e246. 2009.
Moore S, Houston K, Chellew M, et al. 53. incidence of early onset neonatal sepsis and management of.
Morris CB, Vince JD, Ripa P, et al. The clean catch technique for urine collection in infants and young children. Trop Doct. 2007;37(2):125. [pmid: 17540111].
Mularoni PP, Cohen LL, DeGuzman M, et al. A Randomized clinical trial of lidocaine gel for reducing infant distress during urethral catheterization. Pediatr Emerg Care. 2009;25(7):439-43. [pmid: 19564809].
Musa-Aisien AS, Ibadin OM, Ukoh G, et al. Prevalence and antimicrobial sensitivity pattern in urinary tract infection in febrile under-5s at a children's emergency unit in Nigeria. Ann Trop Paediatr. Mar. 2003;23(1):39-45. [pmid: 12648323].
Mustafa MM, Ramilo O, Saez-Llorens X, et al. Cerebrospinal fluid prostaglandins, interleukin 1 beta, and tumor necrosis factor in bacterial meningitis. Clinical and laboratory correlations in placebo-treated and dexamethasone-treated patients. Am J Dis Child. Aug. 1990;144(8):883-7. [pmid: 2116086].
Nademi Z, Clark J, Richards CG, et al. The causes of fever in children attending hospital in the north of England. J Infect. Nov. 2001;43(4):221-5. [pmid: 11869058].
Newman TB, Takayama JI. Urinary tract infection controversy and questions. [comment]. Pediatrics. Apr. 1998;101(4 Pt 1):731-3. [pmid: 9556412].
Nielsen HE, Andersen EA, Andersen J, et al. Diagnostic assessment of haemorrhagic rash and fever. Arch Dis Child. Aug. 2001;85(2):160-5. [pmid: 11466193].
Nigrovic LE, Chiang VW. Cost analysis of enteroviral polymerase chain reaction in infants with fever and cerebrospinal fluid pleocytosis. [see comment]. Arch Pediatr Adolesc Med. Aug. 2000;154(8):817-21. [pmid: 10922279].
Nimri LF, Batchoun R. Community-acquired bacteraemia in a rural area: predominant bacterial species and antibiotic resistance. J Med Microbiol. Oct. 2004;53(Pt 10):1045-9. [pmid: 15358829].
Novak R, Powell K, Christopher N. Optimal diagnostic testing for urinary tract infection in young children. Pediatr Dev Pathol. May. 2004;7(3):226-30. [pmid: 15022064].
Novakova I, Donnelly P, De PB. Amikacin plus piperacillin versus ceftazidime as initial therapy in granulocytopenic patients with presumed bacteremia. Scand J Infect Dis. 1990;22(6):705-11. [pmid: 2284577].
Novotny E, Renfroe B, Yardi N, et al. Randomized trial of adjunctive topiramate therapy in infants with refractory partial seizures. Neurology. 2010;74(9):714-20. [pmid: 20089937].
Nozicka CA, Hanly JG, Beste DJ, et al. Otitis media in infants aged 0-8 weeks: frequency of associated serious bacterial disease. Pediatr Emerg Care. Aug. 1999;15(4):252-4. [pmid: 10460078].
Oddie S, Embleton ND. Risk factors for early onset neonatal group B streptococcal sepsis: case-control study. BMJ. Aug. 10. 2002;325(7359):308. [pmid: 12169506].
Okwara FN, Obimbo EM, Wafula EM, et al. Bacteraemia, urinary tract infection and malaria in hospitalised febrile children in Nairobi: is there an association?. East Afr Med J. Jan. 2004;81(1):47-51. [pmid: 15080516].
Olesch CA, Knight GJ. Invasive meningococcal infection in Western Australia. J Paediatr Child Health. Feb. 1999;35(1):42-8. [pmid: 10234634].
Onyejiaka NA, Ali NB, Fogarasi SR. A neonate in septic shock. Clin Pediatr (Phila). 2010;49(3):297-9. [pmid: 20164076].
Oray-Schrom P, Phoenix C, St MD, et al. Sepsis workup in febrile infants 0-90 days of age with respiratory syncytial virus infection. [Review] [25 refs]. Pediatr Emerg Care. Oct. 2003;19(5):314-9. [pmid: 14578830].
Osman O, Brown D, Beattie T, et al. Management of febrile children in a paediatric emergency department. Health Bull (Edinb). Jan. 2002;60(1):33-9. [pmid: 12664766].
Ottolini MC, Lundgren K, Mirkinson LJ, et al. Utility of complete blood count and blood culture screening to diagnose neonatal sepsis in the asymptomatic at risk newborn. [see comment]. Pediatr Infect Dis J. May. 2003;22(5):430-4. [pmid: 12792384].
Oude Nijhuis CS, Vellenga E, Daenen SM, et al. Lipopolysaccharide-binding protein: a possible diagnostic marker for Gram-negative bacteremia in neutropenic cancer patients. Intensive Care Med. Dec. 2003;29(12):2157-61. [pmid: 14569424].
Ozcelik G, Polat TB, Aktas S, et al. Resistive index in febrile urinary tract infections: predictive value of renal outcome. [see comment][erratum appears in Pediatr Nephrol. 2004 May;19(5):575 Note: Fetinkaya, Feyzullah [corrected to Cetinkaya, Feyzullah]]. Pediatr Nephrol. Feb. 2004;19(2):148-52. [pmid: 14685837].
Paganini H, Gonzalez F, Santander C, et al. Tuberculous meningitis in children: clinical features and outcome in 40 cases. Scand J Infect Dis. 2000;32(1):41-5. [pmid: 10716076].
Pagliano P, Fusco U, Attanasio V, et al. Pneumococcal meningitis in childhood: a longitudinal prospective study. FEMS Immunol Med Microbiol. Dec. 2007;51(3):488-95. [pmid: 17877732].
Pasic S, Minic A, Djuric P, et al. Fever of unknown origin in 185 paediatric patients: A single-centre experience. Acta Paediatrica, International Journal of Paediatrics. 2006;95(4):463-6.
Pecile P, Miorin E, Romanello C, et al. Age-related renal parenchymal lesions in children with first febrile urinary tract infections. Pediatrics. Jul. 2009;124(1):23-9. [pmid: 19564279].
Pecile P, Miorin E, Romanello C, et al. Procalcitonin: a marker of severity of acute pyelonephritis among children. Pediatrics. Aug. 2004;114(2):e249-e254. [pmid: 15286264].
Pecile P, Miorin E, Romanello C, et al. Procalcitonin: a marker of severity of acute pyelonephritis among children. Pediatrics. Aug. Supplement. 2004;(2):54.
Pena BM, Harper MB, Fleisher GR. Occult bacteremia with group B streptococci in an outpatient setting. Pediatrics. Jul. 1998;102(1 Pt 1):67-72. [pmid: 9651415].
Perez A, Herranz M, Segura M, et al. Epidemiologic impact of blood culture practices and antibiotic consumption on pneumococcal bacteraemia in children. European Journal of Clinical Microbiology and Infectious Diseases. 2008;27(8):717-24. [pmid: 18347821].
Philipson EH, Herson VC. Intrapartum chemoprophylaxis for group B streptococcus infection to prevent neonatal disease: who should be treated?. Am J Perinatol. Nov. 1996;13(8):487-90. [pmid: 8989480].
Pollack CV J, Pollack ES, et al. Suprapubic bladder aspiration versus urethral catheterization in ill infants: Success, efficiency, and complication rates. Ann Emerg Med. 1994;23(2):225-30. [pmid: 8304603].
Pourcyrous M, Bada HS, Korones SB, et al. Significance of serial C-reactive protein responses in neonatal infection and other disorders. Pediatrics. Sep. 1993;92(3):431-5. [pmid: 8361798].
Press S, Fawcett NP. Association of temperature greater than 41.1 degrees C (106 degrees F) with serious illness. Clin Pediatr (Phila). Jan. 1985;24(1):21-5. [pmid: 3965227].
Press S. Association of hyperpyrexia with serious disease in children. Clin Pediatr (Phila). Jan. 1994;33(1):19-25. [pmid: 8156722].
Procop GW, Hartman JS, Sedor F. Laboratory tests in evaluation of acute febrile illness in pediatric emergency room patients. Am J Clin Pathol. Jan. 1997;107(1):114-21. [pmid: 8980378].
Putto A, Ruuskanen O, Meurman O, et al. C reactive protein in the evaluation of febrile illness. Arch Dis Child. Jan. 1986;61(1):24-9. [pmid: 3954416].
Rabasa AI, Gofama MM. Urinary tract infection in febrile children in Maiduguri north eastern Nigeria. Nigerian Journal of Clinical Practice. 2009;12(2):124-7. Jun. [pmid: 19764657].
Rao S, Bhatt J, Houghton C, et al. An improved urine collection pad method: a randomised clinical trial. [see comment]. Arch Dis Child. Aug. 2004;89(8):773-5. [pmid: 15269081].
Raper J. Commentary on Suprapubic bladder aspiration versus urethral catheterization in ill infants: success, efficiency, and complication rates. [original article by Pollack C et al appears in ANN EMERG MED 1994;23(2),225-9]. ENA'S Nursing Scan in Emergency Care. Jul. 1994;4(4):6.
Reed K, Newton W. Oral or IV antibiotics for the treatment of febrile children with UTIs?. J Fam Pract. Nov. 1999;48(11):912. [pmid: 10907631].
Reid TM. Emergence of group B streptococci in obstetric and perinatal infections. Br Med J. Jun. 7. 1975;2(5970):533-5. [pmid: 1097038].
Riordan FA, Sills JA, Thomson AP, et al. Bacterial meningitis after MMR immunisation. Postgrad Med J. Dec. 1995;71(842):745-6. [pmid: 8552541].
Roberts KB, Charney E, Sweren RJ, et al. Urinary tract infection in infants with unexplained fever: a collaborative study. J Pediatr. Dec. 1983;103(6):864-7. [pmid: 6644419].
Robertson J. Changing a urine collection pad (UCP) every 30 minutes reduced contamination of urine samples more than a UCP kept in the nappy in children with suspected urinary tract infection. Evid Based Nurs. Jul. 2005;8(3):73. [pmid: 16021702].
Rosenberg N, Cohen SN. Pneumococcal bacteremia in pediatric patients. Ann Emerg Med. Jan. 1982;11(1):2-6. [pmid: 7055347].
Rosenberg N, Ryckaert A. Use of thermogram in detection of meningitis. Pediatr Emerg Care. Jun. 1986;2(2):71-4. [pmid: 3786215].
Roukema J, van Loenhout RB, Steyerberg EW, et al. Polytomous regression did not outperform dichotomous logistic regression in diagnosing serious bacterial infections in febrile children. J Clin Epidemiol. Feb. 2008;61(2):135-41. [pmid: 18177786].
Rowley AH, Wald ER. The incubation period necessary for detection of bacteremia in immunocompetent children with fever. Implications for the clinician. Clin Pediatr (Phila). Oct. 1986;25(10):485-9. [pmid: 3757393].
Rubin LG. Occult bacteremia in the young febrile child. Pediatric Reviews and Communications. 1988;2(3):193-206.
Rusconi F, Parizzi F, Garlaschi L, et al. Interleukin 6 activity in infants and children with bacterial meningitis. The Collaborative Study on Meningitis. Pediatr Infect Dis J. Feb. 1991;10(2):117-21. [pmid: 2062602].
Sakran W, Valinsky L, Koren A, et al. Early onset of neonatal Streptococcus pneumoniae bacteremia and septic arthritis. Clin Pediatr (Phila). Jul. 2004;43(6):579-81. [pmid: 15248014].
Saladino R, Erikson M, Levy N, et al. Utility of serum interleukin-6 for diagnosis of invasive bacterial disease in children. [erratum appears in Ann Emerg Med 1993 Apr;22(4):750 Note: Silber GR [corrected to Siber GR]]. Ann Emerg Med. Dec. 1992;21(12):1413-7. [pmid: 1443833].
Schaad UB, Krucko J, Pfenninger J. An extended experience with cefuroxime therapy of childhood bacterial meningitis. Pediatr Infect Dis. Sep. 1984;3(5):410-6. [pmid: 6387641].
Scholz H, Hofmann T, Noack R, et al. Prospective comparison of ceftriaxone and cefotaxime for the short-term treatment of bacterial meningitis in children. Chemotherapy. Mar. 1998;44(2):142-7. [pmid: 9551246].
Schrag SJ, Hadler JL, Arnold KE, et al. Risk factors for invasive, early-onset Escherichia coli infections in the era of widespread intrapartum antibiotic use. Pediatrics. Aug. 2006;118(2):570-6. [pmid: 16882809].
Schuchat A, aver-Robinson K, Plikaytis BD, et al. Multistate case-control study of maternal risk factors for neonatal group B streptococcal disease. The Active Surveillance Study Group. Pediatr Infect Dis J. Jul. 1994;13(7):623-9. [pmid: 7970951].
Schuchat A, Zywicki SS, Dinsmoor MJ, et al. Risk factors and opportunities for prevention of early-onset neonatal sepsis: a multicenter case-control study. Pediatrics. Jan. 2000;105(1 Pt 1):21-6. [pmid: 10617699].
Schwartz RH, Wientzen RL Jr. Occult bacteremia in toxic-appearing, febrile infants. A prospective clinical study in an office setting. Clin Pediatr (Phila). Nov. 1982;21(11):659-63. [pmid: 7127988].
Seltz LB, Cohen E, Weinstein M. Risk of bacterial or herpes simplex virus meningitis/encephalitis in children with complex febrile seizures. Pediatric Emergency Care. 2009;25(8):494-7. Aug. [pmid: 19633589].
Sensoy G, Sayli TR, Guven A, et al. Infantile nonconvulsive status epilepticus caused by herpes encephalitis. Journal of Pediatric Neurosciences. 2009;4(2):139-41. [pmid: 21887203].
Shah SS, Zorc JJ, Levine DA, et al. Sterile cerebrospinal fluid pleocytosis in young infants with urinary tract infections. J Pediatr. Aug. 2008;153(2):290-2. [pmid: 18639733].
Shaikh N. Acute urinary tract infection in infants and young children. CMAJ. Canadian Medical Association Journal. 2010;182(8):800-1. [pmid: 20159898].
Sharples PM, Seckl JR, Human D, et al. Plasma and cerebrospinal fluid arginine vasopressin in patients with and without fever. Arch Dis Child. Aug. 1992;67(8):998-1002. [pmid: 1520019].
Shaw KN, Gorelick M, McGowan KL, et al. Prevalence of urinary tract infection in febrile young children in the emergency department. Pediatrics. Aug. 1998;102(2):e16. [pmid: 9685461].
Shaw KN, McGowan KL. Evaluation of a rapid screening filter test for urinary tract infection in children. Pediatr Infect Dis J. Mar. 1997;16(3):283-7. [pmid: 9076816].
Shim YH, Lee JW, Lee SJ. The risk factors of recurrent urinary tract infection in infants with normal urinary systems. Pediatr Nephrol. Feb. 2009;24(2):309-12. [pmid: 18830717].
Shinefield H, Black S, Ray P, et al. Efficacy, immunogenicity and safety of heptavalent pneumococcal conjugate vaccine in low birth weight and preterm infants. Pediatr Infect Dis J. Mar. 2002;21(3):182-6. [pmid: 12005078].
Shochet S, Newman TB, Takayama J, et al. Otitis media in febrile infants 0-3 months old; management and outcome in office settings. Abstracts for 2001 - Presented at the PAS Meeting. April/May. Pediatric Academic Societies Abstracts. 2001.
Silverstein M, Bachur R, Harper MB. Clinical implications of penicillin and ceftriaxone resistance among children with pneumococcal bacteremia. Pediatr Infect Dis J. Jan. 1999;18(1):35-41. [pmid: 9951978].
Sjostrom S, Jodal U, Sixt R, et al. Longitudinal development of renal damage and renal function in infants with high grade vesicoureteral reflux. J Urol. May. 2009;181(5):2277-83. [pmid: 19303099].
Smith AL. Childhood bacteremia. N Engl J Med. Jun. 21. 1973;288(25):1351-2. [pmid: 4145199].
Soccorso G, Wagstaff J, Blakey K, et al. Investigating febrile UTI in infants: Is a cystogram necessary?. Journal of Pediatric Urology. 2010;6(2):148-52. [pmid: 19620025].
Soman M. Characteristics and management of febrile young children seen in a university family practice. J Fam Pract. Aug. 1985;21(2):117-22. [pmid: 4020334].
Somech R, Zakuth V, Assia A, et al. Procalcitonin correlates with C-reactive protein as an acute-phase reactant in pediatric patients. Isr Med Assoc J. Feb. 2000;2(2):147-50. [pmid: 10804941].
Soult Rubio JA, Lopez Castilla JD. Febrile syndrome without focus. Pediatria Integral. 2006;10(4):255-62.
St Jacques DM, Barton LL, Rhee KH. Risk of serious bacterial infections in infants with bronchiolitis. [comment]. Arch Pediatr Adolesc Med. Aug. 1998;152(8):819-20. [pmid: 9701147].
Stalnikowicz R, Block C. The yield of blood cultures in a department of emergency medicine. Eur J Emerg Med. Jun. 2001;8(2):93-7. [pmid: 11436922].
Stoll ML, Rubin LG. Incidence of occult bacteremia among highly febrile young children in the era of the pneumococcal conjugate vaccine: a study from a Children's Hospital Emergency Department and Urgent Care Center. Arch Pediatr Adolesc Med. Jul. 2004;158(7):671-5. [pmid: 15237067].
Stovall SH, Schutze GE. Meningococcal infections in children from Arkansas. Pediatr Infect Dis J. May. 2002;21(5):366-70. [pmid: 12150169].
Strait RT, Ruddy RM, Friedland LR, et al. A pilot study of the predictive value of plasma tumor necrosis factor alpha and interleukin 1 beta for Streptococcus pneumoniae bacteremia in febrile children. Acad Emerg Med. Jan. 1997;4(1):44-51. [pmid: 9110011].
Stutman HR. Clinical experience with aztreonam for treatment of infections in children. [Review] [20 refs]. Rev Infect Dis. May. Suppl 7. 1991;13:S582-S585. [pmid: 2068462].
Surpure JS. Hyperpyrexia (temperature greater than 40 C) in children. JACEP. Apr. 1979;8(4):130-3. [pmid: 430938].
Suzuki N, Morimoto A, Ohga S, et al. Characteristics of hemophagocytic lymphohistiocytosis in neonates: a nationwide survey in Japan. J Pediatr. Aug. 2009;155(2):235-8. [pmid: 19446847].
Tan TQ. Procalcitonin in young febrile infants for the detection of serious bacterial infections: is this the “holy grail”?. Pediatrics. Nov. 2008;122(5):1117-8. [pmid: 18977993].
Taneja N, Chatterjee SS, Singh M, et al. Pediatric urinary tract infections in a tertiary care center from north India. Indian Journal of Medical Research. 2010;131:101-5. Jan. [pmid: 20167982].
Tang RB, Lee BH, Chung RL, et al. Interleukin-1beta and tumor necrosis factor-alpha in cerebrospinal fluid of children with bacterial meningitis. Childs Nerv Syst. Aug. 2001;17(8):453-6. [pmid: 11508533].
Tappin DM, Murphy AV, Mocan H, et al. A prospective study of children with first acute symptomatic E. coli urinary tract infection. Early 99mtechnetium dimercaptosuccinic acid scan appearances. Acta Paediatr Scand. Nov. 1989;78(6):923-9. [pmid: 2557721].
Tatara R, Imai H. Serum C-reactive protein in the differential diagnosis of childhood meningitis. Pediatr Int. Oct. 2000;42(5):541-6. [pmid: 11059546].
Teele DW, Pelton SI, Grant MJ, et al. Bacteremia in febrile children under 2 years of age: results of cultures of blood of 600 consecutive febrile children seen in a “walk-in” clinic. J Pediatr. Aug. 1975;87(2):227-30. [pmid: 1151561].
Tiemstra J, Miranda RL. Role of non-group a streptococci in acute pharyngitis. J Am Board Fam Med. Nov. 2009;22(6):663-9. [pmid: 19897695].
Tinsa F, Jallouli M, Ben LM, et al. Neonatal meningitis by Neisseria meningitidis B. Tunis Med. Nov. 2008;86(11):1014-5. [pmid: 19213497].
Torrijos E, Khan AJ, Bastawros M, et al. Urinary tract infections associated with otitis media in infants and children. J Natl Med Assoc. Jun. 1989;81(6):677-9. [pmid: 2746689].
Turner D, Leibovitz E, Aran A, et al. Acute otitis media in infants younger than two months of age: microbiology, clinical presentation and therapeutic approach. Pediatr Infect Dis J. Jul. 2002;21(7):669-74. [pmid: 12237601].
Urbach J, Lebenthal Y, Levy S, et al. Leukocyte adhesiveness/aggregation test (LAAT) to discriminate between viral and bacterial infections in children. Acta Paediatr. May. 2000;89(5):519-22. [pmid: 10852184].
Urinary tract infection. Paediatr Nurs. Oct. 2007;19(8):19.
Valmari P, Peltola H, Ruuskanen O, et al. Childhood bacterial meningitis: initial symptoms and signs related to age, and reasons for consulting a physician. Eur J Pediatr. Sep. 1987;146(5):515-8. [pmid: 3315686].
van Deventer SJ, Buller HR, ten Cate JW, et al. Endotoxaemia: an early predictor of septicaemia in febrile patients. Lancet. Mar. 1988;1(8586):605-9. [pmid: 2894546].
Velaphi S, Siegel JD, Wendel GD Jr., et al. Early-onset group B streptococcal infection after a combined maternal and neonatal group B streptococcal chemoprophylaxis strategy. Pediatrics. Mar. 2003;111(3):541-7. [pmid: 12612234].
Vidwan G, Geis GL. Evaluation, management, and outcome of focal bacterial infections (FBIs) in nontoxic infants under two months of age. J Hosp Med. Feb. 2010;5(2):76-82. [pmid: 20104632].
Waisman Y, Lotem Y, Hemmo M, et al. Management of children with aseptic meningitis in the emergency department. Pediatr Emerg Care. Oct. 1999;15(5):314-7. [pmid: 10532657].
Walsh-Kelly C, Nelson DB, Smith DS, et al. Clinical predictors of bacterial versus aseptic meningitis in childhood. Ann Emerg Med. Aug. 1992;21(8):910-4. [pmid: 1497155].
Waskerwitz S, Berkelhamer JE. Outpatient bacteremia: Clinical findings in children under two years with initial temperatures of 39.5degrees C or higher. J Pediatr. 1981;99(2):231-3. [pmid: 7252680].
Whitley RJ, Soong SJ, Linneman C Jr., et al. Herpes simplex encephalitis. Clinical Assessment. JAMA. Jan. 15. 1982;247(3):317-20. [pmid: 6275134].
Wilkinson M, Bulloch B, Smith M. Prevalence of occult bacteremia in children aged 3 to 36 months presenting to the emergency department with fever in the postpneumococcal conjugate vaccine era. Academic Emergency Medicine. 2009;16(3):220-5. Mar. [pmid: 19133844].
Wootton SH, Allen CH. Fever and fussiness in a 17-day-old infant. Semin Pediatr Infect Dis. Apr. 148. 2005;16(2):77-77. 149. [pmid: 15825137].
Wright PF, Thompson J, McKee KT Jr., et al. Patterns of illness in the highly febrile young child: epidemiologic, clinical, and laboratory correlates. Pediatrics. May. 1981;67(5):694-700. [pmid: 6973132].
Xinias I, Demertzidou V, Mavroudi A, et al. Bilirubin levels predict renal cortical changes in jaundiced neonates with urinary tract infection. World J Pediatr. Feb. 2009;5(1):42-5. [pmid: 19172331].
Yamazaki Y, Shiroyanagi Y, Matsuno D, et al. Predicting early recurrent urinary tract infection in pretoilet trained children with vesicoureteral reflux. Journal of Urology. 2009;182(4 Suppl):1699-702. Oct. [pmid: 19692080].
Yao TC, Chiu CY, Tsai YC, et al. Viridans streptococcal bacteremia secondary to viral gastroenteritis in a healthy infant. Pediatr Int. 2010;52(2):e108-e110. [pmid: 20500456].
Yousef AA, Fryer CJ, Chedid FD, et al. A pilot study of prophylactic ciprofloxacin during delayed intensification in children with acute lymphoblastic leukemia. Pediatr Blood Cancer. Nov. 2004;43(6):637-43. [pmid: 15390313].
Yuen SF, Ng FN, So LY. Evaluation of the accuracy of leukocyte esterase testing to detect pyuria in young febrile children: prospective study. HONG KONG MED. Mar. 2001;7(1):5-8.
Zaffanello M, Cataldi L, Brugnara M, et al. Hidden high-grade vesicoureteral reflux is the main risk factor for chronic renal damage in children under the age of two years with first urinary tract infection. Scandinavian Journal of Urology & Nephrology. 2009;43(6):494-500. [pmid: 19968584].
Zaki M, Mutari GA, Badawi M, et al. Vesicoureteric reflux in Kuwaiti children with first febrile urinary tract infection. Pediatr Nephrol. Sep. 2003;18(9):898-901. [pmid: 12883980].
Zaleznik DF, Rench MA, Hillier S, et al. Invasive disease due to group B Streptococcus in pregnant women and neonates from diverse population groups. Clin Infect Dis. Feb. 2000;30(2):276-81. [pmid: 10671328].
Zhang Y, Isaacman DJ, Wadowsky RM, et al. Detection of Streptococcus pneumoniae in whole blood by PCR. J Clin Microbiol. Mar. 1995;33(3):596-601. [pmid: 7751363].

### Study did not refer to infants presenting to ED or primary care

Adair CE, Kowalsky L, Quon H, et al. Risk factors for early-onset group B streptococcal disease in neonates: a population-based case-control study. CMAJ. Aug. 5. 2003;169(3):198-203. [pmid: 12900477].
Adams WG, Kinney JS, Schuchat A, et al. Outbreak of early onset group B streptococcal sepsis. Pediatr Infect Dis J. Jul. 1993;12(7):565-70. [pmid: 8345997].
Alpern ER, Alessandrini EA, Bell LM, et al. Occult bacteremia from a pediatric emergency department: current prevalence, time to detection, and outcome. [see comment]. Pediatrics. Sep. 2000;106(3):505-11. [pmid: 10969095].
Anand NK, Gupta AK, Mohan M, et al. Coagulase negative staphylococcal septicemia in newborns. Indian Pediatr. Nov. 1991;28(11):1241-8. [pmid: 1808044].
Andersen J, Christensen R, Hertel J. Clinical features and epidemiology of septicaemia and meningitis in neonates due to Streptococcus agalactiae in Copenhagen County, Denmark: a 10 year survey from 1992 to 2001. Acta Paediatr. Oct. 2004;93(10):1334-9. [pmid: 15499954].
Antonow JA, Hansen K, McKinstry CA, et al. Sepsis evaluations in hospitalized infants with bronchiolitis. Pediatr Infect Dis J. Mar. 1998;17(3):231-6. [pmid: 9535251].
Avner J, Crain E, Baker M. Failure to validate Rochester criteria for evaulation of febrile infants. Ambulatory Pediatric Association, 33rd annual meeting. 1993 Jun 04. 1993.
Bailis SA. More on procedures in the evaluation of the febrile pediatric patient. [comment]. Pediatr Ann. May. 1997;26(5):278. [pmid: 9150530].
Barry H. What clinical variables predict the presence of a urinary tract infection in febrile young girls aged younger than 2 years?. Evid Based Pract. Jul. 2000;3(7):8. insert.
Benador N, Siegrist CA, Gendrel D, et al. Procalcitonin is a marker of severity of renal lesions in pyelonephritis. Pediatrics. Dec. 1998;102(6):1422-5. [pmid: 9832579].
Berger RM, Berger MY, van Steensel-Moll HA, et al. A predictive model to estimate the risk of serious bacterial infections in febrile infants. Eur J Pediatr. Jun. 1996;155(6):468-73. [pmid: 8789763].
Bramer S, van Wijk FH, Mol BW, et al. Risk indicators for neonatal early-onset GBS-related disease. A case-control study. J Perinat Med. 1997;25(6):469-75. [pmid: 9494918].
Brkic S, Mustafic S, Nuhbegovic S, et al. Clinical and epidemiology characteristics of urinary tract infections in childhood. Medicinski Arhiv. 2010;64(3):135-8. [pmid: 20645503].
Carroll AE, Silverstein M. C-reactive protein?. [comment]. Pediatrics. Aug. 2002;110(2 Pt 1):422. [pmid: 12165611].
Cimolai N, Roscoe DL. Contemporary context for early-onset group B streptococcal sepsis of the newborn. Am J Perinatol. Jan. 1995;12(1):46-9. [pmid: 7710577].
Davies D. Bag urine specimens still not appropriate in diagnosing urinary tract infections in infants. Canadian Journal of Infectious Diseases. 2004;15(4):210-1.
de Goede C. The ‘bulging fontanelle’ to be included in primary care algorithms. Br J Gen Pract. Oct. 2005;55(519):802-3. [pmid: 16212857].
Doganis D, Siafas K, Mavrikou M, et al. Does early treatment of urinary tract infection prevent renal damage?. Pediatrics. Oct. 2007;120(4):e922-e928. [pmid: 17875650].
Durongpisitkul K, Gururaj VJ, Martin CF. The appropriateness of early discharge of hospitalized children with suspected sepsis. J Fam Pract. Jan. 1997;44(1):91-6. [pmid: 9010376].
El-Maghraby SM, Moneer MM, Ismail MM, et al. The diagnostic value of C-reactive protein, interleukin-8, and monocyte chemotactic protein in risk stratification of febrile neutropenic children with hematologic malignancies. J Pediatr Hematol Oncol. Mar. 2007;29(3):131-6. [pmid: 17356388].
Escobar GJ, Li DK, Armstrong MA, et al. Neonatal sepsis workups in infants >/=2000 grams at birth: a population-based study. Pediatrics. Aug. 2000;106(2 Pt 1):256-63. [pmid: 10920148].
Feder HM Jr. Can we screen febrile children for pneumonia and/or bacteremia without chest x-ray films and blood cultures?. Pediatrics. Feb. 1978;61(2):332-3. [pmid: 634705].
Gilbert GL, Garland SM. Perinatal group B streptococcal infections. Med J Aust. Jun. 11. 1983;1(12):566-71. [pmid: 6343814].
Goldman RD, Matlow A, Linett L, et al. What is the risk of bacterial meningitis in infants who present to the emergency department with fever and pyuria?. Can J Emerg Med. Nov. 2003;5(6):394-9.
Greene JW, Hara C, O'Connor S, et al. Management of febrile outpatient neonates. Clin Pediatr (Phila). Jun. 1981;20(6):375-80. [pmid: 7226692].
Its risk factors at mount sinai hospital. Canadian Pediatric Society 84^th^ Annual Conference. 2007 Jun 26. 2008.
Johnson CE, Whitwell JK, Pethe K, et al. Term newborns who are at risk for sepsis: are lumbar punctures necessary?. Pediatrics. Apr. 1997;99(4):E10. [pmid: 9099785].
Kelly MJ, Vivier PM, Panken TM, et al. Bacteremia in febrile nonneutropenic pediatric oncology patients. Pediatr Blood Cancer. 2010;54(1):83-7. [pmid: 19774640].
Kitanovski L, Jazbec J, Hojker S, et al. Diagnostic accuracy of procalcitonin and interleukin-6 values for predicting bacteremia and clinical sepsis in febrile neutropenic children with cancer. Eur J Clin Microbiol Infect Dis. Jun. 2006;25(6):413-5. [pmid: 16767494].
Koskenvuo M, Mottonen M, Rahiala J, et al. Mixed bacterial-viral infections in septic children with leukemia. Pediatr Infect Dis J. Dec. 2007;26(12):1133-6. [pmid: 18043451].
Lacour AG, Gervaix A, Zamora SA, et al. Procalcitonin, IL-6, IL-8, IL-1 receptor antagonist and C-reactive protein as identificators of serious bacterial infections in children with fever without localising signs. Eur J Pediatr. Feb. 2001;160(2):95-100. [pmid: 11271398].
Liebelt EL, Qi K, Harvey K. Diagnostic testing for serious bacterial infections in infants aged 90 days or younger with bronchiolitis. Arch Pediatr Adolesc Med. May. 1999;153(5):525-30. [pmid: 10323635].
Lieu TA, Mohle-Boetani JC, Ray GT, et al. Neonatal group B streptococcal infection in a managed care population. Perinatal Group B Streptococcal Infection Study Group. Obstet Gynecol. Jul. 1998;92(1):21-7. [pmid: 9649086].
Lin FY, Brenner RA, Johnson YR, et al. The effectiveness of risk-based intrapartum chemoprophylaxis for the prevention of early-onset neonatal group B streptococcal disease. Am J Obstet Gynecol. May. 2001;184(6):1204-10. [pmid: 11349189].
Maayan-Metzger A, Mazkereth R, Kuint J. Fever in healthy asymptomatic newborns during the first days of life. [see comment]. Arch Dis Child Fetal Neonatal Ed. Jul. 2003;88(4):F312-F314. [pmid: 12819164].
McCarthy CA, Powell KR. Screening for serious bacterial infections in young febrile infants. Arch Pediatr Adolesc Med. Mar. 2000;154(3):315-6. [pmid: 10710038].
McWilliam S, Riordan A. How to use: C-reactive protein. Arch Dis Child. Education and practice edition. 2010;95(2):55-8. [pmid: 19531523].
Melendez E, Harper MB. Utility of sepsis evaluation in infants 90 days of age or younger with fever and clinical bronchiolitis. [see comment]. Pediatr Infect Dis J. Dec. 2003;22(12):1053-6. [pmid: 14688564].
Mifsud AJ, Efstratiou A, Charlett A, et al. Early-onset neonatal group B streptococcal infection in London: 1990-1999. BJOG. Sep. 2004;111(9):1006-11. [pmid: 15327618].
Moore S, Houston K, Chellew M, et al. 53. incidence of early onset neonatal sepsis and management of.
Noel F, Wright PF, Bois G, et al. Contribution of bacterial sepsis to morbidity in infants born to HIV-infected Haitian mothers. J Acquir Immune Defic Syndr. Nov. 1. 2006;43(3):313-9. [pmid: 17079993].
Oddie S, Embleton ND. Risk factors for early onset neonatal group B streptococcal sepsis: case-control study. BMJ. Aug. 10. 2002;325(7359):308. [pmid: 12169506].
Oray-Schrom P, Phoenix C, St MD, et al. Sepsis workup in febrile infants 0-90 days of age with respiratory syncytial virus infection. [Review] [25 refs]. Pediatr Emerg Care. Oct. 2003;19(5):314-9. [pmid: 14578830].
Philipson EH, Herson VC. Intrapartum chemoprophylaxis for group B streptococcus infection to prevent neonatal disease: who should be treated?. Am J Perinatol. Nov. 1996;13(8):487-90. [pmid: 8989480].
Purcell K, Fergie J. Lack of usefulness of an abnormal white blood cell count for predicting a concurrent serious bacterial infection in infants and young children hospitalized with respiratory syncytial virus lower respiratory tract infection. Pediatr Infect Dis J. Apr. 2007;26(4):311-5. [pmid: 17414393].
Ramphal R, Grant RM, Dzolganovski B, et al. Herpes simplex virus in febrile neutropenic children undergoing chemotherapy for cancer: a prospective cohort study. Pediatr Infect Dis J. Aug. 2007;26(8):700-4. [pmid: 17848881].
Raper J. Commentary on Suprapubic bladder aspiration versus urethral catheterization in ill infants: success, efficiency, and complication rates. [original article by Pollack C et al appears in ANN EMERG MED 1994;23(2),225-9]. ENA'S Nursing Scan in Emergency Care. Jul. 1994;4(4):6.
Reid TM. Emergence of group B streptococci in obstetric and perinatal infections. Br Med J. Jun. 7. 1975;2(5970):533-5. [pmid: 1097038].
Rosenberg N, Ryckaert A. Use of thermogram in detection of meningitis. Pediatr Emerg Care. Jun. 1986;2(2):71-4. [pmid: 3786215].
Schrag SJ, Hadler JL, Arnold KE, et al. Risk factors for invasive, early-onset Escherichia coli infections in the era of widespread intrapartum antibiotic use. Pediatrics. Aug. 2006;118(2):570-6. [pmid: 16882809].
Schuchat A, aver-Robinson K, Plikaytis BD, et al. Multistate case-control study of maternal risk factors for neonatal group B streptococcal disease. The Active Surveillance Study Group. Pediatr Infect Dis J. Jul. 1994;13(7):623-9. [pmid: 7970951].
Schuchat A, Zywicki SS, Dinsmoor MJ, et al. Risk factors and opportunities for prevention of early-onset neonatal sepsis: a multicenter case-control study. Pediatrics. Jan. 2000;105(1 Pt 1):21-6. [pmid: 10617699].
Shaikh N. Acute urinary tract infection in infants and young children. CMAJ. Canadian Medical Association Journal. 2010;182(8):800-1. [pmid: 20159898].
Smith AL. Childhood bacteremia. N Engl J Med. Jun. 21. 1973;288(25):1351-2. [pmid: 4145199].
Soult Rubio JA, Lopez Castilla JD. Febrile syndrome without focus. Pediatria Integral. 2006;10(4):255-62.
Urinary tract infection. Paediatr Nurs. Oct. 2007;19(8):19.
Velaphi S, Siegel JD, Wendel GD Jr., et al. Early-onset group B streptococcal infection after a combined maternal and neonatal group B streptococcal chemoprophylaxis strategy. Pediatrics. Mar. 2003;111(3):541-7. [pmid: 12612234].
Wan KS, Liu CK, Chen LH. Primary urinary tract infection in infants: prophylaxis for uncomplicated pyelonephritis. Nephrology. Apr. 2007;12(2):178-81. [pmid: 17371343].
Whittam BM, Thomasch JR, Makari JH, et al. Febrile urinary tract infection after ureteroneocystostomy: a contemporary assessment at a single institution. Journal of Urology. 2010;183(2):688-92. Feb. [pmid: 20022039].
Yousef AA, Fryer CJ, Chedid FD, et al. A pilot study of prophylactic ciprofloxacin during delayed intensification in children with acute lymphoblastic leukemia. Pediatr Blood Cancer. Nov. 2004;43(6):637-43. [pmid: 15390313].
Zaleznik DF, Rench MA, Hillier S, et al. Invasive disease due to group B Streptococcus in pregnant women and neonates from diverse population groups. Clin Infect Dis. Feb. 2000;30(2):276-81. [pmid: 10671328].

### Not from the geographic locations specified in this review

Babay HA, Twum-Danso K, Kambal AM, et al. Bloodstream infections in pediatric patients. Saudi Med J. Oct. 2005;26(10):1555-61. [pmid: 16228055].
Falcao MC, Leone CR, D'Andrea RA, et al. Urinary tract infection in full-term newborn infants: value of urine culture by bag specimen collection. Rev Hosp Clin Fac Med Sao Paulo. May. 1999;54(3):91-6. [pmid: 10668279].
Goldraich NP, Manfroi A. Febrile urinary tract infection: Escherichia coli susceptibility to oral antimicrobials. [see comment]. Pediatr Nephrol. Mar. 2002;17(3):173-6. [pmid: 11956854].
Paganini H, Gonzalez F, Santander C, et al. Tuberculous meningitis in children: clinical features and outcome in 40 cases. Scand J Infect Dis. 2000;32(1):41-5. [pmid: 10716076].
Park HK, Jung YJ, Chae HC, et al. Comparison of Escherichia coli uropathogenic genes (kps, usp and ireA) and enteroaggregative genes (aggR and aap) via multiplex polymerase chain reaction from suprapubic urine specimens of young children with fever. Scandinavian Journal of Urology and Nephrology. 2009;43(1):51-7. [pmid: 18759167].

### Narrative or systematic review or other ineligible study designs

Baker MD, Avner JR. The Febrile Infant: What's New?. Clinical Pediatric Emergency Medicine. 2008;9(4):213-20.
Baraff LJ, Oslund S, Prather M. Effect of antibiotic therapy and etiologic microorganism on the risk of bacterial meningitis in children with occult bacteremia. [see comment]. Pediatrics. Jul. 1993;92(1):140-3. [pmid: 8516060].
Bergus G. Serious bacterial infection in children. J Fam Pract. Jun. 1997;44(6):531-2. [pmid: 9191620].
Curran J, Shah NB, Platt SL. Impact of the Rapid Influenza Test on Evaluation of the Febrile Child in the Emergency Setting. Clinical Pediatric Emergency Medicine. 2008;9(4):228-32.
Downs SM, McNutt RA, Margolis PA. Management of infants at risk for occult bacteremia: a decision analysis. [see comment]. J Pediatr. Jan. 1991;118(1):11-20. [pmid: 1986075].
Heffner VA, Gorelick MH. Pediatric Urinary Tract Infection. Clinical Pediatric Emergency Medicine. 2008;9(4):233-7.
Hogg RJ. A search for the “elusive” urinary tract infection in febrile infants. Pediatr Infect Dis J. Mar. 1987;6(3):233-4. [pmid: 3575006].
Kacica MA, Lepow ML. Meningitis: clinical presentation and workup. Pediatr Ann. 1994;23(2):69-70. [pmid: 8196983].
Kuppermann N. Diagnostic testing of the febrile neonate: It is time to collaborate. Arch Pediatr Adolesc Med. 2003;157(6):508-9. [pmid: 12796228].
Leroy S, Romanello C, Galetto-Lacour A, et al. Procalcitonin to reduce the number of unnecessary cystographies in children with a urinary tract infection: a European validation study. J Pediatr. Jan. 2007;150(1):89-95. [pmid: 17188622].
Lieu TA, Baskin MN, Schwartz JS, et al. Clinical and cost-effectiveness of outpatient strategies for management of febrile infants. Pediatrics. Jun. 1992;89(6 Pt 2):1135-44. [pmid: 1594366].
McCarthy P. Management of the febrile infant. Pediatrics. Jun. 1992;89(6 Pt 2):1251-3. [pmid: 1594384].
McCarthy PL, Bachman DT, Shapiro ED, et al. Fever without apparent source on clinical examination, lower respiratory infections in children, bacterial infections, and acute gastroenteritis and diarrhea of infancy and early childhood. Curr Opin Pediatr. Feb. 1994;6(1):105-25. [pmid: 8205167].
McCarthy PL. Fever without apparent source on clinical examination. Curr Opin Pediatr. Feb. 2002;14(1):103-11. [pmid: 11880744].
McCarthy PL. Infants with fever. [see comment][comment]. N Engl J Med. Nov. 11. 1993;329(20):1493-4. [pmid: 8413461].
Nigrovic LE, Chiang VW. Cost analysis of enteroviral polymerase chain reaction in infants with fever and cerebrospinal fluid pleocytosis. [see comment]. Arch Pediatr Adolesc Med. Aug. 2000;154(8):817-21. [pmid: 10922279].
Rubin LG. Occult bacteremia in the young febrile child. Pediatric Reviews and Communications. 1988;2(3):193-206.
Soult Rubio JA, Lopez Castilla JD. Febrile syndrome without focus. Pediatria Integral. 2006;10(4):255-62.
Turner D, Leibovitz E, Aran A, et al. Acute otitis media in infants younger than two months of age: microbiology, clinical presentation and therapeutic approach. Pediatr Infect Dis J. Jul. 2002;21(7):669-74. [pmid: 12237601].

## Key Question 6

### Did not address Key Question or ineligible population/ study design

Baker MD, Monroe KW, King WD, et al. Effectiveness of fever education in a pediatric emergency department. Pediatr Emerg Care. Sep. 2009;25(9):565-8. [pmid: 19755888].
Baker RC, Schubert CJ, Kirwan KA, et al. After-hours telephone triage and advice in private and nonprivate pediatric populations. Arch Pediatr Adolesc Med. Mar. 1999;153(3):292-6. [pmid: 10086408].
Cohen AL, Rivara FP, Davis R, et al. Compliance with guidelines for the medical care of first urinary tract infections in infants: a population-based study. Pediatrics. Jun. 2005;115(6):1474-8. [pmid: 15930206].
Crane JD, Benjamin JT. Pediatric residents' telephone triage experience: do parents really follow telephone advice?. Arch Pediatr Adolesc Med. Jan. 2000;154(1):71-4. [pmid: 10632254].
Gauthier M, Chevalier I, Sterescu A, et al. Treatment of urinary tract infections among febrile young children with daily intravenous antibiotic therapy at a day treatment center. Pediatrics. 2004;114(4):e469-e476. [pmid: 15466073].
Hemphill RR, Santen SA, Howell JM, et al. Follow-up compliance in febrile children: a comparison of two systems. Acad Emerg Med. Oct. 1998;5(10):996-1001. [pmid: 9862592].
O'Neill-Murphy K, Liebman M, Barnsteiner JH. Fever education: does it reduce parent fever anxiety?. Pediatr Emerg Care. Feb. 2001;17(1):47-51. [pmid: 11265909].
Sarrell M, Kahan E. Impact of a single-session education program on parental knowledge of and approach to childhood fever. Patient Educ Couns. Sep. 2003;51(1):59-63. [pmid: 12915281].
Vidwan G, Geis GL. Evaluation, management, and outcome of focal bacterial infections (FBIs) in nontoxic infants under two months of age. J Hosp Med. Feb. 2010;5(2):76-82. [pmid: 20104632].

### Addressed Key Questions but did not meet the age/condition criteria of this review

Baskin MN, O'Rourke EJ, Fleisher GR. Outpatient treatment of febrile infants 28 to 89 days of age with intramuscular administration of ceftriaxone. J Pediatr. Jan. 1992;120(1):22-7. [pmid: 1731019].
Bergman DA, Mayer ML, Pantell RH, et al. Does clinical presentation explain practice variability in the treatment of febrile infants?. Pediatrics. Mar. 2006;117(3):787-95. [pmid: 16510659].
Bertakis KD. The communication of information from physician to patient: a method for increasing patient retention and satisfaction. J Fam Pract. Aug. 1977;5(2):217-22. [pmid: 894226].
Camfield PR, Camfield CS, Shapiro SH, et al. The first febrile seizure--antipyretic instruction plus either phenobarbital or placebo to prevent recurrence. J Pediatr. Jul. 1980;97(1):16-21. [pmid: 7381637].
Chao JH, Kunkov S, Reyes LB, et al. Comparison of two approaches to observation therapy for acute otitis media in the emergency department. Pediatrics. May. 2008;121(5):e1352-e1356. [pmid: 18450878].
Collins KL. Ambulatory treatment of infants with presumed febrile urinary tract infection may be feasible. J Pediatr. 2010;156(1):166-7. [pmid: 20006777].
Condra CS, Parbhu B, Lorenz D, et al. Charges and complications associated with the medical evaluation of febrile young infants. Pediatr Emerg Care. 2010;26(3):186-91. [pmid: 20179660].
Crocetti M, Moghbeli N, Serwint J. Fever phobia revisited: have parental misconceptions about fever changed in 20 years?. Pediatrics. Jun. 2001;107(6):1241-6. [pmid: 11389237].
Dore-Bergeron MJ, Gauthier M, Chevalier I, et al. Urinary tract infections in 1- to 3-month-old infants: ambulatory treatment with intravenous antibiotics. Pediatrics. Jul. 2009;124(1):16-22. [pmid: 19564278].
Garwick AW, Patterson J, Bennett FC, et al. Breaking the news. How families first learn about their child's chronic condition. Arch Pediatr Adolesc Med. Sep. 1995;149(9):991-7. [pmid: 7655604].
Hall JA, Roter DL, Katz NR. Meta-analysis of correlates of provider behavior in medical encounters. Med Care. Jul. 1988;26(7):657-75. [pmid: 3292851].
Hoberman A, Wald ER, Hickey RW, et al. Oral versus initial intravenous therapy for urinary tract infections in young febrile children. Pediatrics. Jul. 1999;104(1 Pt 1):79-86. [pmid: 10390264].
Hoppe JE, Blumenstock G, Grotz W, et al. Compliance of German pediatric patients with oral antibiotic therapy: Results of a nationwide survey. Pediatr Infect Dis J. 1999;18(12):1085-91. [pmid: 10608630].
Johnson JE. Effects of structuring patients' expectations on their reactions to threatening events. Nurs Res. Nov. 1972;21(6):499-504. [pmid: 4485596].
Krief WI, Levine DA, Platt SL, et al. Influenza virus infection and the risk of serious bacterial infections in young febrile infants. Pediatrics. Jul. 2009;124(1):30-9. [pmid: 19564280].
Light PA, Hupcey JE, Clark MB. Nursing telephone triage and its influence on parents' choice of care for febrile children. J Pediatr Nurs. Dec. 2005;20(6):424-9. [pmid: 16298283].
Okoromah CN, Egri-Qkwaji MT. Profile of and control measures for paediatric discharges against medical advice. Niger Postgrad Med J. Mar. 2004;11(1):21-5. [pmid: 15254567].
Oppenheim PI, Sotiropoulos G, Baraff LJ. Incorporating patient preferences into practice guidelines: management of children with fever without source. Ann Emerg Med. Nov. 1994;24(5):836-41. [pmid: 7978555].
Poehling KA, Speroff T, Dittus RS, et al. Predictors of influenza virus vaccination status in hospitalized children. Pediatrics. Dec. 2001;108(6):E99. [pmid: 11731626].
Ray BJ, Metcalf SC, Franco SM, et al. Infant sleep position instruction and parental practice: comparison of a private pediatric office and an inner-city clinic. Pediatrics. May. 1997;99(5):e12. [pmid: 9113969].
Rosenstein NE, Schuchat A. Opportunities for prevention of perinatal group B streptococcal disease: a multistate surveillance analysis. The Neonatal Group B Streptococcal Disease Study Group. Obstet Gynecol. Dec. 1997;90(6):901-6. [pmid: 9397099].
Rossi LN, Rossi G, Bossi A, et al. Behaviour and confidence of parents instructed in home management of febrile seizures by rectal diazepam. Helv Paediatr Acta. Feb. 1989;43(4):273-81. [pmid: 2708070].
Rost K, Carter W, Inui T. Introduction of information during the initial medical visit: consequences for patient follow-through with physician recommendations for medication. Soc Sci Med. 1989;28(4):315-21. [pmid: 2705004].
Roukema J, Steyerberg EW, van der LJ, et al. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. Jan. 2008;15(1):107-13. [pmid: 17947627].
Saunders NR, Tennis O, Jacobson S, et al. Parents' responses to symptoms of respiratory tract infection in their children. CMAJ. Jan. 7. 2003;168(1):25-30. [pmid: 12515781].
Stiles WB, Putnam SM, Wolf MH, et al. Interaction exchange structure and patient satisfaction with medical interviews. Med Care. Jun. 1979;17(6):667-81. [pmid: 449436].
Surpure JS. Hyperpyrexia (temperature greater than 40 C) in children. JACEP. Apr. 1979;8(4):130-3. [pmid: 430938].
Tam PY, Visintainer P, Fisher D. Response to an education program for parents about adult pertussis vaccination. Infect Control Hosp Epidemiol. Jun. 2009;30(6):589-92. [pmid: 19419326].
Tasher D, Somekh E, Dalal I. PFAPA syndrome: new clinical aspects disclosed. Archives of Disease in Childhood. Dec. 2006;(12):981-4. [pmid: 16595648].
Ventura A, Basso T, Bortolan G, et al. Home treatment of seizures as a strategy for the long-term management of febrile convulsions in children. Helv Paediatr Acta. 1982;37(6):581-7. [pmid: 7166492].
Wasserman RC, Inui TS, Barriatua RD, et al. Pediatric clinicians' support for parents makes a difference: an outcome-based analysis of clinician-parent interaction. Pediatrics. Dec. 1984;74(6):1047-53. [pmid: 6504624].
Williams LL, Wilimas JA, Harris SC, et al. Outpatient therapy with ceftriaxone and oral cefixime for selected febrile children with sickle cell disease. J Pediatr Hematol Oncol. Aug. 1996;18(3):257-61. [pmid: 8689337].
Wolf SM, Carr A, Davis DC, et al. The value of phenobarbital in the child who has had a single febrile seizure: a controlled prospective study. Pediatrics. Mar. 1977;59(3):378-85. [pmid: 840556].
Woolley FR, Kane RL, Hughes CC, et al. The effects of doctor--patient communication on satisfaction and outcome of care. Soc Sci Med. Mar. 1978;12(2A):123-8. [pmid: 653374].