# Evidence Tables

The purpose of Appendix C is to provide detailed evidence tables that depict the criteria used to determine validity for each study. Furthermore, the tables summarize the evidence described and reflect specific information discussed in the report. The tables are categorically separated and alphabetized within each category.

Table 1 Studies with combined clinical and laboratory criteria

Table 2 Clinical Criteria

Table 3 Other studies - Prevalence of SBI/IHI in Febrile Infants

Table 4 Studies with laboratory criteria

Table 5 Formal screening criteria

Table 6 Studies in Febrile infant with delayed (question 2a) or immediate (question 3a) treatment

Table 7 Co-infection in febrile infants (studies assessing risk of SBI in infants with or without other infections)

Table 8 KQ6 Included studies reporting on relevant outcomes for infants 0 – 6 months of age