# Data Extraction Forms

Appendix B outlines in detail all of the questions that were used in screening the literature and ultimately determined whether a study was included or excluded. Furthermore, all data that was extracted from each study are also listed in this appendix.

## Key Questions 1–5

Level 1 Broad Screening Form

Level 2 Full Text Screening Form

Level 3 Screening by Study Design Form

Level 4 Screening by Key Question Form

## Key Question 6

Level 1 Broad Screening Form

Level 2 Full Text Screening Form