# Search Strategies

Appendix A lists the exact search strings used for each database included in the search of the literature for this review. This search strategy was divided into two separate searches. Key questions 1-5 were combined in one search and Key question 6 was searched separately due to the different databases targeted.

## Key Questions 1–5

### MEDLINE (1950 to September 21 2010)

1. exp fever/
2. (fever$ or febrile or pyrexi$).tw.
3. 1 or 2
4. exp bacteremia/
5. exp meningitis, bacterial/.
6. exp urinary tract infections/
7. exp herpes simplex/
8. (bacteremia or bacteraemia).tw.
9. (bacteria$ adj3 meningitis).tw.
10. (urinary adj2 tract$ adj3 infection$).tw.
11. (herpes adj2 simplex).tw.
12. ((severe or serious) adj3 bacteria$ adj4 (infection$ or illness$)).tw.
13. 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14. exp “sensitivity and specificity”/
15. exp diagnostic errors/
16. predicti$.tw.
17. sensitivity.tw.
18. specificity.tw.
19. (roc adj curve$).tw.
20. (false adj2 negative$).tw.
21. (false adj2 positive$).tw.
22. 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. exp “signs and symptoms”/
24. exp physical examination/
25. exp medical history taking
26. (ill adj2 appear$).tw.
27. (clinical adj2 examin$).tw.
28. (medical adj2 histor$).tw.
29. (rochester adj4 criteri$).tw.
30. (philadelphia adj4 protocol$).tw.
31. (milwaukee adj3 protocol$).tw.
32. exp Clinical Protocols/
33. “Severity of Illness Index”/
34. (scoring adj2 instrument$).tw.
35. exp risk/
36. risk$.tw.
37. 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36
38. 3 and 13 and 22 and 37
39. limit 38 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
40. (infant$ or newborn$ or neonate$).tw.
41. 38 and 40
42. limit 41 to (english language and yr=“1973 - 2008”)
43. 39 or 42
44. exp clinical laboratory techniques/
45. exp “laboratory techniques and procedures”/
46. exp diagnostic tests, routine/
47. (complete adj2 blood adj3 count$).tw.
48. urine.tw.
49. Urinalysis/
50. urinalysis.tw.
51. (diagnosis or blood or urine or cerebrospinal fluid).fs,sh.
52. 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51
53. 37 or 52
54. 3 and 13 and 22 and 53
55. limit 54 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
56. 40 and 54
57. limit 56 to (english language and yr=“1973 - 2008”)
58. 55 or 57
59. exp time/
60. ((diagnos$ or therap$ or treatment$) adj3 (interval$ or delay$)).tw.
61. (immediate adj3 (treatment$ or therap$ or diagnos$)).tw.
62. (diagnosis or drug therapy or therapy).fs,sh.
63. 59 and 62
64. 60 or 61 or 63
65. 3 and 13 and 64
66. limit 65 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
67. 40 and 65
68. limit 67 to (english language and yr=“1973 - 2008”)
69. 66 or 68
70. Harm Reduction/
71. harm$.tw.
72. benefi$.tw.
73. exp prognosis/
74. ((treatment or therap$) adj2 outcome$).tw.
75. no-observed-adverse-effect level/
76. adverse effects.fs.
77. adverse.tw.
78. contraindications.fs.
79. Medication Errors/
80. 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79
81. exp anti-bacterial agents/
82. exp antiviral agents/
83. Antibiotic Prophylaxis/
84. (antibacteria$ or antivirus$ or antiviral$).tw.
85. 81 or 82 or 83 or 84
86. 3 and 13 and 80 and 85
87. limit 86 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
88. limit 87 to english language
89. 40 and 86
90. limit 89 to (english language and yr=“1973 - 2008”)
91. 88 or 90
92. Mothers/
93. (mother$ or maternal).tw.
94. ((medical or clinical) adj2 histor$).tw.
95. 93 and 94
96. 53 or 95
97. 3 and 13 and 22 and 96
98. limit 97 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
99. limit 98 to english language
100. 40 and 97
101. limit 100 to yr=“1973 - 2008”
102. limit 101 to english language
103. 99 or 102
104. Ambulatory Care/
105. Outpatients/
106. ambulatory.tw.
107. outpatient$.tw.
108. exp primary care/
109. Physicians' Offices/
110. Physicians, Family/
111. (primary adj2 care).tw.
112. (doctor$ adj2 office$).tw.
113. (doctor$ adj2 office$).tw.
114. exp Community Health Services/
115. Emergencies/
116. exp Emergency Medical Services/
117. emergenc$.tw.
118. 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 or 113 or 114 or 115 or 116 or 117
119. prevalence/
120. prevalen$.tw.
121. Epidemiology/
122. epidemiology.fs,tw.
123. exp epidemiologic studies/
124. 119 or 120 or 121 or 122
125. 3 and 13 and 118 and 124
126. limit 125 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
127. limit 126 to english language
128. 40 and 125
129. limit 128 to (english language and yr=“1973 - 2008”)
130. 127 or 129
131. 3 and 13 and 53 and 124
132. limit 131 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
133. limit 132 to english language
134. 40 and 131
135. limit 134 to (english language and yr=“1973 - 2008”)
136. 133 or 135
137. 43 or 58 or 69 or 91 or 103 or 130 or 136
138. 3 and 13
139. limit 138 to (english language and yr=“1973 - 2008” and “all infant (birth to 23 months)”)
140. 40 and 138 (656)
141. limit 140 to (english language and yr=“1973 - 2008”) (539)
142. 139 or 141 (1470)
143. from 137 keep 1-757 (757

### EMBASE (1980 to September 21 2010)

1. exp fever/
2. (fever$ or febrile or pyrexi$).tw.
3. 1 or 2
4. exp bacteremia/
5. exp meningitis, bacterial/
6. exp urinary tract infections/
7. exp herpes simplex/
8. (bacteremia or bacteraemia).tw.
9. (bacteria$ adj3 meningitis).tw.
10. (urinary adj2 tract$ adj3 infection$).tw.
11. (herpes adj2 simplex).tw.
12. ((severe or serious) adj3 bacteria$ adj4 (infection$ or illness$)).tw.
13. 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14. exp “sensitivity and specificity”/
15. exp diagnostic errors/
16. predicti$.tw.
17. sensitivity.tw.
18. specificity.tw.
19. (roc adj curve$).tw.
20. (false adj2 negative$).tw.
21. (false adj2 positive$).tw.
22. 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. exp “signs and symptoms”/
24. exp physical examination/
25. exp medical history taking/
26. (ill adj2 appear$).tw.
27. (clinical adj2 examin$).tw.
28. (medical adj2 histor$).tw.
29. (rochester adj4 criteri$).tw.
30. (philadelphia adj4 protocol$).tw.
31. (milwaukee adj3 protocol$).tw.
32. exp Clinical Protocols/
33. “Severity of Illness Index”/
34. (scoring adj2 instrument$).tw.
35. exp risk/
36. risk$.tw.
37. 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36
38. 3 and 13 and 22 and 37
39. limit 38 to (english language and yr=“1980 - 2008” and infant <to one year>)
40. (infant$ or newborn$ or neonate$).tw.
41. 38 and 40
42. limit 41 to (english language and yr=“1980 - 2008”)
43. 39 or 42
44. exp “diagnosis, measurement and analysis”/
45. (complete adj2 blood adj3 count$).tw.
46. urine.tw.
47. urinalysis.tw.
48. diagnosis.sh.
49. blood.sh.
50. urine.sh.
51. cerebrospinal fluid.sh.
52. 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51
53. 37 or 52
54. 3 and 13 and 22 and 53
55. limit 54 to (english language and yr=“1980 - 2008” and infant <to one year>)
56. 40 and 54
57. limit 56 to (english language and yr=“1980 - 2008”)
58. 55 or 57
59. exp time/
60. ((diagnos$ or therap$ or treatment$) adj3 (interval$ or delay$)).tw.
61. (immediate adj3 (treatment$ or therap$ or diagnos$)).tw.
62. (diagnosis or drug therapy or therapy).sh,tw.
63. 59 and 62
64. 60 or 61 or 63
65. 3 and 13 and 64
66. limit 65 to (english language and yr=“1980 - 2008” and infant <to one year>)
67. 40 and 65
68. limit 67 to (english language and yr=“1980 - 2008”)
69. 66 or 68
70. harm reduction/
71. harm$.tw.
72. prognosis/
73. ((treatment or therap$) adj2 outcome$).tw.
74. exp Adverse Drug Reaction/
75. Side Effect/
76. adverse.tw.
77. contraindicat$.tw.
78. exp Medication Error/
79. benefi$.tw.
80. 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79
81. Antiinfective Agent/
82. (antibacteria$ or antiviral or antivirus or antibiotic$).tw.
83. 81 or 82
84. 3 and 13 and 80 and 83
85. limit 84 to (english language and yr=“1980 - 2008” and infant <to one year>)
86. 40 and 84
87. limit 86 to (english language and yr=“1980 - 2008”)
88. 85 or 87
89. mother/
90. (mother$ or maternal).tw.
91. ((medical or clinical) adj2 histor$).tw.
92. 89 or 90
93. 91 and 92
94. 53 or 93
95. 3 and 13 and 22 and 94
96. limit 95 to (english language and yr=“1980 - 2008” and infant <to one year>)
97. 40 and 95
98. limit 97 to (english language and yr=“1980 - 2008”)
99. 96 or 98
100. exp ambulatory care/
101. outpatient/
102. ambulatory.tw.
103. outpatient$.tw.
104. outpatient care/ or primary medical care/ or private practice/
105. general practitioner/
106. (primary adj2 care).tw.
107. (doctor$ adj2 office$).tw.
108. Community Care/
109. Emergency/
110. emergency health service/
111. emergenc$.tw.
112. 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111
113. prevalen$.tw.
114. exp epidemiology/
115. epidemiology.tw.
116. 113 or 114 or 115
117. 3 and 13 and 112 and 116
118. limit 117 to (english language and yr=“1980 - 2008” and infant <to one year>)
119. 40 and 117
120. limit 119 to (english language and yr=“1980 - 2008”)
121. 118 or 120
122. 43 or 58 or 69 or 88 or 99 or 121
123. 3 and 13
124. limit 123 to (english language and yr=“1980 - 2008” and infant <to one year>)
125. 40 and 123
126. limit 125 to (english language and yr=“1980 - 2008”)
127. 124 or 126
128. from 122 keep 1-268

### EBM Reviews – Cochrane Central Register of Controlled Trials (1^st^ Quarter 2008)

1. exp fever/
2. (fever$ or febrile or pyrexi$).tw.
3. 1 or 2
4. exp bacteremia/
5. exp meningitis, bacterial/
6. exp urinary tract infections/
7. exp herpes simplex/
8. (bacteremia or bacteraemia).tw.
9. (bacteria$ adj3 meningitis).tw
10. (urinary adj2 tract$ adj3 infection$).tw.
11. (herpes adj2 simplex).tw.
12. ((severe or serious) adj3 bacteria$ adj4 (infection$ or illness$)).tw.
13. 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14. exp “sensitivity and specificity”/
15. exp diagnostic errors/
16. predicti$.tw.
17. sensitivity.tw.
18. specificity.tw.
19. (roc adj curve$).tw.
20. (false adj2 negative$).tw.
21. (false adj2 positive$).tw.
22. 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. exp “signs and symptoms”/
24. exp physical examination/
25. exp medical history taking/
26. (ill adj2 appear$).tw.
27. (clinical adj2 examin$).tw.
28. (medical adj2 histor$).tw.
29. (rochester adj4 criteri$).tw.
30. (philadelphia adj4 protocol$).tw.
31. (milwaukee adj3 protocol$).tw.
32. exp Clinical Protocols/
33. “Severity of Illness Index”/
34. (scoring adj2 instrument$).tw.
35. exp risk/
36. risk$.tw.
37. 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36
38. 3 and 13 and 22 and 37
39. limit 38 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
40. (infant$ or newborn$ or neonate$).tw.
41. 38 and 40
42. limit 41 to (english language and yr=“1973 - 2008”)
43. 39 or 42
44. exp clinical laboratory techniques/
45. exp “laboratory techniques and procedures”/
46. exp diagnostic tests, routine/
47. (complete adj2 blood adj3 count$).tw.
48. urine.tw.
49. Urinalysis/
50. urinalysis.tw.
51. (diagnosis or blood or urine or cerebrospinal fluid).fs,sh.
52. 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51
53. 37 or 52
54. 3 and 13 and 22 and 53
55. limit 54 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
56. 40 and 54
57. limit 56 to (english language and yr=“1973 - 2008”)
58. 55 or 57
59. exp time/
60. ((diagnos$ or therap$ or treatment$) adj3 (interval$ or delay$)).tw.
61. (immediate adj3 (treatment$ or therap$ or diagnos$)).tw.
62. (diagnosis or drug therapy or therapy).fs,sh.
63. 59 and 62
64. 60 or 61 or 63
65. 3 and 13 and 64
66. limit 65 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
67. 40 and 65
68. limit 67 to (english language and yr=“1973 - 2008”)
69. 66 or 68
70. Harm Reduction/
71. harm$.tw.
72. benefi$.tw.
73. exp prognosis/
74. ((treatment or therap$) adj2 outcome$).tw.
75. no-observed-adverse-effect level/
76. adverse effects.fs.
77. adverse.tw.
78. contraindications.fs.
79. Medication Errors/
80. 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79
81. exp anti-bacterial agents/
82. exp antiviral agents/
83. Antibiotic Prophylaxis/
84. (antibacteria$ or antivirus$ or antiviral$).tw.
85. 81 or 82 or 83 or 84
86. 3 and 13 and 80 and 85
87. limit 86 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
88. limit 87 to english language
89. 40 and 86
90. limit 89 to (english language and yr=“1973 - 2008”)
91. 88 or 90
92. Mothers/
93. (mother$ or maternal).tw.
94. ((medical or clinical) adj2 histor$).tw.
95. 93 and 94
96. 53 or 95
97. 3 and 13 and 22 and 96
98. limit 97 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
99. limit 98 to english language
100. 40 and 97
101. limit 100 to yr=“1973 - 2008”
102. limit 101 to english language
103. 99 or 102
104. Ambulatory Care/
105. Outpatients/
106. ambulatory.tw.
107. outpatient$.tw.
108. exp primary care/
109. Physicians' Offices/
110. Physicians, Family/
111. (primary adj2 care).tw.
112. (doctor$ adj2 office$).tw.
113. (doctor$ adj2 office$).tw.
114. exp Community Health Services/
115. Emergencies/
116. exp Emergency Medical Services/
117. emergenc$.tw.
118. 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 or 113 or 114 or 115 or 116 or 117
119. prevalence/
120. prevalen$.tw.
121. Epidemiology/
122. epidemiology.fs,tw.
123. exp epidemiologic studies/
124. 119 or 120 or 121 or 122
125. 3 and 13 and 118 and 124
126. limit 125 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
127. limit 126 to english language
128. 40 and 125
129. limit 128 to (english language and yr=“1973 - 2008”)
130. 127 or 129
131. 3 and 13 and 53 and 124
132. limit 131 to (yr=“1973 - 2008” and “all infant (birth to 23 months)”)
133. limit 132 to english language
134. 40 and 131
135. limit 134 to (english language and yr=“1973 - 2008”)
136. 133 or 135
137. 43 or 58 or 69 or 91 or 103 or 130 or 136
138. 3 and 13
139. limit 138 to (english language and yr=“1973 - 2008” and “all infant (birth to 23 months)”)
140. 40 and 138
141. limit 140 to (english language and yr=“1973 - 2008”)
142. 139 or 141

### Pubmed

#55 OR #56 Limits: Entrez Date from 1973 to Current

#55 OR #56

#46 AND #53 Limits: Humans, All Infant: birth-23 months

#46 AND #53

(Multicenter Study[ptyp] OR Randomized Controlled Trial[ptyp] OR Controlled Clinical Trial[ptyp]) OR (random*[tiab] OR RCT[tiab] OR RCTs[tiab] OR sham*[tiab] OR placebo*[tiab]) OR (single blind*[tiab] OR single dumm*[tiab] OR single mask*[tiab]) OR

#49 OR #51

#48 AND #50

infant [mesh] OR infant [tiab] OR infants [tiab] OR newborn* [tiab] OR neonate* [tiab]

#48 Limits: Humans, All Infant: birth-23 months

#46 AND #47

((meta-analysis[ptyp] OR Meta-Analysis[MeSH]) OR (meta analy*[tiab] OR metaanaly*[tiab] OR met analy*[tiab] OR metanaly*[tiab] OR integrative research[tiab] OR integrative review*[tiab] OR integrative overview*[tiab] OR reintegration*[tiab] OR reoverview*[tiab] OR collaborative review*[tiab] OR collaborative overview*[tiab]) OR (quantitative review*[tiab] OR quantitative overview*[tiab] OR quantitative synthes*[tiab] OR systematic literature review*[tiab] OR systematic review*[tiab] OR systematic overview*[tiab] OR methodologic literature review*[tiab] OR methodologic review*[tiab] OR methodologic overview*[tiab]) OR (“technology assessment, biomedical”[MeSH Terms]) OR (health technology assessment*[tiab] OR biomedical technology assessment*[tiab] OR HTA[tiab] OR HTAs[tiab]) OR (systematic[sb]))

#21 AND #45

#22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44

Urinalysis [mesh] OR Spinal Puncture [mesh] OR urinalysis [tiab] OR spinal puncture* [tiab] OR lumbar puncture [tiab]

Diagnostic Errors [mesh] OR diagnostic error* [tiab] OR diagnostic mistake* [tiab] OR mistaken diagnos* [tiab] OR “error in diagnosis” [tiab] OR “error in diagnoses” [tiab] OR “errors in diagnosis” [tiab] OR “errors in diagnoses” [tiab] OR incorrect diagnosis [tiab] OR incorrect diagnoses [tiab]

diagnostic test [tiab] OR diagnostic tests [tiab] OR diagnostic procedure* [tiab] OR diagnostic evaluation* [tiab] OR diagnostic investigation* [tiab] OR diagnostic work* [tiab] OR diagnostic workup* [tiab] OR diagnostic work-up* [tiab] OR diagnostic result* [tiab]

laboratory test [tiab] OR laboratory tests [tiab] OR lab test [tiab] OR lab tests [tiab] OR laboratory work* [tiab] OR lab work* [tiab] OR laboratory workup* [tiab] OR laboratory work-up* [tiab] OR lab workup* [tiab] OR lab work-up* [tiab] OR laboratory investigation* [tiab] OR laboratory evaluation* [tiab] OR laboratory result* [tiab] OR lab result* [tiab] OR Culture method* [tiab] OR culturing method* [tiab] OR sepsis workup [tiab] OR sepsis work-up* [tiab]

Practice Guideline Field: Publication Type

Practice Guidelines as Topic [mesh] OR Algorithms [mesh] OR Decision Trees [tiab] OR cpg [tiab] OR cpgs [tiab] OR practice guideline* [tiab] OR practice protocol* [tiab] OR clinical guideline* [tiab] OR clinical protocol* [tiab] OR algorithm* [tiab] OR decision tree* [tiab] OR decision-making [tiab] OR clinical decision* [tiab]

(Test [tiab] OR tests [tiab] OR testing [tiab] OR culture* [tiab] OR specimen* [tiab] OR workup* [tiab] OR work-up* [tiab]) AND (cerebrospinal fluid* [tiab] OR CSF [tiab] OR spinal fluid* [tiab] OR blood [tiab] OR WBC [tiab] OR CBC [tiab] OR c-reactive protein* [tiab] OR CRP [tiab] OR procalcitonin [tiab] OR PCP [tiab] OR interleukin-6 [tiab] OR IL-6 [tiab] OR urine [tiab] OR stool [tiab])

“Sensitivity and Specificity” [mesh] OR sensitivity [tiab] OR specificity [tiab] OR “predictive value of tests” [tiab] OR false negative* [tiab] OR false positive* [tiab] OR ROC curve* [tiab] OR Receiver Operating Characteristic* [tiab] OR ROC analys* [tiab]

Risk [mesh] OR risk [tiab] OR risks [tiab] OR predicti* [tiab]

Diagnosis, Differential [mesh] OR differential diagnosis [tiab] OR differential diagnoses [tiab] OR delayed diagnosis [tiab] OR delayed diagnoses [tiab]

Laboratory Techniques and Procedures [mesh]

Severity of Illness Index [mesh] OR “Severity of Illness Index” [tiab] OR “severity of illness indexes” [tiab] OR “severity of illness indices” [tiab]

Philadelphia Criteri* [tiab] OR Rochester criteri* [tiab] OR Yale Observation Scale [tiab] OR Young Infant Observation Scale [tiab]

medical history [tiab] OR clinical history [tiab] OR physical examination* [tiab] OR physical exam [tiab] OR physical exams [tiab] OR clinical exam [tiab] OR clinical exams [tiab] OR clinical examination* [tiab] OR medical exam [tiab] OR medical exams [tiab] OR medical examination* [tiab] OR clinical evaluation* [tiab] OR medical evaluation* [tiab] OR physical evaluation* [tiab] OR clinical symptom* [tiab] OR medical symptom* [tiab] OR physical symptom* [tiab]

Physical Examination [mesh]

Medical History Taking [mesh]

“Herpes Simplex/diagnosis” [mesh]

“Osteomyelitis/diagnosis” [mesh]

“Bacterial Infections/diagnosis” [mesh]

“Meningitis, Bacterial/diagnosis” [mesh]

“sepsis/diagnosis”[mesh]

(“fever/diagnosis”[MeSH Terms] OR “fever/etiology”[MeSH Terms])

Diagnosis [mesh]

#3 AND #20

#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19

Herpesvirus hominis [tiab] AND (serious [tiab] OR severe [tiab] OR invasive [tiab])

(HSV* [tiab] OR herpes simplex [tiab]) AND (serious [tiab] OR severe [tiab] OR invasive [tiab])

IHI [tiab]

Herpes Simplex [mesh] AND (serious [tiab] OR severe [tiab] OR invasive [tiab])

osteomyelitis [mesh] OR osteomyelitis [tiab]

Listeria Infection* [tiab] AND (serious [tiab] OR severe [tiab] OR invasive [tiab])

Gram negative [tiab] AND bacteria* [tiab] AND infection* [tiab]

Gram-Negative Bacterial Infections [mesh]

Gram positive [tiab] AND bacteria* [tiab] AND infection* [tiab]

Gram-Positive Bacterial Infections [mesh]

meningitis [tiab] AND (bacteria* [tiab] OR listeria* [tiab] OR escherichia [tiab] OR Haemophilus [tiab] OR Hemophilus [tiab] OR meningococc* [tiab] OR pneumococc* [tiab] OR tuberculo* [tiab])

Meningitis, Bacterial [mesh]

sepsis [tiab] OR septicemia [tiab] OR septicaemia [tiab]

urinary tract infections [mesh] OR UTI [tiab] OR UTIs [tiab] OR urinary tract infection* [tiab] OR urinary infection* [tiab] OR urinary tract inflammation* [tiab]

serious bacterial infection* [tiab] OR severe bacterial infection* [tiab] OR invasive bacterial infection* [tiab] OR rare bacterial infection* [tiab] OR SBI [tiab] OR SBIs [tiab] OR serious infection* [tiab] OR severe infection* [tiab] OR invasive infection* [tiab] OR rare infection* [tiab]

Sepsis [mesh]

#1 OR #2

Fever [tiab] OR fevers [tiab] OR feverish [tiab] OR febril* [tiab] OR febricity [tiab] OR pyrexi* [tiab]

Fever [MeSH]

## Key Question 6

### CINAHL (1982 to May 13 2008)

1. exp FEVER/
2. (Fever or fevers or feverish or febril$ or febricity or pyrexi$).ti,ab.
3. exp SEPSIS/
4. (sepsis or septicemia or septicaemia).ti,ab.
5. (serious bacterial infection$ or severe bacterial infection$ or invasive bacterial infection$ or rare bacterial infection$ or SBI or SBIs or serious infection$ or severe infection$ or invasive infection$ or rare infection$).ti,ab.
6. (serious illness* or serious condition* or serious medical illness* or serious medical condition*).ti,ab.
7. exp Urinary Tract Infections/
8. (UTI or UTIs or urinary tract infection$ or urinary infection$ or urinary tract inflammation$).ti,ab.
9. exp Meningitis, Bacterial/
10. ((meningitis or meningitides or meningeal) adj3 (bacteria$ or listeria$ or escherichia or Haemophilus or Hemophilus or meningococc$ or pneumococc$ or tuberculo$)).ti,ab.
11. exp Gram-Positive Bacterial Infections/
12. (Gram positive adj2 bacteria$ infection$).ti,ab.
13. exp Gram-Negative Bacterial Infections/
14. (Gram negative adj2 bacteria$ infection$).ti,ab.
15. (listeria infection$ adj3 (serious or severe or invasive)).ti,ab.
16. exp OSTEOMYELITIS/
17. osteomyelitis.ti,ab.
18. exp Herpes Simplex/
19. (Herpes Simplex or HSV or Herpesvirus hominis).ti,ab.
20. (serious or severe or invasive).ti,ab.
21. 18 or 19
22. 20 and 21
23. IHI.ti,ab.
24. exp pneumonia/
25. (pneumonia or pneumonitis or pulmonary inflammation* or lung inflammation or bronchopneumonia or pleuropneumonia).ti,ab.
26. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 22 or 23 or 24 or 25
27. limit 26 to (newborn infant <birth to 1 month> or infant <1 to 23 months>)
28. (infant or infants or newborn$ or neonate$).ti,ab.
29. 26 and 28
30. 28 or 29
31. exp CAREGIVERS/
32. exp PARENTS/
33. (Caregiver$ or care giver$ or caretaker$ or care-taker$ or parent$ or stepparent$ or step-parent$ or father$ or mother$ or stepmother$ or stepfather$ or step-mother$ or step-father$).ti,ab.
34. 31 or 32 or 33
35. exp Office Visits/ or exp “Continuity of Patient Care”/
36. ((visit or visits or appointment$ or clinic or clinics or outpatient) and (repeat$ or return$ or recommend$)).ti,ab.
37. (reassessment* or recall* or follow-up or followup or watchful waiting or expectant management).ti,ab.
38. (continuity adj3 care).ti,ab.
39. or/35-38
40. exp Patient Compliance/
41. (comply or complies or compliant or compliance or noncomply or noncompliant or noncompliance or non-compliant or non-compliance or adherent or adherence or nonadherence or non-adherence).ti,ab.
42. (caregiver$ acceptance or caregiver$ attitude$ or caregiver$ responsibilit$ or caregiver$ behavi$ or caretaker$ acceptance or caretaker$ attitude$ or caretaker$ responsibilit$ or caretaker$ behavi$ or care-giver$ acceptance or care-giver$ attitude$ or care-giver$ responsibilit$ or care-giver$ behavi$ or care-taker$ acceptance or care-taker$ attitude$ or care-taker$ responsibilit$ or care-taker$ behavi$).ti,ab.
43. (parent$ acceptance$ or parent$ attitude$ or parent$ responsibilit$ or parent$ behavi$ or patient$ acceptance or patient$ attitude$ or patient$ responsibilit$ or patient$ behavi$).ti,ab.
44. exp Attitude to Health/
45. ((Health adj3 attitude$) or health belief$).ti,ab.
46. 40 or 41 or 42 or 43 or 44 or 45
47. 30 and 34 and 39 and 46

### Embase (1980 to September 22 2010)

1. exp FEVER/
2. (Fever or fevers or feverish or febril$ or febricity or pyrexi$).ti,ab.
3. exp SEPSIS/
4. (sepsis or septicemia or septicaemia).ti,ab.
5. (serious bacterial infection$ or severe bacterial infection$ or invasive bacterial infection$ or rare bacterial infection$ or SBI or SBIs or serious infection$ or severe infection$ or invasive infection$ or rare infection$).ti,ab.
6. (serious illness* or serious condition* or serious medical illness* or serious medical condition*).ti,ab.
7. exp Urinary Tract Infections/
8. (UTI or UTIs or urinary tract infection$ or urinary infection$ or urinary tract inflammation$).ti,ab.
9. exp Meningitis, Bacterial/
10. ((meningitis or meningitides or meningeal) adj3 (bacteria$ or listeria$ or escherichia or Haemophilus or Hemophilus or meningococc$ or pneumococc$ or tuberculo$)).ti,ab.
11. exp Gram-Positive Bacterial Infections/
12. (Gram positive adj2 bacteria$ infection$).ti,ab.
13. (Gram negative adj2 bacteria$ infection$).ti,ab.
14. (listeria infection$ adj3 (serious or severe or invasive)).ti,ab.
15. exp OSTEOMYELITIS/
16. osteomyelitis.ti,ab.
17. exp Herpes Simplex/
18. (Herpes Simplex or HSV or Herpesvirus hominis).ti,ab.
19. (serious or severe or invasive).ti,ab.
20. 17 or 18
21. 19 and 20
22. IHI.ti,ab.
23. exp PNEUMONIA/
24. (pneumonia or pneumonitis or pulmonary inflammation* or lung inflammation or bronchopneumonia or pleuropneumonia).ti,ab.
25. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 21 or 22 or 23 or 24
26. limit 25 to to infant <to one year>
27. (infant or infants or newborn$ or neonate$).ti,ab.
28. 25 and 27
29. 26 or 28
30. exp CAREGIVER/
31. exp PARENT/
32. (Caregiver$ or care giver$ or caretaker$ or care-taker$ or parent$ or stepparent$ or step-parent$ or father$ or mother$ or stepmother$ or stepfather$ or step-mother$ or step-father$).ti,ab.
33. 30 or 31 or 32
34. exp Ambulatory Care/
35. exp Patient Care/
36. ((visit or visits or appointment$ or clinic or clinics or outpatient) and (repeat$ or return$ or recommend$)).ti,ab.
37. (reassessment* or recall* or follow-up or followup or watchful waiting or expectant management).ti,ab.
38. (continuity adj3 care).ti,ab.
39. 34 or 35 or 36 or 37 or 38
40. exp Patient Compliance/
41. (comply or complies or compliant or compliance or noncomply or noncompliant or noncompliance or non-compliant or non-compliance or adherent or adherence or nonadherence or non-adherence).ti,ab.
42. (caregiver$ acceptance or caregiver$ attitude$ or caregiver$ responsibilit$ or caregiver$ behavi$ or caretaker$ acceptance or caretaker$ attitude$ or caretaker$ responsibilit$ or caretaker$ behavi$ or care-giver$ acceptance or care-giver$ attitude$ or care-giver$ responsibilit$ or care-giver$ behavi$ or care-taker$ acceptance or care-taker$ attitude$ or care-taker$ responsibilit$ or care-taker$ behavi$).ti,ab.
43. (parent$ acceptance$ or parent$ attitude$ or parent$ responsibilit$ or parent$ behavi$ or patient$ acceptance or patient$ attitude$ or patient$ responsibilit$ or patient$ behavi$).ti,ab.
44. exp Attitude to Health/
45. exp Patient Attitude/
46. ((Health adj3 attitude$) or health belief$).ti,ab.
47. 40 or 41 or 42 or 43 or 44 or 45 or 46
48. 29 and 33 and 39 and 47

### PsycINFO (1806 to September 22 2010)

1. exp HYPERTHERMIA/
2. (hyperthermi$ or fever or fevers or feverish or febril$ or febricity or pyrexi$).ti,ab.
3. (sepsis or septicemia or septicaemia).ti,ab.
4. (serious bacterial infection$ or severe bacterial infection$ or invasive bacterial infection$ or rare bacterial infection$ or SBI or SBIs or serious infection$ or severe infection$ or invasive infection$ or rare infection$).ti,ab.
5. (serious illness* or serious condition* or serious medical illness* or serious medical condition*).ti,ab.
6. exp urinary function disorders/
7. (UTI or UTIs or urinary tract infection$ or urinary infection$ or urinary tract inflammation$).ti,ab.
8. exp Bacterial Meningitis/
9. ((meningitis or meningitides or meningeal) adj3 (bacteria$ or listeria$ or escherichia or Haemophilus or Hemophilus or meningococc$ or pneumococc$ or tuberculo$)).ti,ab.
10. (Gram positive adj2 bacteria$ infection$).ti,ab.
11. (Gram negative adj2 bacteria$ infection$).ti,ab.
12. (listeria infection$ adj3 (serious or severe or invasive)).ti,ab.
13. osteomyelitis.ti,ab.
14. exp Herpes Simplex/
15. (Herpes Simplex or HSV or Herpesvirus hominis).ti,ab.
16. (serious or severe or invasive).ti,ab.
17. 14 or 15
18. 16 and 17
19. IHI.ti,ab.
20. exp PNEUMONIA/
21. (pneumonia or pneumonitis or pulmonary inflammation* or lung inflammation or bronchopneumonia or pleuropneumonia).ti,ab.
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 18 or 19 or 20 or 21
23. limit 22 to
24. (infant or infants or newborn$ or neonate$).ti,ab.
25. 22 and 24
26. 23 or 25
27. exp CAREGIVERS/
28. exp PARENTS/
29. (Caregiver$ or care giver$ or caretaker$ or care-taker$ or parent$ or stepparent$ or step-parent$ or father$ or mother$ or stepmother$ or stepfather$ or step-mother$ or step-father$).ti,ab.
30. 27 or 28 or 29
31. exp “Continuum of Care”/
32. ((visit or visits or appointment$ or clinic or clinics or outpatient) and (repeat$ or return$ or recommend$)).ti,ab.
33. (reassessment* or recall* or follow-up or followup or watchful waiting or expectant management).ti,ab.
34. (continuity adj3 care).ti,ab.
35. 31 or 32 or 33 or 34
36. exp compliance/
37. (comply or complies or compliant or compliance or noncomply or noncompliant or noncompliance or non-compliant or non-compliance or adherent or adherence or nonadherence or non-adherence).ti,ab.
38. (caregiver$ acceptance or caregiver$ attitude$ or caregiver$ responsibilit$ or caregiver$ behavi$ or caretaker$ acceptance or caretaker$ attitude$ or caretaker$ responsibilit$ or caretaker$ behavi$ or care-giver$ acceptance or care-giver$ attitude$ or care-giver$ responsibilit$ or care-giver$ behavi$ or care-taker$ acceptance or care-taker$ attitude$ or care-taker$ responsibilit$ or care-taker$ behavi$).ti,ab.
39. (parent$ acceptance$ or parent$ attitude$ or parent$ responsibilit$ or parent$ behavi$ or patient$ acceptance or patient$ attitude$ or patient$ responsibilit$ or patient$ behavi$).ti,ab.
40. ((Health adj3 attitude$) or health belief$).ti,ab
41. 36 or 37 or 38 or 39 or 40
42. 26 and 30 and 35 and 41