# Acronyms/Abbreviations

Clinical
ABC: absolute band count
CATH: catheterization
CBC: complete blood cell
CI: confidence interval
CRP: C-reactive protein
CSF: cerebrospinal fluid
CT: computer tomography
CXR: chest x-ray
DAS: diagnostic accuracy study
ESR: erythrocyte sedimentation rate
EV: enteroviral
GBS: group B streptococcal disease
hpf: high power field
HR: high risk (+: positive or -: negative)
HSV: herpes simplex virus
IV/I: intravenous/ injection
HSV: rare invasive herpes simplex virus infection
LE: leukocyte esterase
LR: low risk (+: positive or -: negative)
PCMC: primary children's medical center
PCR: polymerase chain reaction
PCT: procalcitonin
PMN: polymorphonuclear count
RSV: respiratory syncytial virus
SBI: serious bacterial infection/ illness
T: temperature
UA: urinalysis
UTI: urinary tract infection
WBC: white blood cell
YIOS: Young Infant Observation Scale
YOS: Yale Observation Score

Units
μg: micrograms
μg /L: micrograms per liter
μg /mL: micrograms per milliliter
μg/dL: micrograms per deciliter
μm: micromolar
μmol/L: micromoles per liter
cm: centimeters
cm/s: centimeters/second
Ibs: pounds
IU/L: international units per liter
IU/L: international units per liter
kg: kilograms
kg/m^2^: kilograms per meter squared
m: meters
mg: milligrams
mg/d: milligrams per day
mL: millilitre
mmol/L: millimoles per liter
N: sample size
ng/dL: nanogram per deciliter
ng/L: nanogram per liter
ng/mL: nanograms per milliliter
nmol/L: nanomoles per liter
pg/mL: picograms per milliliter
pmol/L: picomoles per liter
° F: degrees Fahrenheit
° C: degrees Celsius

Statistics
ARD: absolute risk difference
CCT: controlled clinical trial
CI: confidence interval
IQR: interquartile range
LS: least square
NS: not significant
RCT: randomized controlled trial
S/sign.: significant
SD: standard deviation
SE/SEM: standard error
WMD: weighted mean difference
ROC (AUC): receiver operating characteristic (area under the curve)
LR: likelihood ratio
PPV: positive predictive value
NPV: negative predictive value

Commonly Used Abbreviations
#: number
%: percent
<: greater than
< or </=+: less than or equal to and
>: less than
> or >/=: greater than or equal to
▲/↑ or ▼/↓: increased, or decreased,
CG: control group
grp: group/s
ctrls: controls
d: day
Deg or °: degrees
Dept.: department
F: female
f/u: followup
FHx: family history
hr: hour
Hx: history
IG: intervention group
M: male
max: maximum
min: minimum
mo: month
NA: not applicable
NIH: National Institutes of Health
NR: not reported
Q: question
Tx: treatment
vs.: versus
wks: weeks
y: year