# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Chantelle Garritty for her role in the management of the project, Janet Joyce for her help in the initial search of evidence, and Tammy Jakobsen and Beverly McLaren for their assistance with the administrative support of this project. David Moher, Ph.D., is director of the University of Ottawa Evidence-based Practice Center.