# Results

Our literature searches for prostate cancer systematic reviews, for large registry databases, and for AS/WW publications yielded 707, 647, and 821 citations, respectively. From these, 914 articles were provisionally accepted for review based on the abstracts and titles. Additional citations recommended by technical expert panel, from reference lists of relevant systematic reviews, or identified through targeted searches of the Cost-Effectiveness Analysis Registry, were also accepted for review. After full-text screening, 195 papers and 4 evidence/economic reports met criteria and are included in the review (Figure 2).

Figure 2 Literature flow

The numbers of studies for each Key Question do not sum to the total number of included studies because some studies addressed multiple Key Questions. AS = active surveillance; CDSR = Cochrane Database of Systematic Reviews; HTA = Health Technology Assessment; CCRCT = Cochrane Central Register of Controlled Trials; CEA Registry = cost effectiveness analysis registry; EPC = Evidence-based Practice Center; ICER = Institute for Clinical and Economic Reviews; TEP = technical expert panel; RCTs = randomized controlled trials; WW = watchful waiting.

Figure 2 is a flow diagram that summarizes this project's literature search strategy, including the study selection process and its results. Searches for prostate cancer systematic reviews, large registry databases, and active surveillance/watchful waiting (AS/WW) publications yielded 707, 647, and 821 citations, respectively. From these, 948 articles were provisionally accepted for review based on their abstracts and titles. Additional citations recommended by the technical expert panel or from reference lists of relevant systematic reviews were also accepted for review. After screening their full texts, 782 articles were rejected for not meeting eligibility criteria. In total, 193 articles met criteria and were reviewed. Of these, 79 primary studies and 1 systematic review were included in Key Question 1 (natural history); 35 unique cohorts (in 56 publications) were included in Key Question 2 (AS/WW definition); 41 primary studies and 1 systematic review were included in Key Question 3 (factors); and finally 2 randomized controlled trials (4 publications), 16 cohort studies, 2 EPC reports, and 2 ICER reprots were included in Key Question 4 (AS vs. treatment).

## Key Question 1 How have the patient population and the natural history of prostate cancer diagnosed in the United States changed in the last 30 years?

Prostate cancer epidemiology is affected by population-level trends, such as the aging of the United States population, but also by changes in the application of screening and diagnostic technologies among the population at risk. To assess temporal trends in the incidence, mortality/survival, disease features at diagnosis, and treatment patterns we performed a search to identify large studies (≥1000 men) utilizing databases sourced from the U.S. population that provided information stratified by factors relevant to Key Question 1 (see the end of the Introduction for the list of factors). We also reviewed the latest version of the Cancer Statistics report prepared annually by the American Cancer Society^1^, a recent SEER Survival Monograph^2^, the 2009/2010 update of the Cancer Trends Progress Report^3^, and data available on the SEER Web site.^a^

a Available at http://seer.cancer.gov/faststats/; last accessed September 30, 2011.

We identified 79 primary observational studies and one systematic review eligible for inclusion in Key Question 1.^4,5,16–92^

Of the primary observational studies, 51 analyzed the Surveillance Epidemiology and End Results (SEER) database of the National Cancer Institute (NCI) or a subset of its component registries, nine additional studies utilized the linked SEER-Medicare database, 11 the Cancer of the Prostate Urologic Research Endeavor (CaPSURE) database, five the National Cancer Database (NCDB), and three analyzed other large U.S.-based databases.

- The SEER database consists of a coordinated system of population-based cancer registries covering geographic areas selected for inclusion based on their ability to provide high quality population-based cancer reporting and for their epidemiologically significant population subgroups. The SEER population is comparable to the general U.S. population with regard to measures of poverty and education; however, the SEER population tends to be somewhat more urban and has a higher proportion of foreign-born persons than the general U.S. population.^b^
  b http://seer.cancer.gov/registries/characteristics.html; last accessed September 30, 2011.
- The racial and age distribution on SEER areas is also not perfectly representative of the total U.S. population and the data may be insufficient for minority groups other than blacks.^93,94^
- The SEER-Medicare database linked the SEER cancer registries data and Medicare enrollment and claims files.^c^
  c See http://healthservices.cancer.gov/seermedicare/; last accessed September 30, 2011.
- A comparison of sociodemographic characteristics of Medicare beneficiaries residing in the SEER areas versus the general U.S. elderly population demonstrated that the age and sex distribution for individuals 65 years and older in the SEER areas was comparable to that of the U.S. elderly population. However, the elderly population in the SEER areas had a lower proportion of whites and a higher proportion of other racial/ethnic groups and was also more likely to reside in an urban setting compared with the average 65 years and older U.S. population.^95^
- The CaPSURE database includes data from a longitudinal, observational study of over 14,000 men with all stages of biopsy-proven prostate cancer. Patients are enrolled regardless of age, stage of disease, or intended treatment plan. Currently, CaPSURE collects data from 40 urology practices in the United States (34 community based, 3 Veterans Administration [VA])-based and 3 academic center based).^d^ Although CaPSURE patients are broadly representative of prostate cancer diagnosed in the community, patient selection is not based on a formal population sampling scheme.
  d See http://urology.ucsf.edu/clinicalres/CRuroOnc_gceps_capsure.html; last accessed September 30, 2011.
- The NCDB is an oncology outcomes database encompassing more than 1,500 cancer programs in the U.S. (including Puerto Rico) accredited by the Commission on Cancer of the American College of Surgeons and the American Cancer Society.^e^
  e See http://www.facs.org/cancer/ncdb/index.html; last accessed September 30, 2011.
- Other databases utilized by the primary studies were the Patterns of Care study (sponsored by NCI and based on sampling participants through SEER) and the Los Angeles County/University of Southern California (LAC/USC) Cancer Surveillance Program (which is now a component registry of SEER).

In addition to the above databases, several studies obtained prostate cancer mortality data from the National Center for Health Statistics (NCHS) of the Centers for Disease Control and Prevention (CDC), the U.S. principal health agency for vital statistics.^f^

f See http://www.cdc.gov/nchs/; last accessed September 30, 2011.

Included studies had large sample sizes (median sample size = 54,670 patients; 25^th^–75^th^ percentile 11,161-138,387), were published between 1990 and 2011, and analyzed data from 1969 to 2008. Figure 3 presents the years covered by each primary study and the databases used. Appendix Tables C1.1-C1.14 present additional information about each of the studies relevant to Key Question 1.

Figure 3 Years covered and databases utilized by studies considered eligible for Key Question 1

Horizontal lines indicate the years covered by each primary study considered for Key Question 1. Different line patterns indicate the different databases utilized by each study. Studies are listed by the first year covered, then by database used, then by year of publication and are presented using the format: first author, year of publication [MEDLINE unique identifier]. Though data from earlier years were available, we analyzed only data from 1980 onward. Studies using SEER along with other information sources have been grouped in the “SEER” category for simplicity.

Figure 3 illustrates the databases utilized and timespans covered by each primary study considered for Key Question 1. Horizontal lines indicate the years covered (beginning in 1980) by each primary study considered for Key Question 1. Different databases are represented by various line patterns. Studies are listed by the first year covered, then by database used, and then by year of publication, and are presented using the format: first author, year of publication [PubMed unique identifier].

We organized the 79 studies into four groups, each of which is discussed in the following sections:

1. studies investigating trends in prostate cancer incidence
2. studies investigating trends in prostate cancer mortality or survival
3. studies investigating patient-, tumor-, or system-level characteristics at prostate cancer diagnosis, and
4. studies presenting information in treatment trends over time

### Trends in Prostate Cancer Incidence

Prostate cancer incidence trends in the United States during the last 30 years have been largely driven by changes in screening practices, mainly the implementation of prostate specific antigen (PSA) screening. Empirical analyses of incidence data and simulation studies demonstrate that patterns in prostate cancer incidence are compatible with the introduction and widespread use of a sensitive screening test, resulting in increases in the number of new cases diagnosed every year. The NCI’s Cancer Trends Progress Report (2009/10) indicates that prostate cancer incidence rates rose between 1975 and 1992 (from approximately 100 to more than 240 new cases per 100,000 men per year), and then fell until around 1995. After a period of nonsignificant increase from 1995 to 2000, rates declined again from 2000 to 2007 (to the current level of approximately 156 new cases per 100,000 men per year; Figure 4).

Figure 4 Age-adjusted SEER incidence rates for prostate cancer (1975–2008)

Only includes invasive cancer cases. Incidence data pertain to SEER9 areas: San Francisco, Connecticut, Detroit, Hawaii, Iowa, New Mexico, Seattle, Utah and Atlanta. Rates are presented per 100,000 and are age-adjusted to the 2000 U.S. standard population. Regression lines were fitted through joinpoint regression. Image obtained from SEER Fast Stats (http://seer.cancer.gov/faststats/index.php; last accessed September 30, 2011).

Figure 4 illustrates the trend of age-adjusted incidence rates for prostate cancer from 1975 to 2008, as calculated from the SEER database and its subregistries. The X-axis indicates year; the Y-axis indicates incidence rates for prostate cancer per 100,000, and are age-adjusted to the 2000 U.S. standard population. Data included only invasive cancer cases. Incidence data pertain to SEER9 areas: San Francisco, Connecticut, Detroit, Hawaii, Iowa, New Mexico, Seattle, Utah, and Atlanta. Regression lines were fit through joinpoint regression. The figure image was obtained from SEER Fast Stats (http://seer.cancer.gov/faststats/index.php; last accessed: July 18th, 2011). As shown in the figure, prostate cancer incidence rose between 1975 and 1992 and then fell until around 1995. After a period of nonsignificant increase from 1995 to 2000, rates declined again from 2000 to 2007.

Overall, 33 studies provided information on trends in prostate cancer incidence (Appendix Table C1.2). Of these, 11 provided information stratified by patient age,^17,27,28,35,38,39,43,55,57,59,79^ 17 by race/ethnicity,^16,17,19,21,25,32,34,42,43,45,46,49,57,76,80,83,84^ 15 by tumor stage,^17,18,20,23,26,27,34,35,42,50,52,55,56,76,85^ and 5 by tumor grade.^17,21,42,52,56^ No studies that met our inclusion criteria provided information stratified by the other factors relevant to Key Question 1 (comorbidity, tumor volume, PSA, biopsy frequency, number of cores obtained at biopsy, or system level characteristics).

Studies providing information on cancer incidence were large (median sample size = 51,337; 25^th^–75^th^ percentile 39,566-100,212), were published between 1990 and 2011, and provided information for years 1969 to 2007.

#### Patient Characteristics

Age. Eleven studies (9 SEER, 2 SEER-Medicare) covering 1969 to 2005 provided information on prostate cancer incidence stratified by patient age.^17,27,28,35,38,39,43,55,57,59,79^ Generally, studies indicated that since the mid-1980s the prostate cancer incidence rate increased across all age groups until 1992–93 and then declined until 1995–99. Data for more recent years were sparse. However, based on a study utilizing the SEER database, compared to the pre-PSA era (1986), the incidence rates in 2005 were 3.64 times higher for men aged 50–59 years (95 percent CI 6.4–8.2), 1.91 times higher for men aged 60–69 (95 percent CI 1.8–2.0), 1.09 times higher for men aged 70–79 years (95 percent CI 1.05–1.14), but 0.56 times less common for men 80 years or older (95 percent CI 0.53–0.60).^38^

Race/ethnicity. Seventeen studies (15 SEER, 1 SEER-Medicare, 1 LAC/USC) covering 1973 to 2007 provided information on prostate cancer incidence stratified by patient race/ethnicity.^16,17,19,21,25,32,34,42,43,45,46,49,57,76,80,83,84^ Thirteen of the 17 studies provided information exclusively for whites or blacks and only four provided information on patients belonging to other racial or ethnic groups; data for other racial/ethnic groups were often only provided in aggregate (not separately for each ethnic group). Studies indicated that all racial/ethnic groups experienced increases in prostate cancer incidence since the mid-1980s. The incidence rate appears to have peaked in 1992 for non-Hispanic whites, in 1993 for blacks, and in 1992 for “other” racial/ethnic groups. For all groups, incidence rates declined between the early-1990s and 1999. One study that provided information up to 2005, reported that the incidence rates in recent years are higher compared to the pre-PSA era but lower than the peak values reached in the mid-1990s both for whites and blacks (both races P < 0.001 for the increase from 1988–89 to 2004–05).^42^

#### Tumor Characteristics

Stage. Fifteen studies (14 SEER, 1 LAC/USC) covering 1969 to 2005 provided information on prostate cancer incidence stratified by tumor stage at diagnosis.^17,18,20,23,26,27,34,35,42,50,52,55,56,76,85^

Fourteen studies investigated trends in the incidence of localized/regional and distant disease. Generally, studies consistently demonstrated that early-stage (localized and regional; several studies did not report data separately for these stages) prostate cancer cases were responsible for the observed increase in prostate cancer incidence from the mid-1980s up to the mid-1990s. When separate estimates were available, studies reported large increases in the incidence of localized disease after the introduction of PSA testing. Over the same period, studies demonstrated decreases in distant (metastatic) prostate cancer incidence. For example, following the introduction of PSA screening, a study using the SEER-Seattle-Puget Sound registry demonstrated a 60 percent decrease in the age-adjusted incidence rate of distant prostate cancer (P < 0.001 comparing 1986 to 1991).^55^ Studies also consistently demonstrated decreases in incidence rates for all disease stages from mid-1990s to 2000. No study reported relevant information after 2000.

A single study (analyzing SEER) investigated changes in the distribution of T stage over time and demonstrated that compared to 1988–89, in 2004–05 the incidence rate had increased by 76 cases per 100,000 person-years for T1 tumors and by 11.2 cases per 100,000 person-years for T2 tumors. In contrast, over the same time period, the incidence of T3 or T4 tumors (combined) had decreased by 47.1 cases per 100,000 person-years (P < 0.001 for the stage specific changes).^42^

Tumor grade. Five studies (all using the SEER database or its component registries) covering 1973 to 2005 stratified prostate cancer incidence by tumor grade (level of differentiation or Gleason score).^17,21,42,52,56^ Studies generally indicated that the increase in prostate cancer incidence observed from the mid-1980s to early-1990s was mainly due to an increase in the incidence rate of moderately differentiated tumors (or tumors of Gleason score 5–7). A single study (of SEER) analyzed data after 2000 and reported a continued increase in incidence rate of tumors with Gleason score 5–7 from 1988 to 2005 and a concomitant decrease in the incidence rate of tumors with Gleason score 2–4 (P < 0.001 for Gleason group-specific changes).^42^

### Trends in Prostate Cancer Mortality and Survival Rates

For the overall U.S. population, the NCI’s Cancer Trends Progress Report (2009/10) indicates that after increasing from 1975 to 1991, prostate cancer death rates fell from 1994 to 2007.^aa^ The baseline prostate cancer mortality in 1975 was 31 deaths per 100,000 men per year and has declined to the current level of approximately 24 deaths per 100,000 men per year.

aa Available at http://progressreport.cancer.gov/; last accessed September 30, 2011.

Among the studies we reviewed, 21 provided information on trends in prostate cancer mortality or changes in survival rates of patients with prostate cancer, stratified by the factors relevant to Key Question 1 (Appendix Table C1.3). Nine of the studies provided information stratified by age,^17,18,24,28,30,33,39,40,86^ 15 by race/ethnicity,^16–19,24,26,27,34,40,44,51,60,76,84,86^ one by comorbidity status,^24^ six by tumor stage,^18,24,40,78,81,86^ and three by tumor grade.^24,40,86^ No studies provided information stratified by any of the other factors relevant to Key Question 1. Of the studies considered eligible, 19 utilized the SEER database, one the SEER-Medicare database and one LAC/USC. Studies were generally large (median sample = 60,494; 25^th^–75^th^ percentile 40,548-229,556), were published between 1990 and 2011, and covered years 1969 to 2007.

#### Patient Characteristics

Age. Ninestudies (all SEER-based) covering 1969 to 2004, reported information on population mortality rates (5 studies) or prostate cancer-specific survival among patients diagnosed with prostate cancer survival (4 studies), stratified by age.^17,18,24,28,30,33,39,40,86^ Studies of population mortality rates demonstrated decreases in the mortality rate for all age groups between the early-1990s and 1999.

One study presented information for years after 2000 and showed that population mortality continued to decline significantly for all age groups in recent years (up to 2004). One study of prostate cancer-specific survival, using the SEER database, demonstrated that over time (for deaths occurring from 1988 to 1995) the proportion of patients diagnosed with prostate cancer who died of their cancer has decreased (i.e., patients with prostate cancer have increasingly died of other causes) across all age groups considered (> 50 years old).^40^ Another study, also using the SEER database, demonstrated that among patients with prostate cancer, increasing age is associated with death from nonprostate cancer causes and that this effect held true throughout the study period.^24^

Comorbidity. A single study using the SEER database reported information on temporal trends in prostate cancer mortality stratified by whether patients had been diagnosed with multiple primary cancers.^24^ The study demonstrated that throughout the study period (1988 to 1995) prostate cancer patients with multiple primary cancers were consistently less likely to die of prostate cancer compared to patients with no multipleprimary cancers. No studies provided information on comorbidities other than multiple primary cancers.

Race/ethnicity. Fifteen studies (12 SEER or component registries, 1 SEER-Medicare, 1 LAC/USC and 1 using data from the NCHS), covering 1969 to 2007 and reported information on trends in prostate cancer mortality rates (10 studies) or prostate cancer-specific survival (7 studies; 2 studies reported both types of information) stratified by patient race/ethnicity.^16–19,24,26,27,34,40,44,51,60,76,84,86^ Eleven of the studies reported exclusively on non-Hispanic whites or blacks whereas four reported on other racial/ethnic groups as well.

Overall, studies demonstrated an increase in the mortality rate from the 1980s to the early-1990s, followed by a decrease from the mid-1990s to 2007 for all racial/ethnic groups. Notably, the mortality rates among blacks were consistently higher compared to that of non-Hispanic whites in all studies and across time periods.

Regarding prostate cancer specific-survival, all studies demonstrated improvements in survival over time, for all racial/ethnic groups during their respective time periods. Six of the seven studies reporting relevant information demonstrated that blacks were at higher risk for prostate cancer death compared to non-Hispanic whites, although the difference between the two groups appeared to decrease over time. One study found no significant difference in the probability of prostate cancer death (versus nonprostate cancer death) between non-Hispanic whites and blacks for the years 1988–95, after adjusting for multiple potential confounders (including tumor grade and stage at diagnosis).^24^

#### Tumor Characteristics

Stage. Six studies (all SEER based) reported on temporal trends in prostate cancer specific mortality among patients diagnosed with prostate cancer stratified by tumor stage at diagnosis.^18,24,40,78,81,86^ Studies covered 1969 to 2001 and demonstrated that over time the proportion of deaths due to prostate cancer among patients diagnosed with the disease has decreased, particularly for patients with early-stage (localized or regional) disease at diagnosis. One study, using the SEER database, demonstrated that the risk of death due to prostate cancer based on tumor stage was persistent from 1988 to 1995, with risk of death more than five times higher for patients diagnosed with distant disease and more than two times higher among those diagnosed with regional disease, as compared to patients with localized disease.^24^

We did not identify any studies reporting trends in population mortality rates stratified by tumor stage.

Tumor grade. Three studies (all SEER based) including prostate cancers diagnosed between 1973 to 1997, reported information on trends in prostate cancer survival stratified by tumor grade at diagnosis.^24,40,86^ One of the studies demonstrated that the probability of dying from prostate cancer among patients diagnosed with prostate cancer decreased during the study period (deaths occurring during 1988–95). Although the decrease was observed for all cancer grades, it was more pronounced among patients with well and moderately differentiated tumors.^40^ Another study, again using data from the SEER database, compared the probability of death by prostate cancer among patients diagnosed with the disease, stratified by tumor grade. The study demonstrated that, compared to patients with well differentiated tumors, patients with moderately differentiated cancers and poorly differentiated disease had a higher probability of prostate cancer death (more than two-fold and more than four-fold higher, respectively). These differences were relatively constant over the time period covered by the study (deaths occurring during 1988–95).^24^ These findings were confirmed by the third study which, using data from the SEER-Detroit database, showed that patients with grade I tumors have the highest 5-year relative survival compared to those with tumors of higher grade and that improvements in this statistic have occurred for all tumor grades (1 to 4) during the study period (patients diagnosed up to 1997 and followed up to 2001).^86^ Trends in mortality rates stratified by tumor grade should be interpreted cautiously given temporal changes in histopathologic grading practice (see next section, subsection on “Histopathologic grading changes”).

We did not identify any studies reporting on population trends in mortality rates stratified by tumor grade.

### Patient, Tumor, and System-Level Characteristics at Diagnosis

#### Patient Characteristics

We identified 52 observational studies reporting on patient characteristics at presentation (27 SEER, 7 SEER-Medicare, 10 CaPSURE, 5 NCDB and 3 other databases) (Appendix Tables C1.4–1.14).

The most commonly examined characteristics at baseline were patient age (21 studies),^19,21,29,30,37,42,46,50,52,55,56,63,65,71–75,77,86,91^ race/ethnicity ( 18 studies),^31,37,46,49,52,53,58,61–63,65,71,74,75,77,80,86,92^ tumor grade (16 studies),^4,22,30,37,46,52,56,65,67,68,71,73,75,77,86,90^ and tumor stage (22 studies).^4,16,23,31,37,46,52,56,62,63,65,67,68,71–76,86,90,91^ Information was available for all factors relevant to Key Question 1 except tumor volume. Studies were generally large (median sample = 46,248; 25^th^–75^th^ percentile, 10,385-134,434), published between 1990 and 2011, and covered the years 1973 to 2008.

Age. Twenty one studies (12 SEER or its component registries, 1 SEER-Medicare, 2 CaPSURE, 5 NCDB, 1 Patterns of Care Study (POCS) data) covering 1973 to 2005, reported information regarding patients’ age at presentation (Appendix Table C1.4).^19,21,29,30,37,42,46,50,52,55,56,63,65,71–75,77,86,91^

Seven studies (5 SEER or its component registries, 2 NCDB) reported trends in the average (mean or median) age at diagnosis of prostate cancer. Five of these studies reported reductions in the average age of patients whereas two studies did not report any changes during their respective time periods. Only one of these studies covered the period after 2005: using the SEER database, this study reported a statistically significant reduction over time in the mean age at diagnosis (from 72.2 to 67.2 years, comparing 1988–89 versus 2004–05).^42^ This change was statistically significant (P < 0.001) and was observed both for whites (absolute reduction = 4.7 years) and blacks (absolute reduction = 6.4 years). Notably, the three studies (all using the SEER database) that reported information on trends in average age stratified by race found that blacks were diagnosed at a younger average age than whites and that this difference persisted over time (i.e., despite changes in the race-specific average age at diagnosis);^19,21,42^ no such analyses were reported for individuals belonging to other racial/ethnic groups.

Fifteen studies (7 SEER or its component registries, 1 SEER-Medicare, 2 CaPSURE, 4 NCDB, and 1 POCS) reported the distribution of patients across discrete age groups (one study using the NCDB database provided information on age both as a continuous variable and grouped into discrete categories and is also included in the preceding paragraph) and generally supported a trend toward younger age at diagnosis (the effect was significant in four of the six studies reporting results of statistical analyses).

Comorbidity. Only two studies (1 CaPSURE, 1 POCS), covering 1997 to 2003, reported trends in the number of comorbidities present at the time of diagnosis of prostate cancer (Appendix Table C1.5).^71,77^ The CaPSURE database analysis grouped individuals into three groups: those with no comorbidities, those with one or two comorbidities, and those with three or more comorbidities.^71^ The study found no statistically significant difference in the distribution of patients in these groups, when comparing 1997–99 versus 2000–03. The POCS analysis grouped individuals into two groups (those with no comorbidity and those with one or more comorbidities) and compared the frequency of each group across two years (1998 versus 2002).^77^ The study concluded that the proportion of patients with no comorbidity has increased over time (from 78.3 percent to 87.4 percent; P < 0.01).

Race/ethnicity. Eighteen studies (9 SEER, 3 SEER-Medicare, 2 CaPSURE, 2 NCDB, 2 other databases) covering 1973 to 2003, reported information on trends in the racial/ethnic distribution of patients with prostate cancer (Appendix Table C1.6).^31,37,46,49,52,53,58,61–63,65,71,74,75,77,80,86,92^ Seven of the studies analyzed only whites and blacks; the remaining 11 studies considered additional racial/ethnic groups. Generally, there was no consistent pattern in the racial or ethnic distribution of cases over time: some studies indicated that the number of whites increased over time, others that it remained stable, and others that it decreased. Studies using the same database often provided discrepant results even for overlapping time periods; thus, no clear conclusion can be reached. These discrepancies may be due to differences in the selection criteria employed in each study.

#### Tumor Characteristics

Stage. Twenty two studies (8 SEER, 2 SEER-Medicare, 6 CaPSURE, 5 NCDB, 1 LAC/USC) covering 1973 to 2007, reported information on trends in the distribution of prostate cancer stage at diagnosis (Appendix Table C1.7). ^4,16,23,31,37,46,52,56,62,63,65,67,68,71–76,86,90,91^ Fifteen of the studies reported information by grouping cases based on information on tumor size, lymph node status, and the presence of distant disease (e.g., by grouping patients into localized, regional, and distant disease stage or by using the American Joint Committee on Cancer staging classification). Six studies reported information on the distribution of T stage groups only (2 for T1–T4, 1 for T1–T3 and 2 for T1–T2a) and one study reported information only on lymph node status.

Studies reporting on cancer stage consistently demonstrated decreases in the proportion of patients presenting distant disease and concomitant increases in the proportion of patients with localized or regional disease, over their respective time periods. All of the studies reporting information on the distribution of T stage used the CaPSURE data. The two studies reporting on T1–T4 tumors^4,65^ and the two studies reporting on T1–T3 tumor^71,90^s consistently demonstrated reductions in the proportion of patients presenting with higher T stages (i.e., a shift towards increasing proportion of patients with T1/2 tumors, even among patients classified as “high risk”). The two studies reporting on T1/T2 tumors both demonstrated a decrease of T1a/T1b tumors and T2a tumors and an increase in T1c tumors.^67,68^

The study reporting on lymph node status used the SEER database and suggested that the proportion of patients with positive lymph nodes decreased during the study period (1988–96).^23^

Tumor volume. The large epidemiologic datasets included in our review did not have information pertaining to trends regarding tumor volume. We performed additional targeted searches in MEDLINE using key words relevant to “tumor volume” and time trends, but did not identify additional studies.

Tumor grade. Sixteen studies (7 SEER or its component registries, 6 CaPSURE, 2 NCDB, 1 POCS) covering 1973 to 2007 reported information on trends in tumor grade distribution at disease presentation (Appendix Table C1.8).^4,22,30,37,46,52,56,65,67,68,71,73,75,77,86,90^ Studies using SEER data consistently demonstrated reductions in the proportion of patients diagnosed with well- or poorly-differentiated tumors (including undifferentiated tumors) with concomitant increases in the proportion of patients with moderately-differentiated disease. Within each study, this temporal trend was found to be statistically significant in six of the seven studies that reported the results of statistical tests assessing changes in the distribution of tumor grade over time. The six studies using CaPSURE data and one study using POCS data reported temporal trends in the distribution of Gleason scores. Generally, these studies showed a decrease over time in the proportion of tumors with Gleason scores 2–4 and increases in tumors with Gleason scores 5–7.

Prostate specific antigen. Eight studies (7 CaPSURE, 1 POCS), covering 1989 to 2007, reported information on trends in PSA levels at presentation (Appendix Table C1.9).^4,64,65,67,68,71,77,90^ Seven studies categorized PSA values ( e.g., < 4, 4–10, >10 ng/mL) and only one study reported the median PSA value by diagnosis year. Generally, studies found that the PSA values at diagnosis have decreased over time (i.e., that a larger number of patients are currently diagnosed with PSA concentrations below 10 ng/mL; this was true even for patients with low risk localized prostate cancer^90^).

We did not identify studies reporting on trends in the proportion of screen-detected prostate cancer cases among all cancer cases that met our inclusion criteria. One study demonstrated that for all age groups above 65 years and both for blacks and whites, the proportion of men who underwent PSA testing at least once and were diagnosed with prostate cancer within 90 days of the test among all men undergoing PSA testing has decreased over time (1988–96).^96^ Distinguishing between screen-detected prostate cases (i.e., cancer cases identified following investigation triggered by a positive PSA test) and cases where use of the PSA test was used as a confirmatory or add-on test (e.g., as part of the investigation of clinical symptoms or signs suggestive of prostate cancer, or suspicious findings on prostate digital rectal examination) is particularly challenging using administrative data and may be uncertain even after review of complete medical records.^96^

#### Diagnostic Strategies

Biopsy Frequency. Four studies (2 SEER component registries, 2 SEER-Medicare), covering 1982 to 2001, reported information on trends in the performance of prostate biopsies (Appendix Table C1.10).^52,54,57,89^ One study using data from the SEER-Detroit registry reported that the proportion of prostate cancer patients diagnosed through biopsy (compared to those diagnosed through other procedures, such as transurethral resection of the prostate) increased over time (1982–95, P < 0.001).^52^ A similar trend was evident in a study using data from the SEER-New Mexico registry.^54^ A SEER-Medicare study also demonstrated an increase in the age-adjusted rate of biopsy procedures (from 685 to 2600 per 100,000 men) between 1986 and 1991.^57^ An updated analysis from the same database, covering the period 1993–2001, reported that the age- and race-adjusted biopsy rate did not statistically significantly change over the study 9-year period (trend P > 0.2).^89^

Number of cores. A single primary study^70^ provided information on the number of biopsy cores obtained during the investigation of suspected prostate cancer cases (Appendix Table C1.11). The study utilized the CaPSURE database and covered 1997 to 2002. It demonstrated a significant increase in the mean number of cores examined per patient (from 7.5 in 1997 to 9.8 in 2002). We note that the study excluded patients who were evaluated with less than six cores, which may have led to underestimation of the change in the number of cores obtained. However, the study found that the increase in the number of cores over time was significant (+0.41 cores per patient per year, P <0.001).

Histopathologic grading changes. In a study of prostate cancer patients from the Connecticut Tumor Registry (1990–92), investigators obtained medical records, pathology reports, and the original slides used for pathological examination for 1858 (49 percent) of the patients diagnosed during the study period.^97^ A single pathologist (blinded to the originally assigned Gleason score) regraded all slides (2002–04). The contemporary reading of the slides resulted in the assignment of significantly higher scores compared to the original readings (mean score increase from 5.95 to 6.8; P < 0.001). The study also demonstrated that this reclassification causes an increase in the Gleason-score adjusted prostate-cancer-specific survival; even in the absence of changes in treatment efficacy or tumor biology (since the same patient histories were used such changes cannot explain differences in survival patterns). This observation is often referred to as the “Will-Rogers” bb phenomenon.^98^

bb The Will-Rogers phenomenon arises when a member who is in the bottom half of a group with a high average outcome is reclassified as a member who is in the top half of a group with a lower average outcome, resulting in increases of the average outcome in both groups. In the prostate cancer case, the phenomenon occurs when the same biopsy sample receives a different Gleason score if assessed using different scoring criteria at different time points (for example, in the 1990s versus now). When members of the low risk group with the least favorable histology are reclassified into the high-risk group (which on average had worse prognosis than the reclassified members), this will inflate grade-adjusted survival over time for both groups.

We also identified a structured review on the same topic through additional targeted searches (Appendix Table C1.12).^99^ None of the studies included in this review (other than the one discussed above) fulfilled our inclusion criteria.

#### System Characteristics

Differences in geographical access and other system-level factors. Four studies (2 CaPSURE, 1 POCS, 1 NCDB), covering 1986 to 2003, reported information on changes in the distribution of patients by system-level factors (Appendix Table C1.13).^65,71,74,77^ Three studies (2 CaPSURE, 1 POCS) provided information on trends in the distribution of patients’ insurance status at diagnosis.^65,71,77^ The two studies utilizing CaPSURE data demonstrated a decrease in the proportion of patients with Medicare coverage at the time of diagnosis over the time periods covered (1997–2003 and 1989–2001).^65,71^ In contrast, the study using POCS data did not demonstrate a change in the distribution of insurance status over time (1998–2002).^77^

One study, using the CaPSURE database reported on trends in the distribution of settings (community versus academic) and geographic regions over time.^65^ Comparing 1997–2001 to 1989–97, there was an increase in the number of patients seen in academic settings (compared to community settings) and an increase in the number of patients originating from Midwestern states (and a concomitant decrease in the proportion of patients from Eastern or Southern states). Because the centers participating in CaPSURE have not remained stable over time, changes in these distributions may be difficult to interpret.

One study, comparing 1998 to 2002, reported an increase in the number of patients residing in areas of higher median income. Again, because sampling strategies changed between the POCS years (and different regions were included), patterns in the distribution of income are difficult to interpret.^77^

Finally, one study, using the NCDB, assessed trends in the distribution of patients by hospital caseload, over time (1986–87 and 1992). There was little evidence of change over the time period covered.^74^

### Trends in Treatment Patterns

Twenty one studies (6 SEER, 3 SEER-Medicare, 6 CaPSURE, 5 NCDB, 1 POCS) provided information on treatment trends over time (Appendix Table C1.14).^4,27,36,41,47,48,58,66,67,69,71–75,77,82,87,88,90,91^ Studies were generally large (median sample size = 71,602; 25^th^–75^th^ percentile 6290-142,340), published between 1994 and 2011, and covered 1973 to 2008. In 12 studies, patients managed by observational management strategies of no active treatment (AS, WW or expectant management) were considered in aggregate with patients receiving androgen deprivation therapy (ADT), or it was unclear whether the data allowed the distinction between these treatments. Most studies demonstrated decreasing trends in the proportion of patients being managed with strategies other than surgery or radiotherapy throughout their respective time periods; studies explicitly reporting on AS/WW-type strategies also indicated decreases in the proportion of patients receiving such treatments. In all seven studies (6 CaPSURE, and 1 using POCS data) providing information for years after 2000, the proportion of patients receiving AS/WW was less than 10 percent; this also held true for subgroups of “low-risk disease” (typically defined based on T stage, Gleason score and PSA criteria) investigated in two studies (both using CaPSURE data).

### Summary

We reviewed 79 studies based on large epidemiologic databases sourced from the U.S. population. For all age or race/ethnicity groups investigated, the incidence rate appears to have peaked in the early 1990s; subsequently, the incidence rate declined between the early 1990s and 1999. Studies consistently demonstrated that early-stage (localized and regional) prostate cancer cases were responsible for the observed increase in prostate cancer incidence from the mid-1980s up to the mid-1990s. Studies also demonstrated decreases in the prostate cancer-specific mortality rate for all age groups between the early-1990s and 1999. Mean age of diagnosis has decreased over time, both for blacks and whites. Another consistent trend over time has been the decrease in low- and high-grade (corresponding to Gleason scores 2–4 and ≥7, respectively) tumors, and a concomitant increase in intermediate grade tumors (corresponding to Gleason scores 5–6). These trends, and their impact on grade-adjusted mortality statistics, need to be interpreted cautiously in the light of changes in histopathologic grading practice (causing a Gleason score shift toward higher values), and the widespread implementation of PSA screening (which will tend to increase the detection of nonhigh grade tumors). Over time, patients diagnosed with prostate cancer are less likely to die of the disease (i.e., they are more likely to die of nonprostate cancer causes); this is particularly true for patients diagnosed at older age. Most studies demonstrated a decrease over time of the proportion of patients being managed with strategies other than radical prostatectomy or radiation therapy. Studies explicitly reporting on AS/WW, also indicated decreases over time in the proportion of patients being managed with such observational management strategies; this was true even for subgroups of men with low-risk disease.

There is little doubt that many of the observed trends in the presentation and natural history of prostate cancer in the U.S. in the last 3 decades are at least in part due to the widespread use of PSA screening. However, for many of these trends summarized in the preceding sections there are multiple potential explanations. For example, observed trends in prostate-cancer specific mortality may be explained by the implementation of PSA screening and its impact on ascertaining cause of death^100^, improved treatments for localized disease (surgery or radiotherapy), widespread use of ADT, earlier detection (and treatment) of recurrent disease, or changes in the underlying disease biology.^33^ Modeling studies may provide insight into the underlying causes of the observed temporal changes^cc^; modeling has been used to quantify the impact of PSA testing on population incidence^101^, mortality^102,103^, and tumor grade at diagnosis^104^, or to explore the potential for overdiagnosis.^96,105^

cc For example, the Cancer Intervention and Surveillance Modeling Network (CISNET), a consortium of NCI-sponsored investigators, uses a comparative modeling approach to explore prostate cancer trends in the US population. Additional information is available at http://cisnet.cancer.gov/; last accessed October 31, 2011.

## Key Question 2 How are active surveillance and other observational management strategies defined?

There are generally three scenarios in which a man with newly diagnosed prostate cancer might not undergo immediate definitive treatments like RP or RT: 1) his disease has a low risk of rapid progression and therefore it is felt that he could be safely monitored and still receive definitive treatment should the need arise; 2) his disease may have a higher risk of rapid progression but he may not be an ideal candidate for definitive treatments after careful deliberation of the different tradeoffs (e.g., life expectancy gained versus the compromise in quality of life living with side effects from immediate treatments), therefore, he could be followed clinically and be offered palliative treatments should he become symptomatic; or 3) his disease is advanced and only palliative treatments are indicated. In the literature, the first approach (scenario 1) is generally termed “active surveillance (AS),” while the second approach (scenario 2) is generally termed “watchful waiting (WW).” However, it is important to note that investigators have used the terms AS and WW interchangeably. Terms like “expectant management,” “conservative management,” and others to denote one of the two approaches have also been used. Regardless of the actual term used, we attempt to clarify the intent of the different approaches in summarizing the relevant studies.

AS management strategies typically use a predefined protocol to monitor triggers for initiating curative treatments, where as watchful waiting ( WW) strategies use a somewhat passive (compared to AS) followup and upon symptomatic disease progression palliative treatments are instituted. A wide variety of combinations of monitoring parameters including clinical symptoms, digital rectal examination (DRE) findings, Gleason score, PSA concentrations, PSA doubling time and/orvelocity, results from transrectal ultrasound (TRUS) guided rebiopsy, bone scan or other imaging modalities have been used. However, the optimal monitoring strategies in patients choosing AS have not yet been well-characterized.^7^

For this Key Question, we undertook a systematic review of the literature to identify studies that followed men who were initially managed conservatively (e.g., AS and WW) and that documented the eligibility criteria for patient selection and followup protocols. We also extracted triggers for recommending treatment and the definitions of prostate cancer progression (Appendix Table C2.1). We considered studies reporting on observational management strategies (i.e., no immediate active treatment with curative intent), enrolling patients based on predefined eligibility criteria, and using prespecified protocols for followup. We reviewed the full-text articles of all qualifying studies but only included the earliest publication or the article with most complete information from the same center or research team that used the same observational strategy (i.e., when the same definition was consistently used in all publications). However, we also considered additional publications reporting on the same cohort when they provided additional relevant information.

There is a broad spectrum of strategies for observational management described in research publications. For the purpose of operationalizing the process of summarizing the various definitions, we divided protocols into those clearly described as having curative intent and those in which their aims were either unclear or primarily palliative, regardless of how these regimens were labeled. This categorization was done for practical reasons, not to suggest what the definitions or protocols for AS, WW, or any other observational strategy should be.

Due to often poor reporting of treatment intent, we based our interpretation on the specific triggers used to initiate treatment in each study. Specifically, we operationally defined protocols with curative intent as those that also used other parameters (with or without symptomatic disease progression) as triggers for active treatment. Protocols where treatment was only initiated upon symptomatic disease progression were considered as palliative.

### Protocols With Curative Intent

We identified 16 unique cohorts reporting formal protocols to monitor triggers for curative treatment of prostate cancer. Of these cohorts, ten are in the United States, two in Canada, two in the UK, one in the Netherland s, and one in Japan (Table 1). In all cohorts, AS was offered to men with low-risk or clinically localized prostate cancer although the eligibility criteria varied. The protocols varied across all 16 cohorts. Baylor College of Medicine and Memorial Sloan-Kettering Cancer Center were the first institutions to report enrollment of patients into AS program in 1984.

Table 1 Unique AS cohorts^a^

Cohorts or Centers | Country | Beginning of enrollment (year)
Baylor College of Medicine and Memorial Sloan-Kettering Cancer Center^106^ | US | 1984
McGill University^107^ | Canada | 1987
University of Connecticut Health Center^108^ | US | 1990
Four tertiary care academic medical canters^109^ | US | 1991
University of Miami^110^ | US | 1991
University of California at San Francisco^111^ | US | After 1991
Royal Marsden Hospital^b,112^ | UK | 1993
Johns Hopkins^113^ | US | 1994
Toronto-Sunnybrook Regional Cancer Center^114^ | Canada | 1995
Memorial Sloan-Kettering Cancer Center^115^ | US | 1997
ProtecT (Prostate testing for cancer and Treatment Trial)^116^ | UK | 2000
Dana-Farber Cancer Institute^117^ | US | 2000
Kagawa Medical University^c,118^ | Japan | 2002
Cleveland clinic^119^ | US | 2004
PRIAS (Prostate cancer Research International Active Surveillance)^120^ | Netherlands | 2006
PASS (the Canary Prostate Active Surveillance Study)^121^ | US | 2008

a Cohorts are listed chronologically by enrollment start year. Some cohorts had multiple publications providing different pieces of information on eligibility criteria and followup protocol. In this case, only the earliest publication was used as the primary citation of the cohort. Details are described in Tables 3 and 5.

b Royal Marsden Hospital had both AS and WW protocols (described separately). Since 1993, the Royal Marsden Urology Unit has offered an AS policy as a management option for favorable-risk early prostate cancer.

c The cohort was not an AS cohort before 2002. See the next section, “Observational management strategies with palliative intent,” for its earlier eligibility criteria and followup protocol.

Common Metrics: Eligibility Criteria for Low-risk or Clinically Localized Prostate Cancer in AS Cohorts (Table 2-3)

The criteria used to identify patients with low-risk or clinically localized prostate cancers generally varied across the 16 cohorts, with the exception that no cohorts enrolled patients with clinical stage greater than T2. The most commonly used parameters of patient eligibility criteria for AS were Gleason score (12 cohorts), PSA (10 cohorts) and number of biopsy cores positive for cancer (8 cohorts).

Age. Three cohorts reported using age as part of their patient eligibility criteria for AS.^109,118,122^ The age criterion was less than 75 years in one multicenter cohort (Cleveland Clinic Foundation, Memorial Sloan-Kettering Cancer Center, University of British Columbia and University of Miami),^109^ less than 80 years in the cohort at University of Miami,^122^ and between 50 and 80 years old in the cohort at Kagawa Medical University in Japan. ^118^ One cohort justified the use of age as part of patient inclusion criteria to mirror those patients who would otherwise be eligible for RP or RT due to a life expectancy greater than 10 years at the time of diagnossis;^109^ the other two did not report the reason for including age as part of patient eligibility criteria for AS.^118,122^

Gleason score. Twelve cohorts (16 publications) used the Gleason score as part of patient eligibility criteria for AS (Tables 2 and 3).^106,109–115,117–120,122–125^ Nine of the 12 cohorts used Gleason score 6 or less (or no pattern 4 or 5). The remaining three cohorts allowed Gleason pattern 4.^111,112,114^ Toronto-Sunnybrook Regional Cancer Center cohort changed the Gleason score criterion that was used to define “favorable-risk” patients for offering AS in the beginning of the study due to the publication of more convincing evidence of a significant difference in natural history between Gleason 6 and 7.^126^ Specifically, between 1995 and 1999, AS was offered to all patients who had a Gleason score 6 or less and PSA 10 ng/mL or less, in addition to older patients (age ≥ 70 years) with Gleason up to 3+4 or PSA up to 15 ng/mL. Since January 2000, the cohort was restricted to patients who had a Gleason score 6 or less and PSA 10 ng/mL or less, regardless of age.^114,125^

Table 2 Cohorts that used Gleason score and PSA as part of patient eligibility criteria for AS

Cohorts or Centers | Gleason score | PSA (ng/mL)
Baylor College of Medicine and MSKCC^106^ | <7
McGill University^107^
UCHC^108^
Four tertiary care academic medical canters^109^ | ≤6 | ≤10
University of Miami^110^ | ≤6 | ≤15; then changed to ≤10
UCSF^111^ | ≤6 with a priori exceptions^b^ | <10 with a priori exceptions^d^
Royal Marsden Hospital^112^ | <3+4 | ≤20 ; then changed to ≤15
Johns Hopkins^113^ | ≤6 | PSA-d ≤0.15
Toronto^114^ | ≤6; ≤3+4 (if ≥70 yr)^c^ | ≤10; <15 (if ≥70 yr)^c^
MSKCC^115^ | No Gleason grade 4 or 5 | <10
ProtecT (Prostate testing for cancer and Treatment Trial)^116^
Dana-Farber Cancer Institute^117^ | ≤6 with no pattern 4
Kagawa Medical University^118^ | ≤6 | ≤20
Cleveland clinic^119^ | No Gleason grade 4 or 5 | ≤10
PRIAS^120^ | ≤3+3=6 | ≤10; PSA-d ≤ 0.2
PASS^121^

Grey shading indicates that a study did not report use of a particular criterion; PSA-d = PSA density (ng/mL/cm3) which is calculated by dividing the PSA level by the total volume of the prostate.

a The Gleason patterns range from 1 to 5, being 5 the least differentiated pattern. A Gleason score of 4+3 (primary + secondary grade) = 7 is different from 3+4 = 7, and has a different prognosis as well. It is therefore more informative to give both patterns, than just providing the sum of those (i.e., the Gleason score).

b Exception: having a Gleason pattern of 4 reported only in a microfocus of tumor

c (if ≥if yr) = for older patients (age ≥yr years), less than Gleason up to 3+4 criterion and PSA less than 15 was used.

d Exception: <15 for men with concurrent benign prostatic hyperplasia or prostatitis

Table 3 Eligibility criteria for enrollment in protocols with curative intent in chronological order of starting enrollment year

Center, Country [Pubmed ID] Enrollment years | Term used in original article | Age (yr) | Gleason score | # biopsy cores/% cores | PSA (ng/mL) | Imaging | Stage | Behavioral indication (other than patients’ choice or preference)
Baylor College of Medicine and MSKCC, US^106^ [15017211] 1984–2001 | EM/deferred therapy | – | <7 | TRUS guided sextant biopsy | – | – | – | Decision for deferred therapy was made by the patient and treating physician together based on the likely presence of small volume cancer.
McGill Univ., Canada^107^ [18484590] 1987–2002 | WW; AS | – | – | TRUS guided biopsy | – | – | “Clinically localized caner”^26^) | Limited life expectancy because of advanced age or poor medical condition
Univ. of Connecticut Health Center, US^108^ [18707696] 1990–2006 | AS | – | – | – | – | – | “low-risk disease” | Patients who elected WW or AS program. Men on WW were generally older with localized prostate cancer who did not desire aggressive intervention. Men on AS were generally younger with low-risk disease.
Four tertiary care academic medical canters,^a^ US^109^ [19233410] 1991–2007 | AS | ≤75 | ≤6 | ≤3 positive cores at diagnostic biopsy | ≤10 | MRI of the prostate was selectively used at diagnosis | T1-T2a | –
Univ. of Miami, US^110,122,123^ [17850361; 20800964; 21215429] 1991–2007 | AS; WW^123^ | ≤80^122^ | ≤6^110^ | TRUS guided biopsy ≤50% of 2 biopsy cores^110^ ≤2 biopsy cores with ≤20% in each core^123^ | ≤15^110^ ≤10^122,123^ | – | ≤T2/T2b^110^ | MD influence had the greatest impact on choosing AS (73%), concerns for incontinence (48%) and erectile dysfunction (44%) also reasons for choosing AS^122^
UCSF, US^111,133^ [18433013] >1991 | AS | – | ≤6; no Gleason pattern 4 or 5 A priori exception: having a Gleason score of 4 reported only in a microfocus of tumor^133^ | Cancer involvement of <33% of biopsy cores <50% of the length of a tumor core involved by carcinoma^133^ A priori exception: having >33% positive biopsy cores due to a tumor microfocus^133^ | <10 A priori exception: <15 for men with concurrent benign prostatic hyperplasia or prostatitis^133^ | – | T1/T2a | life expectancy >3 mo^133^
Royal Marsden Hospital, UK^112,124,134^ [15839912; 17850368] 1993–2002; ≥2002;^124^ 2004–2006^134^ | AS | – | ≤7 (primary ≤3) <3+4^134^ | Less than half of the biopsy cores positive (octant biopsy).^124^ <20% core positive^134^ | ≤20^112^ <15^124^ | – | T1–2, N0/X, M0/X | –
Johns Hopkins, US^113^ [20439642] 1994–2008 | AS (or EM with curative intent) | – | ≤6 | ≤2 cores cancer positive; ≤50% cancer in any single core | PSA density (PSA before diagnosis divided by prostate volume) ≤0.15 ng/mL/cm3 | TRUS to determine PSA density | T1c | –
Toronto-SRCC, Canada^114,125^ [11395227; 19917860] 1995–2002 as a phase II trial; 2003-ongoing as an open prospective cohort | WW; AS^b^ | – | ≤7^114^ ≤6; ≤3+4 (if ≥70 yr)^125^ | – | ≤15^114^ ≤10; <15 (if ≥70 yr)^125^ | Chest X-ray, TRUS of the prostate were mandatory. Bone scan and CT scan of the abdomen and pelvis were performed at the clinicians’ discretion. | T1b-T2b N0 M0 (1997 TNM classification)^c^ | –
Memorial Sloan- Kettering Cancer Center, US^115^ [21167529] 1997–2009 | AS | – | No Gleason grade 4 or 5 | ≤3 positive biopsy cores (minimum 10), no biopsy core containing >50% cancer involvement | <10 | – | T1-T2a | –
ProtecT, UK^116^ [19603015] 2000–2008 | Active monitoring | – | – | – | – | – | “Clinically localized prostate cancer” | –
Dana-Farber Cancer Institute, US^117^ [21167525] 2000–2010 | AS | – | ≤6 with no pattern 4 | <3 cores positive for cancer and < 50% of cancer in any core | – | – | T1c-T2c | –
Kagawa Medical Univ., Japan^118^ [18272471] 2002–2003 | AS | 50–80 | ≤6 | TRUS-guided six sextant biopsy 1–2 positive cores per 6–12 systematic biopsy cores | ≤20 | – | T1cN0M0 | –
Cleveland clinic, US^119^ [21256549] 2004–2009 | Surveillance | – | No primary or secondary Gleason scores 4 or 5 | – | ≤10 (part of D’Amico criteria) | – | Clinical stage T2a or fewer (part of D’Amico criteria) | –
PRIAS, Netherlands^120^ [19817747] 2006 – ongoing | AS | – | ≤3+3=6 | TRUS guided biopsy^d^ Adequate biopsy sampling according to biopsy protocol; maximal 2 biopsy cores invaded with prostate cancer | ≤10 PSA density ≤ 0.2 ng/ml/ml | – | T1c or T2 | –
PASS, US^121^ [19758683] 2008 – ongoing^e^ | AS | – | – | If diagnosis ≤1 year of entry, at least 1 biopsy with ≥10 cores. If diagnosis >1 year of entry, minimum of 2 biopsies; 1 ≤2 years before entry. | – | – | Clinical stage T1-2, NX/0, MX/0 | –

a Cleveland Clinic Foundation, Memorial Sloan-Kettering Cancer Center, University of British Columbia and University of Miami

b Multiple terms used across multiple publications and within single publication

c Since January 2000, Toronto-SRCC study was restricted to low-risk patients only.

d PRIAS protocol can be found: http://www.erspc-media.org/media/publications/PRIAS%20Project_background.pdf. Accessed September 28, 2011.

e Prostate Active Surveillance Study (PASS) protocol can also be found at Clinicaltrial.gov (NCT00756665): http://clinicaltrials.gov/ct2/show/NCT00756665. Accessed September 28, 2011.

DT = doubling time; PSA = prostate-specific antigen; TNM = tumor-node-metastasis system; TURP = transurethral resection of the prostate; yr = yr(s); wk = wk(s); mo = mo(s); SRCC = Sunnybrook Regional Cancer Center; BCCA = the British Columbia Cancer Agency; DRE = digital rectal examination; WW = watchful waiting; AS = active surveillance; EM = expectant management; PAP = prostate acid phosphatase; PSA = prostate specific antigen; TRUS = Transrectal ultrasound; CT = computerized tomography; PSA = prostate-specific antigen; TNM = tumor-node-metastasis system; SRCC = Sunnybrook Regional Cancer Center; BCCA = the British Columbia Cancer Agency; ED = erectile dysfunction; PRIAS = Prostate cancer Research International Active Surveillance; ProtecT = Prostate testing for cancer and Treatment; UCSF=University of California at San Francisco; European Randomized Study of Screening for Prostate Cancer = ERSPC; VA = Veterans Affairs; MSKCC = Memorial Sloan-Kettering Cancer Center

✓ = item was used as part of monitoring strategy but explicit criteria were not defined

– = item was not used or not reported as part of monitoring strategy

Number of cores positive for cancer. Eight cohorts (11 publications) used a maximal number of biopsy cores positive for cancer as part of patient eligibility criteria for AS.^109,110,112,113,115,117,118,120,122–124^ Two criteria were used: 2 or fewer (5 cohorts) and 3 or fewer (3 cohorts) positive biopsy cores. It should be noted that the biopsy strategies varied across these cohorts. For example, some cohorts used sextant (6-core) biopsy, some used octant (8-core) biopsy, and others performed extended biopsy (>10 cores).

Percentage cancer involvement in each core. Five cohorts (7 publications) used “low-volume disease” as part of patient eligibility criteria for AS.^110,111,113,115,117,122,123^ In three cohorts, the definition of “low-volume disease” was involvement of less than half of any individual core with cancer. In the other two cohorts (3 publications), the criterion percent of biopsy cores with cancer involvement was described variably as less than half of two biopsy cores,^110^ less than 20 percent in one or two biopsy cores,^123^ and cancer involvement of less than 33 percent of biopsy cores.^111^

PSA. Ten cohorts (14 publications) used PSA as part of patient eligibility criteria for AS (Table 2.2).^109–115,118–120,122–125^ Three PSA thresholds were used: ≤10 (7 cohorts), ≤15 (3 cohorts), and ≤20 (2 cohorts) ng/mL. Two cohorts used two different PSA density thresholds (≤0.15 or ≤0.2 ng/mL/cm^3^). The number of cohorts do not sum to the total number of cohorts because some cohorts used multiple criteria. Of these, two cohorts reported changes in the PSA criteria to a lower threshold in the more recent years. The cohort at Royal Marsden Hospital changed the PSA threshold from less than or equal to 20 ng/mL to less than or equal to 15 ng/mL in 2002,^112,124^ and the cohort at University of Miami changed the PSA threshold from less than or equal to 15 ng/mL to less than or equal to 10 ng/mL in more recent publications (Tables 2 and 3).^110,122,123^

Imaging. One cohort reported that a chest radiograph was mandatory, and bone scan and computed tomography scan of the abdomen and pelvis were performed at the clinician’s discretion.^114,125^ One other cohort reported that magnetic resonance imaging of the prostate was selectively used at diagnosis.^109^

Behavioral indicators. No behavioral indicator was used explicitly as a criterion for AS program enrollment.

#### Followup Protocols of AS Cohorts

(Tables 4 and 5)

Table 4 Cohorts that used PSA (ng/mL) or PSA kinetics as part of followup protocol for AS

Cohorts or Centers | PSA (ng/mL)
Baylor College of Medicine and MSKCC^106^ | PSA velocity >0.75 ng/mL/year
McGill University^107^ | Used but not specified
UCHC^108^ | Used but not specified
Four tertiary care academic medical canters^109^ | Used but not specified
University of Miami^110^ | PSA increase 25–50 %/year
UCSF^111^ | PSA velocity >0.75 ng/mL/yr; PSA DT <1 year
Royal Marsden Hospital^112^ | PSA DT<4 years; PSA velocity >1 ng/mL/year
Johns Hopkins^113^ | PSA kinetics were not used as part of triggers for intervention
Toronto^114^ | PSA DT <2 years
MSKCC^115^ | >10
ProtecT (Prostate testing for cancer and Treatment Trial)^116^ | Used but not specified
Dana-Farber Cancer Institute^117^ | Used but not specified
Kagawa Medical University†^118^ | PSA DT <2 years
Cleveland clinic^119^ | Used but not specified
PRIAS^120^ | PSA DT 0 to 3 years
PASS^121^ | PSA DT <3 years

PSA DT = PSA doubling time which is defined as the time PSA needs to double its start-value. PSA V = PSA velocity (ng/mL/yr) which is the absolute increase of PSA values in one year.

Table 5 Monitoring criteria in protocols with curative intent in chronological order of starting enrollment year

Center, Country [Pubmed ID] Enrollment years | Monitoring schedule | Gleason score | # biopsy cores /% cores | PSA | Imaging | Behavioral indication | Additional laboratory tests | Triggers for interventions
Baylor College of Medicine and MSKCC, US^106^ [15017211] 1984–2001 | DRE and PSA every 3 mo first yr and every 6 mo thereafter. | any new Gleason pattern 4 or 5 | Repeat TRUS guided sextant biopsy was recommended at 6 mo: bilateral or multifocal cancer, or > 4 cores with cancer | PSA velocity was calculated from 3 separate recorded values in a 12-mo period: > 0.75 ng/ml/yr in 12 mo, or 24 mo | – | – | – | Definitive treatment when objective progression or patients’ requests.
McGill Univ., Canada^26,107^ [18484590] 1987–2002 | Every 3–6 mo PSA and DRE | Gleason pattern of 4 | TRUS guided biopsy was done annually or when there was a change in DRE or PSA. ≥3 positive, or >50% cancer in at least 1 core | ✓ | – | ✓ | – | Clinical disease progression on DRE or repeated sextant biopsy, patient preference, or rising PSA level.^26^
Univ. of Connecticut Health Center, US^108^ [18707696] 1990–2006 | Every 3–6 mo PSA, DRE every 6 to 12 mo, rebiopsies recommended 2 yr after initial biopsy | Progression in Gleason score | Increase in tumor volume (increased number or percent of cores positive) | ✓ | – | Anxiety related to increasing PSA trend | – | Increase in tumor volume, progression in Gleason score, onset of urinary symptoms, change in DRE or patient request (due to anxiety related to increasing PSA trend).
Four tertiary care academic medical canters,^f^ US^109^ [19233410] 1991–2007 | Every 6–12 mo PSA and DRE, rebiopsies within 18 mo and then every 1 to 3 yr | – | – | ✓ | MRI of the prostate was selectively every 1 to 3 yr | – | – | Criteria for recommending treatment were nonstandardized and physician specific.
UCSF, US^111,131–133,135^ [18433013; 21115873; 21419438] >1991 | Every 3 mo PSA and DRE; prostate biopsy every 12–24 mo (after 2003) | Gleason upgrade to ≥4 (if (≤6 at diagnosis) or ≥4+3 (if 3+4 at diagnosis)^131^ | TRUS guided biopsy every 6–12 mo ≥33% of cores or >50% of any core^132^ Rebiopsy ≥10 cores^135^ | PSA velocity >0.75 ng/mL/yr PSA DT < 1 yr^133^ | – | – | – | Disease progression; no specific protocol for intervention (implied)
Univ. of Miami, US^110,127^ [17850361; 10759669] 1991–2007 | Every 3–4 mo PSA and DRE for 2 yr and every 6 mo thereafter.^110^ | ≥7^110^ | >2 positive cores (After 2000, a peripherally targeted TRUS biopsy of 10–12 cores was performed 9–12 mo after the first rebiopsy, and then annually or earlier if dramatic rise in PSA or a change on DRE.)^110^ | Biochemical progression: PSA increase 25–50 %/yr^127^ | TRUS (needed for determining tumor volume) ^110^ | – | – | Treatment is encouraged at an increase in tumor volume, Gleason score ≥7, or the presence of >2 positive cores at rebiopsy.^110^ Treatments were offered at the time of local stage progression by DRE and/or biochemical progression, or systemic progression.^127^
Royal Marsden Hospital, UK^112,124,128^ [15839912; 17850368; 18949747] 1993–2002; ≥2002;^124^ 2004–2006^134^ | Every 3–6 mo PSA and DRE for 2 yr and every 6 mo thereafter. Rebiopsy not routine.^112^ After 2002; monthly PSA in yr 1, every 3 mo in yr 2, and every 6 mo thereafter.^124,134^ DRE every 3 mo for 2 yr. | >7^124^ Primary Gleason ≥4, (initial Gleason 3+3, upgraded to Gleason ≥3+4)^134,136^ | TRUS-guided octant biopsy at 18–24 mo. Sextant or octant ≥50% biopsy cores positive.^124^ | PSA DT<4 yr^124^ PSA velocity >1 ng/mL/yr based on a minimum of 4 values observed over minimum of 6 mo^128,134^ | Repeat imaging only if clinically indicated.^112^ | – | – | Rate of rise of PSA, according to judgment of each patient and clinician.^112^ PSA DT<4 yr, histologic progression, or patient preference, or PSA velocity >1 ng/mL/yr ^128^
Johns Hopkins, US^113^ [20439642] 1994–2008 | Every 6 mo PSA and DRE; annual extended 12-core biopsy | ≥7; or Gleason pattern 4 or 5 | >2 cores cancer positive; or single core >50% cancer (from annual extended 12- core biopsy) | ✓ (PSA kinetics not used as a trigger for intervention) | – | Patient request for curative treatment^137^ | – | Annual surveillance biopsy: Gleason ≥7; or Gleason pattern 4 or 5; or >2 cores cancer positive; or single core >50% cancer.
Toronto-SRCC, Canada^114,125,129,130^ [11395227; 19917860; 20478589; 20846681] 1995–2002 as a phase II trial; 2003-ongoing as an open prospective cohort | Every 3 mo for the first 2 yr and every 6 mo thereafter | Histologic progression: Gleason score upgraded to ≥8 in the rebiopsy of the prostate at 18 months post enrollment | Subsequent biopsies were performed every 3–4 yr to identify biologic progression.^125^ Sextant biopsies were used from 1995 to 2000; since 2000, 10 to 14-core biopsies were performed using the Vienna nomogram.^129^ | PSA progression: PSA DT <2 yr, based on at least 3 separate measurements over a minimum of 6 mo; final PSA >8 ng/ml; p-value <0.05 from regression of ln(PSA) on time. Protocol changes in PSA DT assessment or calculation in 1999 and after 2002.^g^ In 2005 the group developed a general linear mixed model as a clinical decision making aid.^h,130^ | Bone scan annually for the first 2 yr and biennially thereafter. If PSA >15 ng/ml, annual bone scan was performed. TRUS was performed every 6 mo. | – | PAP and serum creatinine | Clinical,^i^ histologic or PSA progression triggered the offer of treatment based on age, extent of disease and comorbidities.
Memorial Sloan-Kettering Cancer Center, US^115^ [21167529] 1997–2009 | Every 6 mo PSA and DRE; biopsy was within 12 to 18 mo starting AS and repeated every 2 to 3 yr | Gleason grade 4 or 5 | >3 positive biopsy cores (minimum 10), biopsy core containing >50% cancer involvement | >10 | – | – | – | Treatment was recommended when the patient no longer met study eligibility criteria during followup.
ProtecT, UK^116^ [19603015] 2000–2008 | PSA every 3 mo in year 1 and ever 6 mo thereafter | – | referred to biopsy if a PSA ≥3 ng/mL; rebiopsy was not routine | ✓ | – | – | – | The aim was “to identify developing cancers early enough to allow treatment with surgery or radiotherapy”^j^ (implied using PSA level or change and/or rebiospy results as triggers)
Dana-Farber Cancer Institute, US^117^ [21167525] 2000–2010 | PSA and DRE every 6 mo; biopsy every 12 to 18 mo | ≥7 | 20-core biopsy; ≥3 positive cores, or >50% of any core involved with cancer | ✓ | – | – | – | Patients with progression^k^ were offered surgery or radiotherapy.
Kagawa Medical Univ., Japan^118^ [18272471] 2002–2003 | PSA every 2 mo for 6 mo, every 3 mo thereafter; Re-biopsy at 1 yr (no data beyond 1 yr) | – | Rebiopsy did not fit initial pathology criteria (i.e., 1–2 positive cores per 6–12 systematic biopsy cores) | PSA DT <2 yr after 6 mo (based on all PSA or most recent 1 yr) | – | – | – | PSA DT <2 yr after 6 mo; rebiopsy did not fit initial pathology criteria
Cleveland clinic, US^119^ [21256549] 2004–2009 | PSA every 6–12 mo, surveillance biopsy usually every 2 yr or sooner | ✓ | ✓ | ✓ | – | – | – | Considering multiple parameters (PSA and PSA kinetics, changes in DRE, quantity of cancer in biopsy specimens, and biopsy Gleason score)
PRIAS, Netherlands^120^ [19817747] 2006 – ongoing | PSA at 3 mo, DRE at 6 mo and standard rebiopsy after 1 yr | >3+3=6 | Biopsy protocol^l^ | PSA DT 0 to 3 yr | – | – | – | PSA DT 0 to 3 yr, T state >2 or rebiopsy findings exceed study inclusion thresholds
PASS, US^121^ [19758683] 2008 – ongoing | PSA every 3 mo, DRE every 6 mo, rebiopsy at 6–12 mo from the time of entry, at year 2, then every 2 yr | Any increase in Gleason grade | – | PSA DT <3 yr | – | – | – | Biochemical progression; clinical progression (a stepwise increase in tumor stage by DRE or identification of regional or distant metastasis)

f Cleveland Clinic Foundation, Memorial Sloan-Kettering Cancer Center, University of British Columbia and University of Miami

g For the first 4 yr of the study, PSA DT <2y was used as a trigger. This criterion identified 10% of patients as high-risk and was considered overly stringent. In 1999 the cut-off was increased to 3 yr. From 1995 to 2002 PSA DT was calculated by a statistician using linear regression of all PSA values after the patient left the clinic and the 95% upper bound confidence limit of PSA DT had to be <3 yr. Later PSA DT was calculated by physicians who used PSA fluctuations to determine whether PSA DT was “truly” <3 yr.

h The model generates 2 reclassification curves (high and low risk) which, when overlaid over PSA data of each patient, defines 3 risk zones of high, intermediate and low risk of reclassification. A patient with a PSA consistently in the high risk zone is recommended to undergo treatment.

i Clinical progression = at least one of the following: >2 times of the product of the maximum perpendicular diameters of the primary lesion as measured digitally; symptoms requiring TURP; development of ureteric obstruction; radiological or clinical evidence of distant metastasis.

j Source: http://www.epi.bris.ac.uk/protect/

k Progression criteria: (1) 3 or more positive cores, (2) increased grade (Gleason score 7 or greater) and/or (3) more than 50% of any core involved with cancer.

l PRIAS protocol can be found: http://www.erspc-media.org/media/publications/PRIAS%20Project_background.pdf (assessed 7/15/2011)

DT = doubling time; PSA = prostate-specific antigen; TNM = tumor-node-metastasis system; TURP = transurethral resection of the prostate; yr = yr(s); wk = wk(s); mo = mo(s); SRCC = Sunnybrook Regional Cancer Center; BCCA = the British Columbia Cancer Agency; DRE = digital rectal examination; WW = watchful waiting; AS = active surveillance; EM = expectant management; PAP = prostate acid phosphatase; PSA = prostate specific antigen; TRUS = Transrectal ultrasound; CT = computerized tomography; PSA = prostate-specific antigen; TNM = tumor-node-metastasis system; SRCC = Sunnybrook Regional Cancer Center; BCCA = the British Columbia Cancer Agency; ED = erectile dysfunction; PRIAS = Prostate cancer Research International; ProtecT = Prostate testing for cancer and Treatment; UCSF=University of California at San Francisco; European Randomized Study of Screening for Prostate Cancer = ERSPC; VA = Veterans Affairs; MSKCC = Memorial Sloan-Kettering Cancer Center

✓ = item was used as part of monitoring strategy but explicit criteria were not defined

– = item was not used or not reported as part of monitoring strategy

All 16 cohorts included regular PSA testing in the followup protocol (Tables 4 and 5). DRE was included in the followup protocols of 12 of the cohorts. Fourteen cohorts included routine rebiopsy (Figure 5). The testing frequency of PSA, DRE, and rebiopsy varied across the cohorts. One cohort also incorporated a regular bone scan schedule. Criteria for recommending curative treatments varied across the cohorts. The recommended treatments were not standardized and were left at the discretion of treating physicians and patients in many of the cohorts.

Figure 5 Followup frequencies of 16 unique AS cohorts^a^

^a^Cohorts of active surveillance in chronological order of starting enrollment year. Some cohorts had multiple publications providing different pieces of information on followup protocol. In this case, only the earliest publication was used as the primary citation of the cohort. See Table 2.5 for more detailed monitoring criteria in each cohort.

Legends: ✓* = every 3–4 mo; ✓** = every 3–4 years; ✓*** = every 2 mo for 6 mo. Merged cell represents a range of followup frequency; for example, a merged cell of 3 and 6 mo with a check mark in the middle of the merged cell means a followup frequency of 3 to 6 mo.

MSKCC= Memorial Sloan-Kettering Cancer Center; UCHC= University of Connecticut Health Center; Four academic medical centers=Cleveland Clinic Foundation, University of British Columbia and University of Miami; UCSF= University of California at San Francisco; ProtecT= Prostate testing for cancer and Treatment Trial; PRIAS= Prostate cancer Research International Active Surveillance; PASS= the Canary Prostate Active Surveillance Study)

Gleason score. Twelve cohorts (21 publications) used the Gleason score as part of monitoring criteria for disease progression.^106–108,110–115,117,119–121,124,125,127–132^ Generally, disease progression was defined as a Gleason score or pattern greater than those used in the eligibility criteria for AS (Table 2). One cohort did not use the Gleason score as part of eligibility criteria for AS, but reported the use of any increase in the Gleason grade as part of monitoring criteria for disease progression.^121^

Number of cores positive for cancer. Eight cohorts (9 publications) used the minimal number of biopsy cores positive for cancer as part of monitoring criteria for disease progression.^106–108,110,113,115,117,118,120^ Two criteria were used: 3 or more (6 cohorts) and greater than 4 (3 cohorts) positive biopsy cores. One cohort reported that “an increased number of cores positive for cancer” was used as one of the parameters for defining disease progression but the specific number of cores was not reported.^108^ The rebiopsy frequencies varied across the cohorts (Figure 5).

Percentage cancer involvement in each core. Six cohorts (8 publications) used more than 50 percent cancer involvement in each biopsy core as part of monitoring criteria for disease progression.^107,112,113,115,117,124,128,132^ Two other cohorts considered an increase in tumor volume as part of monitoring criteria for disease progression, but specific percentage cancer involvement was not reported.^108,119^

PSA. All 16 cohorts included regular PSA testing in the followup protocol. The testing frequency varied across the cohorts (Figure 5). Six cohorts considered rising PSA and/or PSA kinetics as part of triggers for treatment but did not specify the detailed criteria. One cohort explicitly reported that PSA kinetics was not used as part of triggers for intervention. Nine cohorts used a variety of PSA triggers for treatment (Figure 5): PSA doubling time ranging from <1 to <4 years (6 cohorts), various PSA velocity criteria (4 cohorts), and PSA greater than 10 ng/mL (1 cohort). The number of cohorts do not sum to the total number of cohorts because some cohorts used multiple criteria. Of these, Toronto-Sunnybrook Regional Cancer Center cohort changed the original PSA doubling time trigger (PSA doubling time < 2 years in the first 4 years of the study) to PSA doubling time < 3 years in 1999.^130^ In 2005, the same group also added risk zone to the protocol (the group developed a clinical decision making aid that can define 3 risk zones of high, intermediate and low risk of reclassification when overlaid with PSA data from each patient).^130^ A patient with a PSA consistently in the high risk zone is recommended to undergo treatment. Two cohorts did not use PSA kinetics as a trigger for treatment.^113,117^

Imaging. One cohort performed annual bone scan for the first 2 years and biennially thereafter.^114,125,129,130^ Another cohort reported that magnetic resonance imaging of the prostate was selectively performed every 1 to 3 years during followup.^109^

Behavioral indicators. No study based used a formal assessment of any behavioral indicator to initiate active treatment as part of their followup protocol, but one cohort explicitly reported that some patients requested treatment due to anxiety related to increasing PSA.^108^

### Observational Management Strategies with Palliative Intent

We identified 13 unique cohorts reporting followup protocols for patients who initially received no treatment and who were subsequently treated only for symptomatic progression. We labeled these observational management strategies as having primarily palliative intent. Of these cohorts, seven are in the United States; two in Canada; four in the UK; one in Sweden; one across Finland, Sweden, and Iceland; one in the Netherlands; and one in Taiwan (Table 6). Six cohorts were formed in the pre-PSA screening era. Howard University College of Medicine was the first institution to report enrollment of patients into an observational management program in 1967.

Table 6 Unique 13 cohorts of observational management strategies with palliative intent

Cohorts or Centers | Country | Beginning of enrollment (year)
Howard University college of Medicine^138^ | US | 1967^a^
Orebro Medical Center^139^ | Sweden | 1977 a
North Stockholm^140^ | Sweden | 1978 a
Freeman Hospital^141^ | UK | 1978 a
Western General Hospital^142^ | UK | 1978 a
Taichung Veterans Hospital^143^ | Taiwan | 1983 a
Scandinavian Prostate Cancer Group Study Number 4 (SPCG-4) trial^144^ | Finland, Sweden, and Iceland | 1989
Erasmus University Hospital^145^ | Netherlands | Before 1990
Royal Marsden Hospital (before 2002)^112^ | UK | 1993
Prostate Cancer Intervention Versus Observation Trial (PIVOT)^146^ | US | 1994
Watchful Waiting Study^147^ | US | 1998
Hospitals in Manchester region^148^ | UK | Not reported (publication year 2001)
University of Florida^149^ | US | 2003

Hospitals in Manchester region= University Hospital of South Manchester, Withington Hospital, Christie Hospital; Hope Hospital. Some cohorts had multiple publications providing different pieces of information on eligibility criteria and followup protocol. In this case, only the earliest publication was used as the primary citation of the cohort. Details are described in Table 7 and 8.

a Early cohorts that did not use PSA as part of eligibility criteria or followup protocols. These cohorts are assumed to have formed during the pre-PSA screening era.

#### Common Metrics: Eligibility Criteria for Observational Management Strategies with Palliative Intent

(Table 7)

Table 7 Eligibility criteria for enrollment in protocols with palliative intent in chronological order of starting enrollment year

Center, Country [Pubmed ID] Enrollment years | Term used | Age (yr) | PSA (ng/mL) | Gleason score | # biopsy cores /% cores | Imaging | Stage | Behavioral indication (other than patients’ choice or preference)
Howard University College of Medicine, US^138^ [1600492] 1967–1989 | EM /WW | – | – | – | – | – | Stage A and B | –
Orebro Medical Center, Sweden^139^ [7933233] 1977–1984 | Deferred treatment | Any (all patients >75 were not given any initial treatment from 1978–79) | – | – | – | – | T0-T2 | –
Northern Stockholm region, Sweden^140^ [17467883] 1978–1982 | WW | – | – | – | – | Normal bone scan | 71% T1-2 and 29% with T3 | –
Freeman Hospital, UK^141^ [3191340] 1978–1985 | Deferred treatment | – | – | – | – | – | – | Patients without symptoms after initial outflow tract surgery or biopsy
Western General Hospital, UK^142^ [8343901] 1978–1990 | Deferred treatment | – | – | – | – | – | incidental (T0/stage A) or localized *T1/stage B1/B2) | –
Taichung Veterans Hospital, Taiwan^143^ [12854876] 1983–1996 | No treatment | – | – | – | – | – | T1a | –
SPCG-4, Finland, Sweden, and Iceland^144^ [12226148] 1989–1999 | WW | <75 | <50 | If diagnosed with an extended biopsy protocol, <25% of the tumor Gleason grade 4 and <5% grade 5 | – | Bone scan negative | T0d, T1 or T2; T1c (after 1994) | –
Erasmus Univ. Hospital, Netherlands^145^ [7544841] ≤ 1990; 1993–2006^150^ | No treatment /AS^150^ | 50–75^a,151^ | ≤ 15^150^ | <8^150^ | – | Bone scan and chest x-ray negative | T1c or T2^150^ | No treatment decision was made by the urologist in discussion with the patient and his family, with respect to patient age, general health, clinical stage and patient preference.^145^ All patients had estimated survival >1 yr.
Royal Marsden Hospital, UK^112^ [15839912] 1993–2002 | WW | – | Any | ≤ 7 | – | – | any T stage, N0/X, M0/X | Unsuitable for RP typically because advanced age or comorbidities.
PIVOT, US ^146^ [18783735] 1994–2002 | WW | ≤ 75 | ≤ 50 | Any | – | Bone scan negative | T1-T2/Nx/M0 | –
Watchful Waiting Study, US^147^ [14501381] 1998–2003 | WW | <85 | <50 | <8 | – | – | – | > 3-yr life expectancy, no history of any type of malignancy within the past 5 yr with the exception of non-melanoma skin cancer
Hospitals in Manchester region, UK^148^ [11711356] NR | WW | – | <50 | – | – | Bone scan negative | – | –
Univ. of Florida, US^149^ [18263992] 2003–2006 | EM | – | – | – | – | – | “Low-stage, low-grade disease” | Severe medical condition with a life expectancy of <10 yr

WW = watchful waiting; EM = expectant management; NR = not reported; DT = doubling time; mo = month(s); PAP = prostate acid phosphatase; PSA = prostate specific antigen; TRUS = Transrectal ultrasound; CT = computerized tomography; PSA = prostate-specific antigen; TNM = tumor-node-metastasis system; US = ultrasound; yr = year(s); ED = erectile dysfunction; SPCG-4 = Scandinavian Prostate Cancer Group Study Number 4; PIVOT = Prostate Cancer Intervention Versus Observation Trial; VA = Veterans Affair

a ERSPC-screening protocol, carried over to AS selection criteria because patients were identified from ERSPC

b University Hospital of South Manchester, Withington Hospital, Christie Hospital; Hope Hospital

The six cohorts in the pre-PSA screening era enrolled patients primarily based on clinical staging alone. Of these, four cohorts enrolled patients with clinical stage T2 or less,^138,139,142,143^ one cohort enrolled “patients without symptoms after initial outflow tract surgery or biopsy,”^141^ and the other cohort enrolled both patients with clinical stage T1-2 (71 percent) and T3 (21 percent) but all patients had normal bone scan findings.^140^

Of the seven cohorts in the PSA screening era, three cohorts (4 publications) enrolled patients with clinical stage T2 or less,^137,145,146,150^ one cohort enrolled patients with “low-stage, low-grade disease,”^149^ one cohort enrolled patients with any T stage N0/X, M0/X,^112^ and the other two cohorts did not report or did not use clinical stage as part of patient eligibility criteria. The commonly used patient eligibility criteria were PSA (5 cohorts), age (4 cohorts), Gleason score (4 cohorts), and normal bone scan findings (4 cohorts). More details of each eligibility criterion in these seven cohorts are described in the following sections.

Age. Four cohorts (5 publications) reported age as part of patient eligibility criteria.^144–147,150^ The age criterion was less than 75 years in the WW arm in SPCG-4 (Scandinavian Prostate Cancer Group Study Number 4)^144^ and PIVOT (Prostate Cancer Intervention Versus Observation Trial),^146^ and less than 85 years in the Watchful Waiting Study.^147^ One cohort at Erasmus University hospital enrolled patients from the European Randomized Study of Screening for Prostate Cancer (ERSPC).^145,150^ The ERSPC-screening protocol was carried over to become part of the patient selection criteria for this cohort, which required patients’ age to be between 50 and 75 years old.^151^

Gleason score. Four cohorts (5 publications) used the Gleason score as part of patient eligibility criteria.^112,144,145,147,150^ The Gleason score criterion was less than 8 in three cohorts.^112,145,147,150^ The SPCG-4 cohort reported that “patients whose condition was diagnosed with an extended biopsy protocol were accepted if less than 25 percent of the tumor was Gleason grade 4 and less than 5 percent grade 5.”^144^

Number of cores positive for cancer. None of the 13 unique cohorts used number of cores positive for cancer as part of patient eligibility criteria.

Percentage cancer involvement in each core. None of the 13 unique cohorts used percent cancer involvement in each core as part of patient eligibility criteria.

Prostate specific antigen. Five cohorts (6 publications) used PSA threshold as part of patient eligibility criteria.^144–148,150^ Two criteria were used: PSA less than 50 ng/mL (4 cohorts)^144,146–148^ and less than or equal to 15 ng/mL (1 cohort).^145,150^

Imaging. Four cohorts (5 publications) required normal bone scan findings as part of patient eligibility criteria.^144–146,148,150^ One cohort also required patients to have normal chest radiograph findings to be eligible for the observational management program.^145,150^

Behavioral indicators. No behavioral indicator was used explicitly as a criterion for patient enrollment in the 13 unique cohorts.

#### Followup Protocols of Observational Management Strategies with Palliative Intent

(Table 8)

Table 8 Monitoring criteria in protocols of observational management strategies with palliative intent in chronological order of starting enrollment year

Center, Country [Pubmed ID] Enrollment years | Monitoring schedule | PSA | Gleason score | # biopsy cores /% cores | Imaging | Behavioral indication | Additional laboratory tests | Triggers for interventions
Howard University College of Medicine, US^138^ [1600492] 1967–1989 | Every 3 mo for the first 5 yr, every 4–6 mo thereafter. Assessment included DRE, PAP and since 1985 a PSA was done. | ✓ (after 1985) | – | – | Annual bone scan; CT of the pelvis was used infrequently | – | PAP | Signs and/or symptoms of disease activity.
Orebro Medical Center, Sweden^139^ [7933233] 1977–1984 | Every 6–12 mo clinical exam, PAP, and bone scans. PSA only performed in the last few yr | ✓ (in the last few yr) | – | – | Bone scan | – | PAP | Patients were treated hormonally if disease progressed for they had symptoms of progression.
Northern Stockholm, Sweden^140^ [17467883] 1978–1982 | Every 3 to 6 mo for the first 2 yr and every 6 to 12 mo thereafter with DRE and PAP; annual rebiopsies during the first 4 yr | – | – | – | Bone scan every 12 to 18 mo | – | PAP | Treatment was offered if clinical progression with symptoms
Freeman hospital, UK^141^ [3191340] 1978–1985 | NR (“Disease progression was monitored”) | – | – | – | 6-monthly bone scans (after 1983) | – | Acid and alkaline phosphatase | No treatment until symptomatic progression.
Western General Hospital, UK^142^ [8343901] 1978–1990 | Every 3 mo | – | – | – | Chest X-rays, skeletal X-rays and bone scans every 6 mo | – | ✓ | Progression of disease (i.e., development of metastases (M1) or elevation of PAP to > 2 u/l) and/or development of symptoms.
Taichung Veterans hospital, Taiwan^143^ [12854876] 1983–1996 | Every 3–6 mo PSA and DRE (after 1990, introduction of PSA) | ✓ (after 1990) | – | – | – | – | – | No treatment until there was evidence of cancer progression.
SPCG-4, Finland, Sweden, and Iceland^144^ [12226148] 1989–1999 | Every 6 mo in the first 2 yr, then every 1 yr | ✓ | – | Rebiopsy was not routinely undertaken^152^ | A bone scan and chest radiograph were obtained annually until 1997; thereafter, chest radiographs were obtained annually for the first 2 yr | – | Hemoglobin, creatinine, alkaline phosphatase | Adjuvant local or systemic treatment was not given. TURP was as a treatment for local progression.^a^
Erasmus Univ. hospital, Netherlands^145^ [7544841] ≤ 1990; 1993–2006^150^ | Usually Followed clinically every 6 mo; Follow-up regimens varied among local practices^150^ | ✓ | – | – | “Bone scan and chest x-ray were repeated regularly” | – | Alkaline phosphatase | Local b and metastatic progression were evaluated. Subjective progression, like obstructive micturition or pain, was considered for treatment decisions.^145^ The authors reported that of 13 patients with progression, 6 started treatment (5 for subjective symptoms; 1 for objective progression only). The authors also reported that PSA progression may serve as a trigger point to treatment.^150^
Royal Marsden Hospital, UK^112^ [15839912] 1993–2002 | Every 6 mo PSA and DRE | ✓ | – | – | – | – | – | Symptomatic prostate cancer progression
PIVOT, US ^146^ [18783735] 1994–2002 | Every 6 mo PSA | ✓ | – | – | Bone scan every 5 yr | – | – | Discouraged treatment for asymptomatic progression (eg, per PSA)
Watchful Waiting Study, US^147^ [14501381] 1998–2003 | Every 3 mo PSA | ✓ | – | – | – | – | – | Developing progressive disease
Hospitals in Manchester, UK^148^ [11711356] NR | Every 6 mo PSA | >50 | – | – | All patients underwent “multiple bone scans” (all negative), | – | – | Hormonal manipulation was demanded by the protocol when the PSA rose to 50 ng/mL.
Univ. of Florida, US^149^ [18263992] 2003–2006 | Every 3 mo PSA and DRE; Repeat biopsy about 6 mo after the initial diagnosis. | ✓ | – | – | – | – | – | Cancer progresses or symptoms become imminent.

WW = watchful waiting; EM = expectant management; NR = not reported; DT = doubling time; mo = month(s); PAP = prostate acid phosphatase; PSA = prostate specific antigen; TRUS = Transrectal ultrasound; CT = computerized tomography; PSA = prostate-specific antigen; TNM = tumor-node-metastasis system; US = ultrasound; yr = year(s); ED = erectile dysfunction; SPCG-4 = Scandinavian Prostate Cancer Group Study Number 4; PIVOT = Prostate Cancer Intervention Versus Observation Trial; VA = Veterans Affairs

✓ = item was used as part of monitoring strategy but explicit criteria were not defined

– = item was not used or not reported as part of monitoring strategy

a Local progression was defined as a palpable transcapsular tumor growth; symptoms of obstruction of the flow of urine that necessitated intervention, or both.

b Local progression was defined as symptoms (subjective), increase in T category, increase in prostate size on DRE by 25%, or increase in ultrasound measured volume >40%.

Five of the six cohorts in the pre-PSA screening era included regular prostate acid phosphatase (PAP) testing and bone scan in the followup protocol.^138–142^ The sixth cohort reported regular PSA and DRE in the followup protocol for patients who received no treatment after the introduction of PSA in 1990.^143^ No information regarding the followup protocol in the pre-PSA screening era was provided. The monitoring frequency varied across these six cohorts (Figure 6).

Figure 6 Followup frequencies of 13 unique cohorts of observational management strategies with palliative intent^a^

^a^Cohorts of watchful waiting in chronological order of starting enrollment year. See Table 8 for more detailed monitoring criteria in each cohort.

Legends: ✓* = every 3 mo for the first 5 yr; every 4–6 mo thereafter; ✓** = usually every 6 mo but followup regimens varied among local practices. Merged cell represents a range of followup frequency; for example, a merged cell of 3 and 6 mo with a check mark in the middle of the merged cell means a followup frequency of 3 to 6 mo. PAP = prostate acid phosphatase HUCM = Howard University College of Medicine; Northern Stockholm = Northern Stockholm region in UK; SPCG-4 = Scandinavian Prostate Cancer Group Study Number 4 trial; PIVOT= Prostate Cancer Intervention Versus Observation Trial; Hospitals in Manchester region= University Hospital of South Manchester, Withington Hospital, Christie Hospital; Hope Hospital

^b^The authors reported that all patients underwent “multiple bone scans” during followup and all had normal findings.

All seven cohorts (8 publications) in the PSA screening era included regular PSA testing.^112,144–150^ The monitoring frequency varied across the cohorts (Figure 6). Compared with AS cohorts (see previous section), rebiopsy was not commonly included in the followup protocol among WW cohorts.

Gleason score. None of the 13 unique cohorts used the Gleason score as part of followup protocols for patients who did not receive initial treatments.

Number of cores positive for cancer. None of the 13 unique cohorts used number of cores positive for cancer as part of followup protocols for patients who did not receive initial treatments.

Percentage cancer involvement in each core. None of the 13 unique cohorts used number of cores positive for cancer as part of followup protocols for patients who did not receive initial treatments.

PSA. Three cohorts formed in the pre-PSA screening era reported that PSA testing became part of followup protocol after PSA became available.^138,143,147^ All six cohorts in the PSA screening era included regular PSA testing as part of followup protocol. However, rising PSA concentration alone was not used as a trigger for treatment in five cohorts.^112,144,146,147,149^ The sixth cohort reported that “hormonal manipulation was demanded by the protocol when the PSA rose to 50 ng/mL.”^148^

Imaging. Five cohorts in the pre-PSA screening era included regular bone scan in the followup protocol.^138–142^ The monitoring frequency varied across the cohorts (Figure 6). One cohort also included regular chest and skeletal radiographs in the followup protocol.^142^ Another cohort reported that computed tomography of the pelvis was conducted infrequently.^138^ Three cohorts (4 publications) in the PSA screening era included regular bone scans and chest radiographs in the followup protocol.^144–146,150^ The monitoring frequency varied across the cohorts (Figure 6). Another cohort reported that all patients underwent “multiple bone scans” during followup.^148^

Behavioral indicators. No behavioral indicator was used explicitly in any of the followup protocols.

### Observational Management Strategies with Unclear Treatment Intent

Six cohorts reported followup protocols but did not report triggers for treatment of prostate cancer, so it is unclear what observational management strategies were used to indicate the need for treatments in those patients who did not receive initial treatments (Table 9). Various terms were used to describe the observational management strategies in these cohorts, including “no treatment,” “expectant management,” “watchful waiting,” and “active surveillance.” The eligibility criteria and followup protocol of these cohorts were summarized in Tables 10 and 11. None of these cohorts used parameters that have not been previously described.

Table 9 Cohorts that did not report triggers for treatment of prostate cancer

Country | Center or Study Name
US | Kansas City Veterans Affairs Hospital University of North Carolina
Canada | British Columbia Cancer Agency Princess Margaret Hospital
Japan | Kagawa Medical University (1990–1998) Kitasato University Hospital

Table 10 Protocols that did not report information on triggers for intervention in chronological order of starting enrollment year

Center, Country [Pubmed ID] Enrollment years | Term used | Age (yr) | PSA (ng/mL) | Gleason score | # biopsy cores /% cores | Imaging | Stage | Behavioral indication (other than patients’ choice or preference)
Kagawa Medical Univ., Japan^153^ [10765093] 1990–1998 | EM;WW | – | “elevated PSA” | ≤6 | 1–2 positive cores per 6 sextant cores; ≤50% involvement of any positive core | – | – | –
Kitasato Univ. Hospital, Japan^154^ [11851612] 1991–2000 | WW | – | – | – | 6 sextant biopsy | – | “clinically localized prostate cancer” | –
Univ. of North Carolina, US^155^ 1991–1996 | EM | – | – | – | – | – | T1c | –
Princess Margaret Hospital, Canada^156^ [21211899] 1995–2010 | AS | – | <10 | <6 | ≤3 positive biopsy cores (<50% of a core involved at initial diagnostic biopsy); fist-time biopsies consisted of 6 cores before 2001 and 11 cores after 2001. | – | T1c-T2a | –
BCCA, Canada^157^ [9445192] NR | WW | – | – | – | – | – | – | Patient wish (37%), reduced life expectancy due to medical problem (19%), physician recommendation (42%); relative contraindication to RT (2%)
Kansas City VA, US^158^ [21172105] 2004–2009 | AS^a^ | – | <20 | <6 | <20% positive biopsy | | ≤ T2 | –

WW = watchful waiting; EM = expectant management; NR = not reported; DT = doubling time; mo = month(s); PAP = prostate acid phosphatase; PSA = prostate specific antigen; TRUS = transrectal ultrasound; CT = computerized tomography; PSA = prostate-specific antigen; TNM = tumor-node-metastasis system; US = ultrasound; yr = year(s); BCCA = British Columbia Cancer Agency

a AS criteria were created explicitly for the analyses only, this is not a prospective AS cohort.

Table 11 Monitoring parameters in cohorts that did not report information on triggers for intervention in chronological order of starting enrollment year

Center, Country [Pubmed ID] Enrollment years | Monitoring schedule | PSA | Gleason score | # biopsy cores /% cores | Imaging | Behavioral indication | Additional laboratory tests | Triggers for interventions
Kagawa Medical Univ., Japan^153^ [10765093] 1990–1998 | NR | PSA DT based on 1^st^ PSA >1 mo after biopsy. ≥3 values at intervals ≥1 mo apart for >6 mo. | – | – | – | – | – | NR
Kitasato Univ. Hospital, Japan^154^ [11851612] 1991–2000 | “a DRE,” generally seen every 3–6 mo “as clinical circumstances dictated.” | – | – | – | Annual bone scan | – | – | NR
Univ. of North Carolina, US^155^ 1991–1996 | PSA at 3 mo; then every 6 mo | Biochemical progression: PSA level increase in 3 consecutive measurements and the total increase was > 5 ng/mL | – | – | – | – | Hematocrit and creatinine every 6 mo | NR
Princess Margaret hospital, Canada^156^ [21211899] 1995–2010 | For the most part, PSA every 3mo for 2 yr and every 6 mo in stable patients; DRE every 6 mo; a confirmatory biopsy within 12 mo and then every 2–3 yr until the patient reached 80 yr of age or refused treatment^a^ | ✓ | – | Repeat biopsies consisted of 10 cores before 2001 and 15–16 cores after 2001. >3 cores or any core involvement >50% | – | – | – | NR Note: Pathologic progression was devalued, defined as increased grade, increased number of cores to more than 3 or any core involvement >50%.
BCCA, Canada^157^ [9445192] NR | PSA generally every 3–6 mo as needed | ✓ | – | – | – | – | – | NR
Kansas City VA, US^158^ [21172105] 2004–2009 | PSA every 3 mo and a repeat TRUS guided prostate biopsy at 1 yr | ✓ | – | All biopsies were performed using a standard 12-core biopsy scheme, but increased number if larger glands | – | – | – | NR

WW = watchful waiting; EM = expectant management; NR = not reported; DT = doubling time; mo = month(s); PAP = prostate acid phosphatase; PSA = prostate specific antigen; TRUS = Transrectal ultrasound; CT = computerized tomography; PSA = prostate-specific antigen; TNM = tumor-node-metastasis system; US = ultrasound; yr = year(s); BCCA = British Columbia Cancer Agency

✓ = item was used as part of monitoring strategy but explicit criteria were not defined

– = item was not used or not reported as part of monitoring strategy

a The authors reported that five physicians in a nonstandardized fashion followed patients, although a relatively similar pattern of care was provided.

### Summary

We identified 16 unique cohorts reporting formal protocols to monitor triggers for curative treatment of prostate cancer. The eligibility criteria for patient selection and followup protocols were heterogeneous.

Among these cohorts, the most commonly used parameter as part of patient eligibility criteria was Gleason score (12 cohorts), no higher than Gleason 6 or 7. More recently, Gleason patterns were also used in some of these AS cohorts, such as no higher than Gleason 3+3 or 3+4. All 16 cohorts enrolled only patients with clinical stages T2 or less and included regular PSA testing in the followup protocol. PSA and Gleason score were the most commonly used parameters as part of monitoring criteria for disease progression. Generally, progression in Gleason was defined as a Gleason score or pattern greater than those used in the eligibility criteria for AS. Regularly scheduled rebiopsy was also a common parameter in the AS followup protocol. Large variation exists in terms of the definitions of disease progression, and the frequencies of AS monitoring protocols.

In contrast to the above AS cohorts, less variability exists in terms of the definitions of eligibility criteria for patient selection and followup protocols among the 13 cohorts of other observational management strategies. All such cohorts used only symptomatic progression as triggers for treatment; thus we labeled these observational management strategies as having primarily palliative treatment intent. Regular bone scan schedule was commonly included in these followup protocols. Rebiopsy was typically not used in these strategies; imaging tests were more commonly used to track disease progression.

Implicit in the Key Question is a comparison between AS and other observational strategies in the modern PSA era. Thus, we compared the 16 unique cohorts reporting formal protocols to monitor triggers for curative treatment with the seven unique cohorts of other observational strategies with primarily palliative intent in the PSA screening era. Enrollment into AS protocols more commonly used Gleason score as a threshold than other observational strategies. They also used the number and percentage of cores positive for cancer as a threshold while none of the other strategies used these factors. Both sets of strategies generally used some sort of PSA criteria, but the thresholds in AS were generally lower (10–15 ng/mL) than the other observational strategies (15 or 50 ng/mL). AS protocols had more clearly defined followup than other observational strategies, with explicit indications for curative treatment including increase in Gleason scores, number and percentage of positive cores (on rebiopsy), and/or PSA velocity. AS protocols generally did not include imaging in their followup protocols. In contrast, other observational strategies typically included imaging in their followup, specifically bone scan and chest radiography. They also generally did not use rebiopsy but they did use PSA in their followup. Comparison of the followup frequencies between AS and other observational strategies (Tables 2.3 versus Table 2.10) showed that PSA testing and DRE were common in both strategies, but somewhat more frequent with AS protocols, at least within the first year of followup.

## Key Question 3 What factors affect the offer of, acceptance of, and adherence to active surveillance?

For this Key Question, eligible studies included: (1) multivariable database analyses of predictors for the offer of, acceptance of, and adherence to AS (or WW), (2) survey or interview type studies addressing the same issues, and (3) experimental studies that examined a factor of interest addressing the same issues, when applicable (e.g., the effect of decision aids on the acceptance of AS). Eligible studies reporting multivariable analyses had to adjust for age and disease stage or risk. We excluded studies in which AS/WW was not analyzed separately from nonaggressive treatments like ADT. Similarly, for survey or interview type studies, only those including men with prostate cancer and reporting data directly relevant to AS/WW were reviewed. Of note, the outcomes of many of the studies were either treatment with an observational strategy or interruption (cessation) of the observational strategy. Studies generally did not directly analyze the offer of, acceptance of, and adherence to AS.

Figure 7 summarizes the studies reviewed for Key Question 3. Twenty-five studies reported multivariable analyses of the association between different physician or patient factors, delivery system, and the offer of, acceptance of, and adherence to, AS or WW.^66,77,159–181^ These analyses were mainly conducted on the CaPSURE or SEER databases. In addition, 16 survey or interview type studies explored similar associations.^122,182–196^ No experimental study specifically examined factor(s) addressing the offer of, acceptance of, and adherence to AS. However, one relevant systematic review detailed the use of decision-making tools and aids in the management of men with prostate cancer.^197^ As described in the Methods chapter, the included studies were those initially identified in our search for publications concerning active surveillance, and from references in relevant reviews. We did not do a targeted search for the specific factors of interest.

Figure 7 Evidence map for key question 3

Studies considered for Key Question 3 are depicted as circles with size proportional to the study sample size, stratified by design (focus groups, surveys, or studies reporting multivariable prediction models) and outcomes assessed (“offer” of, “acceptance” of, “adherence” to observational management strategies or prediction of having received observational management). One study that reported factors influencing the acceptance of randomization versus non-randomized choice of treatment is not shown. Hollow circles represent studies including prostate cancer patients only; black circles represent studies of physicians only; gray circles represent studies including both patients and physician. Placement within each box is random. MV = multivariable; WW = watchful waiting.

Figure 7 summarizes the studies reviewed for Key Question 3. These studies are depicted as circles with size proportional to the study sample size, stratified by design (focus groups, surveys, or studies reporting multivariable prediction models) and outcomes assessed (“offer” of, “acceptance” of, “adherence” to observational management strategies or prediction of having received observational management). One study that reported factors influencing the acceptance of randomization versus non-randomized choice of treatment is not shown. Hollow circles represent studies including prostate cancer patients only; black circles represent studies of physicians only; gray circles represent studies including both patients and physician. The figure generally depicts that multivariable analyses have the largest sample sizes, followed by survey types studies with focus groups having the smallest sizes.

It should be noted that among this group of studies, only two specifically targeted men who were put on an active monitoring protocol with triggers for curative treatments.^172,173^ The remainders were analyses of men who were either not treated or not initially treated. We could not determine whether they were on an active monitoring protocol with triggers for curative treatments.

Only the qualitative results of the multivariable analyses are described in this section. Because the reviewed studies used heterogeneous coding schemes for their predictors (for example, age was used as a continuous variable in some studies but as a nominal [discrete] variable in others) and adjusted for varying sets of confounding variables, meaningful comparison of effect sizes across studies is precluded. For these reasons, we do not present effect estimates for each predictor of interest from these analyses (such as odds ratios for predicting treatment received, or hazard ratios for WW interruption), although detailed quantitative information is available in Appendix Tables C3.1 to C3.3.

It should also be noted that the common method for reporting “adherence to AS” in the literature is the “interruption of AS” to seek definitive treatments and we follow this convention in our review. A man could interrupt AS to seek curative treatments for several reasons, among which: 1) the person meets some criteria on AS protocol indicative of disease progression that would call for curative treatment, 2) the person does not meet criteria for curative treatment (i.e., continued surveillance is indicated), but due to personal preference, he decides to stop AS and pursue curative treatment, and 3) the person decides to forgo present or future curative treatment (e.g., because of advanced age or new comorbidities) and switches to WW. The first reason would commonly be considered “adherent” (the person is following the protocol) and the latter two “not adherent” (he chose to discontinue the AS protocol even though there was no indication of disease progression). However, the studies reviewed largely ignored this distinction or had insufficient data to make this distinction and assessed adherence by reporting “interruption of AS” to seek definitive treatments.^aaa^ The one exception was those studies that assessed patient anxiety leading to curative treatment despite not meeting disease progression criteria.

aaa We do not know the proportion of non-adherence. We do know that the proportion of patients on AS who went on to receive active treatments ranged from 16 to 54 percent with a median followup of 1 to 7 years (see Appendix Table C5.1).

### Physician Factors (Appendix Tables C3.1–3.3)

#### Primary Care

Offer of AS. No study specifically examined how the involvement of a primary care physician in the decisionmaking process might affect the offer of AS.

One survey of 381 New Zealand general practitioners given clinical vignettes reported that 45 percent of general practitioners would recommend WW if a patient’s life expectancy was less than 10 yr, but only 3 percent would recommend WW if a patient’s life expectancy was more than 10 yr.^184^

Acceptance of AS. No study specifically examined how a patient’s primary care physician might affect the acceptance of AS.^bbb^

bbb We are aware of one age- and comorbidity-stratified analysis of 85,088 men with clinically localized disease identified from the SEER-Medicare database which concluded that men who saw a primary care physician after diagnosis were more likely to have AS/WW than those who did not (e.g., for men aged 75–79 years with comorbidity index of ≥2, 76.5 vs. 12.2 percent, see original paper for results from other categories).^198^ This study did not meet our multivariable analysis inclusion criterion.

Three survey/interview-type studies (sample sizes were 25,^183^ 102,^187^ and 185^122^) reported that physician recommendation (urologists or radiation oncologists) was the most influential factor in a patient’s decision (30 percent in Holmboe 2000;^187^ 73 percent in Gorin 2011;^122^ no quantitative data were available in Davison 2009^183^) to elect or not elect AS. Two other surveys of men with prostate cancer (sample sizes were 654^185^ and 231^190^) reported that physician recommendation (urologists, radiation oncologists, and others) was most influential in reaching a treatment decision (51 percent^185^ and 57 percent^190^). However, one multivariable analysis of men in the Prostate Cancer Research International: Active Surveillance study (PRIAS) reported that patients who perceived that physician played the most important role in shared decision-making process also had higher decisional conflict (more doubts) regarding the patient’s choice of AS (“This suggests that men who perceive that they have actively participated in the treatment decision-making process have fewer doubts regarding their treatment decision”).^181^

Adherence to AS. No study specifically examined how a patient’s primary care physician might affect adherence to AS. However, one survey of 53 men on AS who ultimately received treatment reported that 81 percent believed that treatment was favored by their physicians (urologists, radiation oncologist, medical oncologist, primary care physician), which was the primary cause of the change in plan for AS.^186^ In contrast, physician notes revealed that for only 24 percent of the patients was there documentation that the physician recommended treatment due to clinical or biochemical evidence of tumor progression, leading to the study’s conclusion that physicians more often perceive that patients themselves initiated the treatment decisions.

#### Diagnosing Physician

Offer of AS. No study specifically examined how the involvement of the diagnosing physician in the decisionmaking process might affect the offer of AS. However, one survey of 185 men already on AS reported that AS was offered by 36 percent of the physicians who had made the initial diagnosis.^122^

Acceptance of AS. No study or survey specifically addressed how the involvement of the diagnosing physician might affect the acceptance of AS.

Adherence to AS. No study specifically examined how the involvement of the diagnosing physician might affect the adherence to AS.

#### Consultant—2nd Opinion

Offer of AS. No study specifically examined how the involvement of a consulting physician for a second opinion in the decisionmaking process might affect the offer of AS. However, a description of interviews with 18 couples in which the men were recently diagnosed with early stage prostate cancer and had not yet decided on a treatment reported that “the urologist had recommended seeking a second opinion and indeed had offered to facilitate such a referral [for several couples]. None followed through with this suggestion... The fact that the urologist [had recommended seeking] a second opinion only further reinforced their trust and confidence....”^194^

In an interview of 108 men in Australia with newly diagnosed localized prostate cancer, concerning their urological consultation, 71 percent reported that their urologists discussed WW (versus 92 percent for RP and 87 percent for RT).^192^

One survey of 200 urologists querying their preferences for treatments for men with localized prostate cancer and few comorbidities reported that 67 percent preferred RP, 29 percent preferred RT, and 4 percent preferred WW.^193^ The same study also surveyed 780 men with all stages of prostate cancer and reported divergent opinions (patient versus physician) on whether treatment options were discussed: 20 percent of the men versus 1 percent of the urologists felt that treatment options were not discussed. It should be noted, however, that the urologists in the survey were not necessarily the surveyed patients’ own urologists.

One survey of 238 men with newly diagnosed prostate cancer and their 25 urologists reported on their office encounters.^182^ Ninety-five men presented for an initial consultation, and 143 men presented for a second opinion visit. The urologists recommended 0.52 more treatment options (SE 0.19, P < 0.001) in the initial consultation setting than in the second opinion visit setting. For men with low-risk disease, 25 percent of the urologists recommended AS and 77 percent recommended RP in the initial consultation setting, but only 16 percent recommended AS and 91 percent recommended RP in the second opinion visit setting. The survey also reported a discrepancy between what the physicians recommended and what the patients heard: in those patients for whom the urologists recommended RP, 67 percent reported receiving the recommendation; in those patients for whom the urologists recommended RT or ADT, only about 25 percent of the patients reported receiving the recommendation.

Acceptance of AS. No study or survey specifically addressed how the involvement of a consulting physician might affect the acceptance of AS.^ccc^

ccc We are aware of one age-stratified analysis of 85,088 men with clinically localized disease identified from the SEER-Medicare database which concluded that for all age groups, men who saw urologists either with or without medical oncologists were more likely than those seen by both urologists and radiation oncologists to receive AS/WW (all ages combined: 26.3 percent or 34.1 percent vs. 4.6 percent, respectively; see original paper for age-stratified results).^198^ This study did not meet our multivariable analysis inclusion criterion.

Adherence to AS. No study or survey specifically addressed how the involvement of a consulting physician might affect adherence to AS.

### Clinical Factors

Offer of AS. One survey of 1063 urologists and radiation oncologists reported that about 10 to 20 percent would recommend WW for a patient with a PSA of around 5 ng/mL and a Gleason score of around 4 or 5 (the given scenario was a 65 years old man in good health, with negative DRE and no evidence of nonlocalized disease), but almost none would recommend WW for those with higher PSA or Gleason scores (Fowler 2000).^188^ The responses of urologists and radiation oncologists did not differ significantly.

#### Acceptance of AS

Age. Twelve multivariable analyses provided results for age with respect to AS/WW.^66,77,159,161,162,166,171,174,175,177,179,180^ All reported men who were older (generally aged 65 to 75 years) had an increased probability of receiving AS/WW versus active treatments.

Comorbidities. Five multivariable analyses reported that men with an increased number of comorbidities also had an increased probability of receiving AS/WW versus active treatments.^66,77,159,164–166^ Two multivariable analyses did not find an association.^177,180^

Gleason score. Three multivariable analyses reported that men with a higher Gleason score also had a decreased probability of receiving AS/WW versus any other treatment.^77,180^ or RP.^171^

Histopathology. Two multivariable analyses provided results for histopathology with respect to AS/WW.^159,166^ Both reported that men with well-differentiated, as compared to either moderately or poorly differentiated, prostate tumors had an increased probability of receiving AS/WW versus other treatments.

Stage. Three multivariable analyses reported that men with higher stage disease (local versus in situ;^199^ T2 versus T1^171,177^) had a decreased probability of receiving AS/WW versus active treatments.

PSA. Three multivariable analyses reported that men with increased PSA had a decreased probability of receiving AS/WW versus active treatment.^77,171,177^ One multivariable analysis of men with high risk but nonmetastatic prostate cancer reported that higher PSA (>20 vs. ≤10ng/mL) was associated with increased probability of receiving AS/WW versus RP.^179^

Risk groups. Two multivariable analyses reported that men assessed as D’Amico low-risk^200^ (versus intermediate- or high-risk) had an increased probability of receiving AS/WW versus active treatments.^66,161^

#### Adherence to AS

Age. Four multivariable analyses analyzed age with respect to interruption of AS/WW.^164,168,175,176^ Two found that men who were younger had an increased probability of receiving definitive treatments,^168,175^ and two found that age was not a factor.^164,176^

Comorbidities. Three multivariable analyses reported that the number of comorbidities was not associated with interruption of AS/WW.^164,175,176^

Gleason score. Five multivariable analyses reported that Gleason score at diagnosis was not associated with interruption of AS/WW.^168,172,174–176^

Histopathology. No study analyzed histopathology to describe tumor differentiation with respect to interruption of AS.

Stage. Three multivariable analyses reported that men with higher stage disease (T2 versus T1) had an increased probability of interruption of AS/WW to seek secondary treatment.^168,175,176^ One analysis reported that disease stage (T2 versus T1) was not a significant predictor of the receipt of curative treatment.^174^

PSA. Two multivariable analyses reported that men with increased PSA at diagnosis also had an increased probability of interruption of AS/WW to seek active treatments.^168,175^ One analysis reported that neither initial PSA nor PSA density was predictive of men who interrupted AS to seek radical treatment, but the free to total PSA ratio was predictive of the probability of interruption of AS.^172^ One analysis reported that initial PSA was not predictive of men who interrupted AS to seek definitive treatment, but that a short PSA doubling time was (< 2 yr vs. 2 to 5 yr).^176^ Two other multivariable analyses also reported that increased PSA velocity during followup was predictive of interruption of AS to seek active treatments.^164,174^

Risk groups. One multivariable analysis reported that patients assessed as D’Amico low-risk (versus intermediate- or high-risk) had a decreased probability of interruption of AS/WW to seek active treatment,^167^ while two reported that risk classification was not a significant predictor in the interruption of AS/WW.^164,168^

### Patient Factors

#### Family Involvement

Offer of AS. No study or survey specifically addressed how family involvement might affect the offer of AS.

Acceptance of AS. One survey reported that 19 percent of 654 men,^185^ and another survey 9 percent of 231 men,^190^ mentioned that advice from family and friends was the most influential factor in reaching a treatment decision. In a content analysis of focus group or interview discussion including a total of 44 men with localized prostate cancer, 20 men reported relying on influential others (an individual whose illness experience and/or story had explicit influence on the participant’s treatment decision) to make a treatment decision.^191^ Of these 20 men, this influential other caused one man to consider WW more strongly and one to more likely reject WW. One open-ended interview of 102 men with localized disease reported that one of the reasons for not electing WW was that their families were against that option (4 percent). Other reasons cited were fear of consequences for not selecting WW (64 percent) and perceived elevated risk because of increased PSA or Gleason score (12 percent).^187^

Adherence to AS. No study or survey specifically addressed how family involvement might affect adherence to AS.

#### Personal Preferences

Offer of AS. No study or survey specifically addressed how personal preferences might affect the offer of AS.

Acceptance of AS. One analysis of the ProtecT trial compared 180 men who refused randomization, but instead selected AS (i.e., men who did not participate in the trial) with 138 men in the trial who were randomized to AS.^173^ The analysis found that men with increased baseline anxiety (per unit increase on the Hospital Anxiety and Depression scale; adjusted OR 0.93; 95 percent CI 0.87, 0.99; P = 0.04) and lower SES (per decrease in SES from I [high] to V [low]; adjusted OR 0.68; 95 percent CI 0.49, 0.96; P = 0.03) had decreased probability of selecting AS and refusing randomization (i.e., these men did not proactively seek AS but preferred randomization for AS vs. active treatment).

Four survey/interview type studies (sample size 25,^183^ 50,^189^ 185,^122^ and 768^195^) reported that concern for treatment side effects (impotence [44 percent] and incontinence [48 percent];^122^ side effects (11 percent, type not specified);^195^ no quantitative data were available in two studies^183,189^) was one reason that patients elected AS/WW.

Some other reasons cited in an interview of 21 men with localized disease two of whom chose WW were to maintain current quality of life and no need for active therapy because cancer was small and slow-growing.^196^ The authors further observed that “for most men [including both who chose WW and those who did not], both black and white, treatment decision making occurred within an emotional context of fear and uncertainty and without systematic use of information.”

One multivariable analysis reported that the desire to avoid side effects or having current bowel problems were predictive of the choice of WW versus other treatments or undecided.^178^ One multivariable analysis reported that having urinary dysfunction was predictive of choosing WW over RP, while having sexual dysfunction was predictive of choosing RT over WW.^177^ Another multivariable analysis reported that having other urinary conditions (besides the primary urinary dysfunction) was also predictive of choosing WW over RP.^165^

Adherence to AS. One multivariable analysis reported that increased anxiety in men was associated with an increased probability of interruption of AS.^164^

#### Risk Perceptions

Offer of AS. No study or survey specifically addressed how risk perceptions might affect the offer of AS.

Acceptance of AS. One qualitative description of interviews conducted in 25 men with low-risk prostate cancer reported that physician description of prostate cancer affects patient perception of the seriousness of the condition as well as treatment choice.^183^ One survey of 654 men with early stage prostate cancer reported that men who chose RP over RT or WW perceived prostate cancer as a significantly more serious disease.^185^ Another survey of 102 men with localized prostate cancer reported that fear of consequences was the most common reason for not selecting WW.^187^

Adherence to AS. No study or survey specifically addressed how risk perceptions might affect the adherence to AS.

#### Family History

Offer of AS. No study or survey specifically addressed how family history might affect the offer of AS.

Acceptance of AS. No study or survey specifically addressed how family history might affect the acceptance of AS.

Adherence to AS. Two multivariable analyses reported that family history was not a significant factor in predicting interruption of AS/WW.^175,176^

#### Social Support

Offer of AS. No study or survey specifically addressed how social support might affect the offer of AS.

Acceptance of AS. Four multivariable analyses reported that not being married or in a permanent relationship was associated with an increased probability of receiving WW versus active treatments.^77,160,166,180^ One analysis found that marital status was not a factor in predicting receiving WW.^177^

A report of interviews with 18 couples in which the men were recently diagnosed with early stage prostate cancer and had not yet decided on a treatment demonstrated the complexity of reaching a treatment decision.^194^ The authors concluded that couples ruled out options based on both formal (provided by the physicians) and informal (provided by family and friends) information, and that they also “considered both their own individual histories and concerns and their shared life experiences.” Of the 18 couples referred by urologists, only one couple elected watchful waiting. The authors further stated that “’Doing nothing’ was ultimately rejected for the certainty [the couples] perceived to be associated with it: certain death, feared to be slow and painful.”

Acceptance of AS. One multivariable analysis reported that marital status was not associated with time to interruption of AS.^164^

### Other Factors That Could Affect the Offer of, Acceptance of, or Adherence to AS

Income or socioeconomic status. Three multivariable analyses examined income level with respect to AS/WW.^66,177,199^ One reported that less than $30,000 annual income (versus at least $40,000) in men with prostate cancer was associated with an increased probability of receiving AS/WW versus other treatments.^199^ The remaining two reported that income was not a significant factor in predicting the choice of AS/WW versus other treatments.^66,177^

One multivariable analysis reported that men in higher socioeconomic strata (versus lower strata) had a decreased probability of receiving AS/WW versus active treatments.^77,159^

Education. Five multivariable analyses examined education level with respect to AS/WW.^66,161,166,167,177^ Three reported that education was not a significant factor in predicting men receiving AS/WW.^66,161,177^ One reported that men who resided in census tracts with fewer residents who had a high school education (versus more) had an increased probability of receiving AS/WW versus other treatments.^166^ One reported that college graduates (versus non-college graduates) had an increased probability of interrupting AS/WW to seek active treatments.^167^

Race. Ten multivariable analyses examined race/ethnicity with respect to AS/WW.^77,159,164,166,168–170,176,177,180^ Six found that race/ethnicity was not a significant factor in selecting AS/WW or in the decision to interrupt AS/WW and seek definitive treatments.^77,164,168–170,176^ Four analyses reported that blacks were more likely than whites to receive AS/WW versus active treatments.^159,166,177,180^

One survey of 231 men with prostate cancer in North Carolina reported that there was no significant difference between blacks and whites as to whether the option of WW was discussed with their physicians (48.7 percent versus 56.1 percent).^190^

#### Delivery System

##### Economic Incentives and Disincentives

Offer of AS. No study or survey specifically addressed how economic incentives and disincentives might affect the offer of AS.

Acceptance of AS.

Insurance Type (HMO, Military, Private). Two multivariable analyses reported that having Medicare (versus private insurance,^66^ or private or Veterans Administration (VA) insurance^160^) increased the probability of receiving AS/WW (versus active treatments). One analysis reported that having Medicare plus supplement (versus private) also increased the probability of AS/WW (versus RP).^179^ One analysis reported that having preferred provider organization (PPO) or health maintenance organization (HMO) coverage decreased, and that having VA insurance increased, the probability of receiving AS/WW versus RP.^163^ It also reported that Medicare supplemented with fee-for-service, HMO, or PPO coverage decreased the probability of receiving AS/WW versus RP.

Adherence to AS. One multivariable analysis reported that insurance status was not a significant factor in predicting interruption of AS/WW.^164^

##### Availability of Technology

No study or survey specifically addressed how the availability of technology might affect the offer or acceptance of, or adherence to, AS.

##### Geographic Location

Offer of AS

Small area variation. No study or survey specifically addressed how small area variation might affect the offer of AS.

Regional variation. No study or survey specifically addressed how regional variation might affect the offer of AS.

Urban vs. rural. One survey of 231 men with prostate cancer reported that there was no significant difference between urban and rural residents in North Carolina as to whether the option of WW was discussed with their physicians (51.9% vs. 53.7%).^190^ Acceptance of AS

Small area variation. No study or survey that specifically addressed how small area variation might affect the acceptance of AS. One study, however, did report that there was a wide variation in the selection of AS/WW across 36 practice sites in the United States (ranging from 0 to 28 percent) and that this variation was not explained by known patient factors.^69^ The variation remained after restricting the analysis to men with low-risk disease. In a multivariable analysis, the proportion of variation for AS/WW among men with low-risk disease attributable to practice site was 21 percent (95 percent CI 0.11, 0.37).

Regional variation. One multivariable analysis claimed that men who resided in New Jersey versus those in California (excluding San Francisco-Oakland, San Jose, and Los Angeles) had an increased probability of receiving AS/WW versus any other treatments.^77^ No significant differences were found between men in California (excluding San Francisco-Oakland, San Jose, and Los Angeles) and men in other registries (San Francisco-Oakland, San Jose, Los Angeles, Seattle, Detroit, Atlanta, Iowa, New Mexico, Utah, Louisiana, Connecticut, and Alaska natives). However, another multivariable analysis reported that men in Northeast had a decreased probability of selecting AS/WW (versus active treatments) compared with men in greater California (excluding San Francisco, San Jose-Monterey, and Los Angeles).^180^

Urban vs. rural. One multivariable analysis reported that men who resided in urban areas (versus rural areas) had a decreased probability of receiving AS/WW versus RP or RT.^159^ One survey of 231 men with prostate cancer in North Carolina reported that there was a difference in whether physician recommendation was the most influential factor in the treatment decision between urban and rural residents (62.3 percent versus 43.9 percent, respectively; P=0.004). ^190^ Adherence to AS

Small area variation. No study or survey specifically addressed how small area variation might affect adherence to AS.

Regional variation. No study or survey specifically addressed how regional variation might affect the offer of AS.

Urban vs. rural. No study or survey specifically addressed how urban versus rural residence might affect adherence to AS.

##### Academic Centers Versus Private Practice

Offer of AS. No study or survey specifically addressed whether the treatment facility’s status as an academic centers versus a private practice might affect the offer of AS.

Acceptance of AS. One multivariable analysis reported that treatment facility status (academic versus community practice) was not a significant factor in predicting receiving AS/WW versus active treatment.^66^

Adherence to AS. No study or survey specifically addressed whether the treatment facility’s status as an academic center versus a private practice might affect adherence to AS.

#### Communication Strategies

##### Risk Assessment, Predictive Models

No study or survey that specifically addressed the role of risk assessment and predictive models in affecting the offer of, acceptance of, or adherence to AS. One study (a 2008 review^201^) did, however, catalogue 109 prostate cancer predictive tools, which included endpoints like disease recurrence, metastasis, and survival, though no studies were identified that systematically assessed how these predictive tools were used in patient discussions.

##### Decision-making Tools and Aids

No study or survey specifically addressed how the use of decision-making tools or aids might affect the offer or acceptance of, or adherence to, AS.

One 2009 systematic review did, however, report on the use of various decision aids (DAs) to help men with low-risk prostate cancer participate actively in the decisionmaking process concerning their treatments.^197^ Thirteen of 219 articles (representing 3 RCTs and 10 nonrandomized trials) were judged eligible for inclusion. Eligibility criteria consisted of a study population that included men with low-risk prostate cancer who had the option of RP, RT, or WW. Using the Jadad scoring system,^202^ the reviewers rated two RCTs as good^203,204^ and one poor.^205^

The majority of the DAs examined were developed de novo. They included, either alone or in combination, a written information package, consultation with a nurse or urologist, generic video, interactive computer program/CD-ROM decision aid, and a personalized multidisciplinary consultation. Most of the DAs were designed to be completed outside the clinic and after diagnosis, but prior to making a decision.

The participants in general found the DAs to be informative. One RCT reported a decrease in anxiety in participants in the intervention arm (written information package with discussion, a list of questions they could ask their physician, and an audiotape of the medical consultation) versus written information alone.^205^ One RCT found that there was no difference in satisfaction with treatment choice between those who received individualized DAs and those using a generic DA.^204^ One RCT found that the men in the DA arm selected their physician’s treatment choice less often than those who received usual care.^203^ The nonrandomized studies reported that DAs appeared to increase patients’ knowledge concerning prostate cancer and its treatments. They were also found to help encourage more active patient involvement in the decisionmaking process.

The authors noted several limitations in conducting their review, namely, too few high quality trials, heterogeneous outcome measures, and that the quality of the information provided in the DAs themselves were not assessed, which precluded determination as to whether these DAs met the quality standards set by the International Patient Decision Aids Standards Collaboration.^206^

### Summary

Only two studies specifically examined men who were enrolled in an active monitoring protocol with triggers for curative treatments (as opposed to other non-AS observational management strategies).^172,173^ The van As study found that the free-to-total PSA ratio and T-stage were independent predictors of time to radical treatments in patients on the protocol, while initial PSA, PSA density, Gleason score, number of positive cores, and prostate volume were not.^172^ The Mills study found that decreased baseline anxiety and higher socioeconomic status were both associated with a decreased probability of willingness to consent to AS randomization (i.e., these men did not take a chance and proactively selected AS).^173^

Within the remainder of the heterogeneous studies, some tentative conclusions could be drawn concerning observational management strategies in men with prostate cancer:

- For many men, physician recommendation is an important element in helping reach a treatment decision.
- The context in which the consultation with a urologist is made (initial consultation versus second opinion visit) may be a factor in determining whether observational management strategy is offered as a treatment option or not.
- The following patient and clinical variables are potentially important in increasing the probability that a patient receives observational management strategies: increased age, presence of comorbidities, lower Gleason score, lower tumor stage, lower diagnostic PSA, membership in a lower risk group, and decreased baseline anxiety.
- The following patient and clinical variables are potentially important in increasing the probability that a patient interrupts observational management strategies to seek definitive treatments: decreased age, higher tumor stage, higher diagnostic PSA, higher PSA velocity, membership in a higher risk group, and increased anxiety.
- Physicians may have predetermined clinical notions as to when to recommend observational management strategies.
- For some men, opinions from family members and other influential people are important in reaching a treatment decision.
- Avoidance of treatment side effects is an important determinant in predicting the choice of observational management strategies.
- Prostate disease risk perceptions matter, as those who perceived prostate cancer as a more serious disease tended to choose RP over RT or observational management strategies.
- Men who are unattached (i.e., not in a permanent relationship) may have a higher probability of receiving observational management strategies versus active treatments.
- Men from lower socioeconomic strata or who are black (versus white) are more likely to receive observational management strategies.
- The type of insurance (e.g., Medicare vs. private insurance) may be a determinant in the choice of observational management strategies versus other treatments.
- Residing in an urban area (versus a rural area) may affect the probability of men receiving observational management strategies versus active treatment.
- The use of decision aids may be informative and could encourage more active patient involvement in the treatment decisionmaking process.

## Key Question 4 What are the comparative short- and long-term outcomes of active surveillance versus immediate treatment with curative intent for localized prostate cancer?

In conformity with the Key Question, we systematically reviewed only comparative studies that directly compared AS (or other observational management strategies) to immediate treatment with curative intent. In order to understand the effectiveness of AS relative to active treatment options, studies of AS need a control group for comparison. As such, we did not include single-arm AS cohort studies, which cannot address comparative effectiveness questions. Thus, this review does not address evaluations of long-term clinical outcomes reported in noncomparative cohort studies, which are beyond the scope of the Key Question.

### Clinical Outcomes

We did not identify any studies reporting clinical outcomes specifically of AS management strategies compared with immediate definitive treatment. No study evaluated AS where the intervention was employed in a predefined group of patients using predefined monitoring methods to identify patients who would potentially be eligible for treatment with curative intent.

Faced with a lack of studies comparing AS to immediate treatment, we elected to evaluate studies that compared other observational management strategies (largely resembling WW) with immediate treatment. One can argue that efficacy results from studies of WW may represent the low bound of the potential efficacy of AS.

In addition to previously published systematic reviews and evidence reports, our searches identified updated results from a multicenter RCT (2 publications, one on clinical outcomes and one on costs), and 12 cohort studies (2 prospective and 10 retrospective). Notably, the majority of evidence for this key question came from retrospective analyses of observational studies. Due to the differences in patient characteristics and risk profile between patients treated with observational strategies and those who received active treatments, confounding by indication is likely in these studies. Temporal changes in patient characteristics at diagnosis may affect the magnitude of the reported treatment effect sizes in observational studies. Of the studies we reviewed only two performed statistical analyses that accounted for year of diagnosis.^207,208^ Another study included only patients diagnosed in a single year.^159^ One study used pathology information based on a contemporary reading of available pathology material in its statistical adjustments.^209^

#### Findings from Previous Systematic Reviews

We examined two recent systematic reviews of treatments of men with clinically localized prostate cancer.^8,9^ Of note, these systematic reviews included some studies of men receiving ADT in their observational management groups, such primary studies would not have met the primary study inclusion criteria for this report.

One AHRQ evidence report^9^ included two RCTs comparing WW with RP: the Scandinavian Prostate Cancer Group Study 4 (SPCG-4),^210^ and the Veterans Administration Cooperative Urological Research Group (VACURG) trial.^211^ A recent (2010) Cochrane Report on the same topic^212^ did not identify any additional studies; however, we identified the latest update of the SPCG-4 trial results^213,214^ (discussed in the primary study section below). In SPCG-4, 695 patients were enrolled between 1989 and 1999, and randomized to either watchful waiting (WW) or radical prostatectomy (RP); they were followed for a median of 8.2 years. When compared with patients on WW, patients who had RP had significantly lower mortality (RR 0.74; 95 percent CI 0.56, 0.99; P = 0.04), disease-specific mortality (RR 0.56; 95 percent CI 0.36, 0.88; P = 0.01), and distant metastases (RR 0.60; 95 percent CI 0.42, 0.86; P = 0.04).^210^ The VACURG trial followed 142 patients for a median of 23 years, and found no difference in mortality between WW and RP groups.^211^

Additionally, the AHRQ evidence report on localized prostate cancer treatment^9^ considered the results of two randomized trials reporting on QoL and self-reported functional status.^215,216^ One included study was an ancillary investigation from the SPCG-4.^215^ The study found that self-reported erectile dysfunction and urinary leakage were more common in the RP group, whereas urinary obstruction was more common in the WW group. Bowel function, prevalence of anxiety, prevalence of depression, well-being, and the subjective QoL were similar in the two groups.^215^ The second study was based on a randomized trial comparing RT with deferred treatment^216^ and demonstrated that patients in the RT group experienced a decrease in QoL due to the development of hematuria, incontinence, mucus, and having to plan daily activities in response to intestinal problems.^216^

Another AHRQ report^8^ that compared RT and no treatment evaluated one prospective cohort study^217^ and eight^209,218–224^ retrospective cohort studies. The included prospective cohort study reported no difference in sexual function between brachytherapy (BT) and no treatment, but significantly worse sexual function between external beam radiation therapy (EBRT) and no treatment.^217^ Of the four retrospective cohort studies that compared disease-specific survival between radiation therapy and no treatment, one found significantly better disease-specific survival in men treated with BT.^219^ Three studies reported gastrointestinal or genitourinary toxicity outcomes and found no difference between BT or EBRT and no treatment, but one study found a higher rate of receiving treatment for urethral stricture in patients treated with combined EBRT and BT, compared with those with no treatment.^218^ One study reported significantly higher rates of second primary cancer in patients treated with EBRT compared with those with no treatment.^220^

#### Findings from Primary Studies

To address Key Question 4, we searched for studies that compared observational management strategies with immediate definitive treatment. As discussed above, our searches did not identify any studies comparing patients managed with AS versus immediate active treatment with curative intent. Here we summarize findings from reviewed studies where the observational management strategy mostly resembled WW. We included only multicenter studies that enrolled men with localized prostate cancer, and reported age-adjusted effect sizes. Characteristics of the 12 eligible studies reporting on clinical outcomes are shown in Appendix Table C4.1. Two RCTs (in 3 publications^213,214,225^) three prospective cohort studies,^226–228^ and ten retrospective cohort studies^207–209,218,223,224,229–232^ were included. The two RCTs reported updated results from the SPCG-4 and UMEA1 trials that had been included in the previously mentioned systematic review.^9^ Among the 13 cohort studies, sample size ranged from 113^226^ to 44,630^208^ and followup duration from 12 months^226^ to more than 13 years.^209^ Methodological quality of the studies was rated as A in one study,^213^ B in nine studies,^207–209,214,218,223,224,229,230^ and C in five studies.^226–228,231,232^

##### Comparison Between Observational Management Strategies and Radical Prostatectomy^ddd^ ddd During the conduct of our review, preliminary results from the Prostate cancer Intervention Versus Observation Trial (PIVOT, NCT00007644), a randomized trial of RP versus WW with palliative intervention, were presented at the 2011 annual meeting of the American Urological Association (AUA). We did not include this study in our evidence tables because no full text publication was available.

Appendix Table 4.2 presents the detailed results from the one RCT and its ancillary investigation, as well as 14 cohort studies that compared observational management strategies with RP.

Randomized controlled trials. The SPCG-4 RCT followed 695 men with localized prostate cancer for a median of 12.8 years.^213^ Compared with men on WW, men treated with RP had significantly lower prostate cancer-specific mortality (RR 0.62; 95 percent CI 0.44, 0.87; P = 0.01), all-cause mortality (RR 0.75; 95 percent CI 0.61, 0.92; P = 0.007), and incidence of distant metastases (RR 0.59; 95 percent CI 0.45, 0.79; P <0.001).

Subgroup analyses found no significant modification of the treatment effect on mortality by PSA (< 10 vs. ≥ 10ng/mL, interaction P = 0.72 and P = 0.30, for overall and prostate cancer-specific mortality, respectively) or Gleason score (<7 vs. ≥7, interaction P = 0.36 and P = 0.52, for overall and prostate cancer-specific mortality, respectively). However, age was found to be a modifier of the treatment effect (interaction P = 0.003 when age was dichotomized at 65 years of age; P = 0.001 when treating age as a continuous variable). The favorable effects of RP on overall mortality were present among men younger than 65 years (HR = 0.52; 95 percent CI 0.37, 0.73; P < 0.001), but not men older than 65 years (HR = 0.98; 95 percent CI 0.75, 1.28; P = 0.89). Effect modification by age did not reach statistical significance for prostate cancer-specific mortality (interaction P = 0.16; HR = 0.49; 95 percent CI 0.31, 0.79; and HR = 0.76; 95 percent CI, 0.25, 2.32; comparing men younger vs. older than 65 years, respectively). The authors reported that none of the subgroup analyses performed were specified in the main study protocol but were determined “before any data were seen.”^213^ Thus, the study may not have had adequate power to detect effect modification; the absence of statistically significant interactions does not indicate that clinically meaningful differences do not exist between the investigated subgroups.

An additional subgroup analysis limited to low-risk prostate cancer patients (124 in the RP group and 139 in the WW group) was also reported. Low-risk cancers were defined as PSA < 10 ng/mL and Gleason score < 7 or WHO grade of 1 (for tumors diagnosed only by cytologic assessment). In this subgroup, the HRs comparing RP versus WW were 0.62 (95 percent CI 0.42, 0.92; P=0.02), 0.53 (95 percent CI 0.24, 1.14; P=0.14) and 0.43 (95 percent CI 0.23, 0.79; P=0.008), for overall survival, prostate-cancer specific mortality and development of metastatic disease, respectively. The study reported that the most common non-fatal complications in the RP group within 1year of surgery were impotence and urinary leakage, with cumulative one-year incidence proportions of 58.1 percent and 32.2 percent, respectively. Urinary obstruction, pulmonary embolism and deep-vein thrombosis were uncommon (cumulative one-year incidence proportions 2.1 percent, 1.4 percent and 1 percent, respectively). Data on adverse events in the WW group for the first year were not provided.

An ancillary investigation^214^ from the Swedish component of the SPCG-4 RCT (including a total of 326 patients) evaluated the quality of life outcomes at different followup timepoints (2 to 3 years, 4 to 5 years, and 6 to 8 years postrandomization). The study found that anxiety (moderate or high) and depressed mood (moderate or high) were less common in the RP group compared to the WW group, and that sense of well being and quality of life were not significantly different between groups at 2–3 years post randomization. Depressed mood was more common in the RP group compared to the WW group at 4–5 years post randomization; significant differences were not observed for other quality of life outcomes. No significant differences were observed at and 6–8 years post randomization. This ancillary investigation also reported that about 80 percent and 42 percent of patients in the RP group reported erectile dysfunction and urinary leakage, compared to 37 percent and 11 percent in the WW group respectively 2 to 3 years post randomization. At 6–8 years post randomization the corresponding frequencies were 83 percent and 56 percent in the RP group and 55 percent and 25 percent in the WW group.

Observational studies—Cancer-specific mortality. Three cohort studies^207,209,223^ compared prostate cancer-specific mortality between patients on observational strategies and patients treated with RP based on large databases (SEER-Medicare,^207^ the National Cancer Register of Sweden Follow-up Study, NCRSFS,^223^ and the Connecticut Tumor Registry^209^). All three studies identified a statistically significant difference between treatments favoring RP (HR 0.63; 95 percent CI 0.55, 0.71 [using a propensity score^207^], HR 0.49; 95 percent CI 0.34, 0.71,^223^ and HR 0.29; 95 percent CI 0.17, 0.52,^209^ respectively). However, an instrumental variable analysis of the SEER-Medicare study did not identify any significant difference between treatments with wide confidence intervals around the estimated treatment effect (HR 1.37; 95 percent CI 0.15, 12.5).^207^

Observational studies—All-cause mortality. Five studies compared all-cause mortality between observational management strategies and RP.^207,208,223,230,232^ One was based on the CDC-NPCR Patterns of Care Study (POCS),^230^ two used the SEER-Medicare database,^207,208^ one used NCRSFS data,^223^ and one used the Center for Prostate Disease Research database to identify men of 70 years of age or older who were diagnosed with localized prostate cancer.^232^ From CDC-NPCR POCS, the 5-year all-cause mortality rate was significantly higher in patients on WW than in patients treated with RP (adjusted HR 2.3; 95 percent CI 1.70, 3.12).^230^ Similarly, the two reports that analyzed data from the SEER-Medicare database,^207,208^ one report analyzed data from the Center for Prostate Disease Research database,^232^ and the NCRSFS study^223^ showed favorable outcome in the RP group (HR 0.65; 95 percent CI 0.62, 0.68[using a propensity score^207^]; adjusted HR 0.49; 95 percent CI 0.41, 0.57^207^; adjusted HR 0.50; 95 percent CI 0.47, 0.53;^208^ and adjusted HR 0.52; 95 percent CI 0.32, 0.84,^232^ respectively; the latter estimate was derived from an analysis comparing WW to RP (reference group), where patients initially managed with WW were stratified by whether they later received secondary therapy. This analysis may be susceptible to bias because the decision to administer secondary treatment is often made based on information not available at baseline (e.g., tumor progression status during followup); and this information is likely to be associated with the clinical outcome of interest. This study was exclusively limited to patients who were aged 70 years or older.^232^ An instrumental variable analysis performed in one of these studies however, did not find a significant difference between treatments (HR 0.92; 95 percent CI 0.39, 2.17); however confidence intervals were wide indicating substantial uncertainty around the HR estimate.^207^

Observational studies—Morbidity of primary treatment. One report analyzed the data from the CaPSURE database and found that men treated with RP had a higher rate of receiving treatments for urethral stricture than men on WW over a median followup of 2.7 years (adjusted HR 10.4; 95 percent CI 3.28, 33.3).^218^ One study analyzed the risk of additional surgical procedures following primary treatment with WW, RP, RT or ADT.^231^ The reported multivariable-adjusted estimates compared WW only with RP and demonstrated that bladder irrigation/cystostomy procedures and TURP/bladder neck incision were more common in the WW group compared to the RP group (HR 1.71; 95 percent CI 1.33–2.20 and HR 2.63; 95 percent CI 2.08–3.33, respectively). In contrast urethra dilation procedures were less common in the WW group (HR 0.71; 95 percent CI, 0.61–0.84) and cystoscopy procedures were not significantly different (HR 1.00; 95 percent CI, 0.88–1.13), compared to the RP group.

Observational studies—Quality of life. Four studies reported QoL outcomes.^226–229^ Two studies analyzed data from the CaPSURE registry. One of them reported that patients on observational management strategies (WW or AS, reported in aggregate) had significantly lower mean SF-36 scores in the social function domain compared to patients treated with RP (89 vs. 100; P < 0.05, respectively), but no difference was found in three other domains of SF-36.^229^ The other study using CaPSURE data^227^ presented trends in QoL scores from immediately after treatment through 2 years of followup, and reported that scores for most general and disease-specific QoL domains improved statistically significantly at one and two years post treatment compared with scores immediately after treatment among patients who received RP. Patients on observational management strategies (WW or AS, reported in aggregate) did not experience statistically significant changes in their scores over time with the exception of a statistically significant improvement in “health change” at one year of followup (compared to immediately post treatment assignment), however the sample size of the group was small (n=87). Patients receiving radiotherapy experienced improvements in “health change,” bowel function, and urinary bother scores between the immediate post-treatment period and one year of followup (however, “health change” significantly worsened between year 1 and year 2 in this group).

The third study originated from four academic centers in Wisconsin and suggested that disease-specific QoL declined more among patients receiving RP compared to WW (for the domains of urinary and sexual function) but did not identify a difference between treatment groups for urinary bother, sexual bother, bowel function, bowel bother, or general QoL.^226^

The fourth study included a subgroup of patients with available longitudinal data from the Health Professionals Followup Study followed for up to 3 years to assess the changes in general QoL and UCLA Prostate Cancer Index. The study reported that WW was not associated with statistically significant changes on any of the SF-36 scales compared to RP (data were extracted only for the longitudinal component of this study).^228^

[underlined: Studies of QoL often report multiple outcomes and perform multiple comparisons. None of the studies we reviewed reported the use of statistical procedures that account for multiple testing. However, we note that such procedures are not universally recommended.] ^233,234^

##### Comparison Between Observational Management Strategies and Radiation Therapy

Detailed results from the eight studies that compared observational management strategies and radiation therapy (RT) are shown in Appendix Table C4.3. No study reported on the effects of treatment on the development of metastatic disease.

Randomized controlled trial. One study^225^ reported quality of life comparisons based on a subset of 54 surviving responders from the UMEA1 trial. UMEA1 was a randomized trial of 166 patients comparing RT with WW. The authors stated that the complete trial data are “not yet ready for publication.” At 10 years of followup, the study reported no statistically significant differences in health-related quality of life function or symptom scales. No significant difference was observed between RT (mean=2.3) and WW (mean = 2.3; P not reported) for “limitations in daily life” caused by prostate cancer. No significant difference was observed for “life situation” between RT (mean=3.7) and WW (mean=3.3; P=0.398). Out of 20 comparisons in symptom/function scores (abstracted in Appendix Table C4.3) only that of “sexual bother” was statistically significant (mean scores: 3.8 vs. 7.4 in the WW and RT groups, respectively; higher values indicate worse function; P=0.011). A weak urinary stream was the most reported symptom and the mean score differed significantly between WW (mean 4.8) and RT (mean 3.0; higher values indicate worse function; P = 0.034). No differences were observed at 10 years between RT and WW regarding the questions “How would you feel if you lived the rest of your life with your urinary/bowel/sexual problems as they are now?” (P values comparing the two groups were 0.643, 0.653 and 0.819, respectively).

Observational studies—Cancer-specific mortality. One study using data from NCRSFS reported that RT was associated with a non-significant improvement in prostate cancer-specific mortality compared to surveillance (WW or AS in aggregate; HR 0.70; 95 percent CI 0.45, 1.09) at 8.2 years of followup.

Observational studies—All-cause mortality. Two studies reported adjusted estimates comparing all-cause mortality between observational management strategies and RT.^208,223^ One study was based on the SEER-Medicare database,^208^ and the other used NCRSFS data.^223^ Both studies reported significantly lower mortality rates in patients treated with RT compared with patients managed with an observational strategy (HR 0.81; 95 percent CI 0.78–0.85,^208^ and HR 0.68; 95 percent CI 0.57, 0.82,^223^ respectively).

Observational studies—Morbidity of primary treatment. One report analyzed the incidence of treatment for urethral stricture captured in the CaPSURE registry and did not find a significant difference between patients on WW and patients treated with EBRT, or between patients on WW and patients treated with BT over a median followup of 2.7 years.^218^

Observational studies—Quality of life. Three studies reported quality of life outcomes.^224,226,229^ From the CaPSURE registry, patients on WW had significantly lower mean SF-36 score in the social function domain than patients treated with RT (89 vs. 86; P < 0.05, respectively), but no difference was found in three other domains of SF-36.^229^ In a study of 4 academic medical centers from Wisconsin no significant difference in disease-specific and general QoL was observed between patients managed with RT and those managed with expectant management.^226^ Finally, a study based on the Eindhoven Cancer Registry found that RT had a negative effect on the physical functioning and bodily pain dimensions of the SF-36 instrument, the spiritual and total wellbeing scores of the Quality of Life-Cancer Survivors (QoL-CS) instrument, and the bowel function and bowel bother dimensions of Expanded Prostate Cancer Index Composite (EPIC), compared to observational management. No other significant difference between treatments was observed for general QoL, cancer-specific QoL, or disease-specific-QoL.

##### Comparison Between Observational Management Strategies and Combination Therapy or Active Treatments Considered in Aggregate

Detailed results from the two studies that compared AS/WW and other active treatment groups (a combined group of patients managed with RP or RT and a group receiving both RT and EBRT) are shown in Appendix Table C4.4. No study reported incidence of metastatic disease or quality of life outcomes.

One study analyzed data from the SEER-Medicare database up to year 2002, and compared patients on observation with patients who received any active treatment, including RP, EBRT, and BT.^208^ Compared with patients on observation, patients on active treatment had significantly lower risk of prostate cancer-specific mortality (adjusted HR 0.67; 95 percent CI 0.58, 0.77) and all-cause mortality (adjusted HR 0.69; 95 percent CI 0.66, 0.72).^208^

One study analyzed the data from the CaPSURE registry and found that a group of men treated with EBRT and BT (combined treatment) had a higher rate of receiving treatments for urethral stricture than men on WW over a median followup of 2.7 years (adjusted HR 4.56; 95 percent CI 1.23, 16.88).^218^ No significant difference was found between patients on WW and patients treated with combined RP and EBRT.^218^

### Costs

#### Findings from Studies of Actual Patient Costs

We identified four primary studies (three using U.S. data^159,235,236^ and one from Sweden^237^) reporting on comparisons of costs of active treatments and observational management strategies for localized prostate cancer. All studies included groups of patients treated with WW and used various active treatments as comparators; no comparative study reporting on costs included a group managed with AS. Details from each study including the populations, treatments compared, and cost estimates are presented in Appendix Table C4.5.

One study used the SEER-Medicare database (13,769 patients matched 1:1 with noncancer controls; 2805 of the patients had been managed with WW) to estimate incremental treatment costs during the first 5 years of treatment. Using inverse probability of treatment weights derived from a propensity score to account for factors that affect treatment selection, this study found that, WW has lower incremental costs ($8535) compared with RP ($19,481) or RT ($16,653) over 5 years.^159^

A second study used data from the CaPSURE database (235 patients; 37 managed with WW) to estimate mean first year costs.^235^ The unadjusted mean cost of WW ($484) was lower compared with RP (without hormonal therapy, $7320) or RT (without hormonal therapy, $7430). After adjusting for patient and disease characteristics, the difference in costs among treatments was statistically significant (analysis of covariance P < 0.001).

A third study, again using CaPSURE data, estimated that WW had a total cumulative cost over 5.5 years of follow up of $31,871 and $31,789, for low and intermediate risk prostate cancer patients, respectively. The corresponding values were $28,366 and $41,419 for BT; $48,840 and $56,725 for EBRT and $32,795 and $35,037 for RP.^236^ Notably, each treatment had a distinct cost pattern when total costs were separated into those related to medications, office visits and hospitalizations (please see Appendix Table 4.5 for details).

The fourth study was an ancillary investigation from the SPCG-4 trial, a randomized study of RP versus WW for men with localized prostate cancer.^237^ The study reported cost estimates (based on Swedish prices and converted to euros, €) for a subset of patients (n=212; 105 managed with WW and 107 with RP) participating in the trial. After a median followup of 11.8 years for the WW group and 12.2 years for the RP group, the total mean cost of WW was €18,124 for WW compared with €24,147 for RP. After adjustment for age, Gleason score and PSA, the difference between treatments remained and was statistically significant (P = 0.003). The applicability of Swedish cost estimates to the United States setting is likely to be limited.

#### Findings From Model-Based Economic Evaluations

In addition to the primary cost studies discussed above, we also considered model-based cost estimates, including the cost-minimization or cost-consequence analyses and cost components of cost-effectiveness or cost-utility analyses of AS (but not WW). We did not review the cost-effectiveness or cost-utility analyses reported in these documents and focused only on cost information.

Two economic evaluations conducted by the Institute for Clinical and Economic Reviews (ICER)^238,239^ reported cost-utility analyses comparing AS with active treatment options (IMRT, BT, and open retropubic nerve-sparing RP). eee An associated publication based on these reports was also reviewed.^240^ Cost estimates were obtained from multiple sources including outpatient costs from the 2008 Red Book, Hospital Outpatient Prospective Payment System, Physician Fee Schedule, Centers for Medicare & Medicaid Services Lab Fees and Durable Medical Equipment Schedules; and inpatient payments from the Hospital Inpatient Prospective Payment System, the 2008 Anesthesia Conversion Factor and American Society of Anesthesiologists payment information. The information obtained was incorporated into a disease history Markov model to determine the cost (and effectiveness) of each treatment strategy. The AS protocol included regular physical examinations, PSA testing, and rebiopsies (one year following diagnosis and every 3 years thereafter). In the model, 61.1 percent of all patients originally assigned to AS received treatment, using a lifetime horizon; 28.3 percent of all patients received treatment within the first 5 years. In the base case analysis (cohort of 65 year old men diagnosed with low-risk clinically localized prostate cancer, lifetime model horizon, 3 percent annual discount rate) comparing AS (followed by IMRT with short term ADT in cases of progression, or IMRT alone in cases of patient preference for active treatment) and RP, the total cost of an open RP management strategy was estimated at $28,348 and the total cost of an AS strategy was estimated at $30,422. In a similar model (cohort of 65 year old men diagnosed with low-risk clinically localized prostate cancer, additional life expectancy of 16 years, lifetime model horizon, 3 percent annual discount rate) the total costs were $30,422 for AS, $23,348 for RP, $25,484 for BT, $37,861 for intensity-modulated RT and $53,828 for proton beam RT. Sensitivity analyses produces largely consistent results.

eee ICER reports are available online at http://www.icer-review.org; last accessed September 30, 2011.

One study^241^ reported a cost comparison of AS and RP. Costs were obtained from 2008 Medicare reimbursement rates. The costs for RP were based on Medicare reimbursements in 2008 for patients treated by a single, high-volume surgeon (volume was not reported). Several AS protocols were modeled: they differed by biopsy frequency (within a year of diagnosis and every 12 or 18 months thereafter), duration of active followup during which biopsies were performed (5 or 10 years after diagnosis) and the rate of “conversion” to active treatment (5 percent or 7 percent annually, obtained from literature sources). The model had a 15 year horizon and used a 5 percent discount rate. The cost per patient in the AS models ranged from $6558 to $11,992. Costs were higher with longer periods of active followup, more frequent biopsies and higher rates of conversion to active treatment. Costs for the AS strategies were 43 percent to 78.7 percent of the per-patient cost of RP. In the RP group 92 percent of all costs occurred in the first year; in contrast, most costs in AS strategies occurred in later years. Sensitivity analyses demonstrated that increasing the cost of RP by $5000 affected the cost comparison results: it led to a 14.2 percent to 20.2 percent increase in the cost of AS versus a 32.8 percent increase in the cost or RP.

Another study^242^ reported a cost comparison of AS versus open retropubic RP, robotic-assisted RP, EBRT, and BT. Professional fees were obtained from 2010 Medicare reimbursement values for the study region (Miami, Florida). For inpatient costs the model used the mean inpatient costs of patients with clinically localized prostate cancer at the authors’ institution (Miller School of Medicine, Miami, Florida). The AS protocol included transrectal ultrasound guided biopsies (within a year of diagnosis and annually thereafter), follow-up visits for PSA testing and digital rectal examination of the prostate (every 3 months for the first 2 years and every 6 months thereafter). The estimates also incorporated a 25 percent probability of receiving treatment at 5 years on AS (10 percent were expected to receive EBRT and 15 percent open retropubic RP). A disease history Markov model was used to determine the cost of management of complication associated with different treatment strategies. The incidence of the various complications was obtained from Hayes et al.^240^ The model horizon was 10 years and the reported stated that the model did “not account for inflation.” At year 1, the cumulative cost was $9732 for retropubic RP, $17,824 for robotic-assisted RP, $20,730 for EBRT, $14,061 for BT, and $1154 for AS. At year 10, the cumulative cost was $15,084 for retropubic RP, $22,762 for robotic-assisted RP, $23,953 for EBRT, $17,284 for BT, and $13,116 for AS. The authors noted that AS is associated with a different cost distribution because its initial cost is lower but the cost of follow-up is relatively higher, compared to active treatments.

We caution that the cost estimates discussed in this section are model-based; as such, they are sensitive to the model structure and inputs, including model assumptions about disease natural history and treatment effectiveness.

### Summary

No study reported clinical outcomes specifically for AS management strategies versus immediate definitive treatment. Therefore, there is insufficient evidence for the comparative short- and long-term outcomes of AS versus immediate definitive treatment for localized prostate cancer.

We identified an updated analysis from a multicenter RCT (SPCG-4) and 11 multicenter cohort studies that reported clinical outcomes comparing observational management strategies with active treatments including RP and RT. We also identified a cost study based on the above mentioned SPCG-4 trial and two additional observational studies comparing the costs of treatments for localized prostate cancer. The majority of evidence for Key Question 4 came from observational studies. Confounding bias (often referred to as “confounding by indication”) is a concern for such studies, due to the differences in patient characteristics (that may be associated with the outcomes of interest) between patients treated with observational strategies and those who received active treatments. Although multivariable regression analyses or propensity score methods were employed to control for confounding by all reviewed studies, such analyses cannot account for unmeasured confounders of the treatment-outcome association.

Observational management strategies versus RP. Studies generally reported that men treated with RP had lower all-cause or prostate cancer-specific mortality rates than men on WW. The development of metastatic disease was assessed by a single study that found a significant benefit for RP compared to WW. Morbidity of primary treatment was reported by two studies that suggested an increased risk of urethral stricture (and procedures to treat it) were less likely among patients managed using observational management strategies. One of these studies also investigated cystoscopies (equally common in RP and observation groups), bladder irrigation/cystostomy and TURP/bladder neck incision (both more common among patients managed with observation). QoL was reported in three studies, which reported heterogeneous results.

Observational management strategies versus RT. Studies generally reported that men treated with RT had lower all-cause mortality rates than men on WW. One study reported prostate cancer-specific mortality information and found no statistically significant difference between RT and observational management. No study reported on treatment comparisons for the development of metastatic disease. Morbidity of treatment decision was reported by only one study which found no significant difference between observational management and BT or EBRT. QoL measures were reported in four studies, which reported heterogeneous results.

Observational management strategies versus combined radiation modalities or active treatments considered in aggregate. Data from one study showed that active treatments (RP, RT, BT considered together) resulted in lower all-cause and prostate cancer-specific mortality rates compared to WW. Morbidity of primary treatment was reported by only one study which found that a group of patients receiving EBRT and BT (combination therapy) had a higher rate of receiving treatments for urethral stricture compared to a group managed observationally.

Short- and long-term costs. Both short and long-term costs observed in clinical studies appear to be higher for active treatment strategies (RP or RT) compared to WW; however evidence originated from small studies using heterogeneous measurement methods. We did not identify any primary study comparing the cost of AS with active treatment strategies; economic modeling using U.S. prices suggested that within 10 to 15 years of diagnosis AS may be less costly compared to active treatments; a study using a lifetime horizon indicated that AS may be associated with higher costs compared to RP and BT, but lower costs compared to intensity modulated RT (IMRT) and proton beam RT.

## Key Question 5 What are the research needs regarding active surveillance (or watchful waiting) in localized prostate cancer?

As summarized and discussed in previous sections of this report, the evidence directly addressing the four principal Key Questions is largely incomplete. In part this is because published studies tended to address research questions that were different in scope or focus than the questions posed by the sponsors of the NIH State-of-the-Science Conference; in part much of the available data are not amenable to analyses that could adequately answer the Key Questions.

As described for Key Question 2, there is not yet consistency among clinicians or researchers as to the definitions of AS or of WW, the standard protocols for the interventions, or how to manage patients whose cancers show signs of progression. In addition, studies based on database analyses frequently could not segregate patients who had AS from those who had WW. It is also common for analyses to group together patients who had no treatment with those who had ADT alone. This was particularly the case for analyses of the SEER database, in which it is only possible to distinguish nonaggressive therapy (e.g., AS or ADT) from prostatectomy or radiation therapy.

For the most part, the Key Questions, and thus this review, implicitly assume that it is possible to identify men who are at sufficiently low risk of progression of their prostate cancer that AS can be a safe and appropriate option for them. This report did not review studies that evaluated methods of categorizing patients into risk groups. However, our readings and discussions with experts lead us to the conclusion that additional basic and clinical research is needed to more accurately classify or predict those men whose diseases are indeed at a low risk of progression. Presumably, these are the men for whom it would be most appropriate to consider offering AS.

Also as described above, there are numerous gaps in the evidence regarding the many specific factors and subgroups of interest to the conference. This section will not attempt to delineate all the places where evidence is inadequate, but instead will highlight those areas that our EPC concluded are in most need of future research. The future research needs will be addressed in the order of the Key Questions.

### Key Question 1 Patient Population and Natural History Changes in Last 30 Years

While there are several gaps in evidence regarding time-trend analyses of specific factors of interest to the conference sponsors, better understanding of time-trends in the future can be gained by improving the data being collected and expanding the scope of the major U.S. databases. In particular, we found that detailed stage and grade information are often not available requiring researchers to create broad categories that place major limitations on the analyses. Likewise, future research would be enhanced if more accurate and specific data were collected about the therapeutic interventions or observational management strategies. As just mentioned above, one cannot use the SEER database to accurate analyze true WW (or AS), since these observational management strategies cannot be distinguished from use of ADT. In addition, the SEER database is inadequate to analyze data from races other then blacks and whites, since Hispanics/Latinos, Asians, and others are apparently underrepresented, precluding complete racial analyses. This may require adding new registries to SEER that better represent other races.

We were also concerned about a potentially important source of bias in the SEER database which may require resolution to allow for appropriate future analyses on cancer staging. Analyses of SEER reported summary stage information using the “a combination of the most precise clinical and pathological documentation of the extent of disease.”^fff^ This may result in misclassification, as the accuracy of available information on staging depends on the treatment patients receive. For patients who have had RP, pathological staging information is available, whereas for those who have received RT, ADT monotherapy, AS, or WW, only clinical staging information is available. Thus, patients having surgery are staged more accurately than those with clinical or imaging staging alone. This bias could be reduced if the SEER database maintained the staging information that is available prior to surgery, so that researchers can analyze unbiased data about staging.

fff See the SEER staging manual, available at: http://seer.cancer.gov/tools/ssm/ (last accessed September 30, 2011).

### Key Question 2 Definition of Active Surveillance

Little new research per se is needed to address how AS has been defined by researchers. However, interpretation of future studies would be best served if there were a standard, agreed-upon definition of AS that clearly distinguishes it from WW and other forms of withheld or noncurative treatments. A consensus conference may be the most appropriate forum to define AS. Features of the definition will need to include 1) the goal or intent of the intervention (e.g., delaying curative treatment until there is evidence of progression); 2) the “eligibility criteria,” a determination of which patients should be offered AS based on disease and patient characteristics; 3) the “followup protocol,” the minimum set of tests that should be followed (e.g., DRE and PSA), and their timing; and 4) criteria or triggers for stopping AS, when there has been sufficient or rapid enough progression to warrant active, curative treatment.

Working under the (still unproven) assumption that AS is a safe and effective treatment alternative to RP or RT, the best AS protocol should be investigated by randomized or other prospective comparative studies that directly compare different protocols. The current retrospective or case series studies provide some data to allow for comparison of protocols, but these data are largely incomplete and adjustment using techniques of multivariable analysis is likely inadequate to control for confounding and other biases. Examples of comparisons for future trials could include use of different combinations of followup testing (e.g., PSA, DRE, imaging, rebiopsy), different timing for the tests (e.g., every 3 or 6 months), and different definitions of progression that would determine when curative treatment is offered. These trials will require long-term followup. The outcomes of greatest clinical importance are those that are most pertinent to patients’ health, well-being, and longevity. Examples include all-cause mortality, prostate-cancer-specific mortality, development of symptomatic disease or distant metastases, urological and other complications (from testing, treatment, or deferring treatment), quality of life, anxiety, and family dynamics. Also of interest would be overall costs, use of resources, and numbers of negative invasive tests (i.e., biopsies showing no progression that arguably were thus unnecessary). Since only about half of men on AS require treatment due to disease progression within 5 years,^168^ and only a percentage of them will have clinically important outcomes (e.g., cancer death), a trial may also need to be quite large to be adequately powered.

Another related question of interest that was not asked for in the Key Question (and thus was not systematically reviewed) is which tests are the best predictors of either progression or clinical outcomes. Ideally, for the purpose of developing an AS protocol, these studies should be conducted only in men who are being followed with AS, excluding men with more advanced disease at baseline or who are undergoing curative treatment. Studies would need to properly account for whether ADT is being used. Prospective studies that directly compare specific tests (e.g., PSA, DRE, imaging, rebiopsy) would be most reliable. However, such studies may have large amounts of confounding and colinearity. For example, there will likely be large variation in the frequency of specific tests, which may be confounded with the tests themselves; the results of some tests (e.g., DRE) may affect the frequency or use of other tests (e.g., rebiopsy), and it may be impossible to separate out the effects of individual tests that are conducted together (e.g., PSA and DRE).

Consideration should be given to conceptualizing AS monitoring strategies as dynamic treatment regimes (i.e., rules for sequential decision making based on the evolution of patient or tumor characteristics over time). Such approaches formalize the process of choosing between competing monitoring strategies based on expected responses to treatment and related intermediate and long-term outcomes using appropriate statistical models. Compared to standard research methods (e.g., directly comparing two monitoring strategies in a parallel group study), dynamic treatment modeling may be better at identifying the optimal monitoring regime while accounting for the temporal structure of the data (e.g., multiple monitoring visits) and the fact that treatment decisions at each visit are determined by the measurements performed (e.g., PSA, repeat biopsy). Indeed, statistical methods exist that can use observational or randomized study data to determine the factors that should be considered as triggers for intervention, as well as the optimal cut-off values of these factors.^243,244^

At a minimum, future study reports should be very explicit and clear about what their definitions of AS (or WW) were, what were the goals of the intervention, what were the exact protocols, what were the exact definitions of progression, how and when protocols or standards changed during their study (and why), and why and how often patients and clinicians chose to not follow the protocols.

### Key Question 3 Factors That Affect Offer of, Acceptance of, and Adherence to AS

As described under the findings for Key Question 3, there are two major categories of studies that address this Key Question: quantitative analyses of databases and registries, and more qualitative analyses of surveys of men diagnosed with prostate cancer and their clinicians. To date, both types of analyses have limitations that preclude strong conclusions. The databases tend to have data only about what treatment patients received and when. Therefore, whether different treatment options were offered to them, whether they accepted those options, and whether they adhered to their initial choices could only be inferred. Even the best analysis of predictors of initial treatment cannot adequately address the Key Question of interest to this conference’s sponsors, since the three treatment stages of interest (offer, acceptance, and adherence) are not described in the database. Thus, full statistical analyses of predictors will require the prospective collection of data specifically about what interventions were offered to each patient, which treatments the patients accepted, and when they chose to receive curative treatment despite lack of evidence of progression. Ideally, data would also be collected on what a priori definition of progression was used for each patient to allow the analysis of lack of adherence. These datasets will need to be sufficiently large to allow for testing of multiple predictor variables. In addition, future studies should only perform complete analyses of all treatment options (AS or WW, surgery, radiation, ADT, and combinations) without arbitrarily grouping treatments (e.g., AS and ADT) or selectively excluding treatments (e.g., by pairwise comparisons). This will minimize bias and increase clarity about what is being tested.

We believe that, where possible, future database analyses and prospective observational studies should focus on those predictors that are amenable to change or that can be acted upon. For example, if it is shown that men who receive educational materials are more likely to accept AS, this intervention can be implemented. Or if it is found that black men are less likely to be offered AS, then training of physicians to minimize implicit bias may be warranted. However, researchers should avoid interpreting analyses to suggest that men with certain demographic (or other nonmodifiable) features are most likely to accept treatment and thus other men should not receive the offer of treatment.

Further surveys of patients, their families, and their clinicians are warranted. To improve reliability, these should be adequately powered to ensure that sufficient numbers of men were treated with different interventions and to allow full analyses of the tested predictors. Studies should use established methods including standardized qualitative research designs and, ideally, validated questionnaires to elicit preferences. Studies of this sort also need to consider the overall adequacy of discussion with patients regarding management options—and documentation of those discussions. Adequate documentation of these discussions will surely improve the veracity of some of these survey data.

Though not requested by the sponsors, future Key Questions of interest to be addressed by systematic review and primary studies could include comparisons of interventions that improve the likelihood that eligible men are offered AS, that improve acceptance of AS, and that improve adherence with AS. Arguably, it is more important to first establish how to successfully get men offered, accepting, and adhering to AS before determining which men are at greatest risk of failing to receive AS. If no intervention successfully improves the likelihood that men will adhere to AS, it may not be particularly relevant to flag those men most at risk of nonadherence.

Another issue for consideration could be when and how to discuss with patients the option of transitioning from AS to either WW or other nontreatment protocols, for those patients who may decide that they might no longer desire curative treatment regardless of progression.

### Key Question 4 Active Surveillance Versus Immediate Curative Treatment

An RCT with long followup would provide the best evidence to adequately assess the differential effects between AS and immediate curative treatment. The least biased, most reliable study design comparing two interventions is the RCT that adheres to modern methodological standards. While the patient and his clinicians cannot be blinded to his treatment plan, outcome assessors—particularly those who conduct psychometric testing—should be blinded. The primary outcomes of interest should be the same as those listed above, under research needs for Key Question 2, namely patient-centered clinical outcomes, including psychometric measurements, adverse events, resource utilization, and costs. However, we acknowledge that conducting and completing an adequately powered trial of sufficient duration may be challenging and resource-intensive. The greatest difficulty is likely to be recruiting sufficient physicians and patients who are willing to allow chance to dictate the choice between AS and immediate treatment (note that the Active Surveillance Therapy Against Radical Treatment in Patients Diagnosed With Favorable Risk Prostate Cancer (START) has been terminated because of not meeting accrual target^ggg^). One will also need to factor in the probability of acceptance of the scientific equipoise across these treatment options in maximizing recruitment (witness the rapid enrollment in the Prostate Testing for Cancer and Treatment trial (ProtecT) discussed further in the Discussion). Trials would then need to be of sufficiently long duration to collect data on the clinically relevant outcomes.

ggg See http://clinicaltrials.gov/ct2/show/NCT00499174; last accessed September 30, 2011.

In lieu of RCTs, adequate findings may be possible from long-term databases with prospectively collected data. However, these studies ideally should also use AS protocols that are defined a priori and undergo minimal change over time or between centers. A second-tier, but more practical option, is to allow for a range of a priori AS protocols across centers, also allowing for modifications over time; however, the AS protocols should be broadly similar to each other and any changes in protocols should be systematically tracked and adjusted for in analyses. The determination of which patients are potentially eligible for AS should also be made a priori. Only these patients (whether they ultimately received AS or another treatment) should be analyzed. To be interpretable, these studies will need to use multivariable analyses, propensity scores, or other validated methods (e.g., instrumental variable regression) to adjust for the broad range of factors that affect the decision to use AS. These include, but are not limited to disease factors (e.g., stage and grade); disease markers (e.g., PSA and imaging); patient demographics, psychometrics, personality traits, and personal relationships; clinic features and setting; primary care physician factors; and treating physician factors. We do not believe that retrospective studies (without a priori definitions of AS, eligibility criteria, or choice of variables of interest) are capable of having adequate data for unbiased analyses, because patient and tumor characteristics are strongly associated with initial treatment choice as well as outcomes (i.e., they are strong confounders of the treatment-outcome association).

Subgroup analyses of either the trials or the prospective comparative studies should be conducted to look for particular sets of men who may benefit most (or least) from one approach or the other. Preferably, these subgroups should be considered a priori to allow studies to be adequately powered for these subgroup analyses, to minimize bias, and to constrain type I error (false-positive findings). The factors listed in Key Questions 1 and 2 form a good starting point to consider which subgroups may be of interest. In addition, future studies that could uncover better bio- and imaging markers of indolent versus aggressive disease, and thus could better stage patients as having either low or high risk disease, are necessary to better inform which patients are most likely to benefit from observational versus active treatment.