# Methods

The present review evaluates trends in the epidemiology and natural history of prostate cancer in the United States. It also reports on aspects relevant to active surveillance (AS), watchful waiting (WW), and other “no treatment” approaches for managing localized disease. The evidence presented was obtained through a systematic review of the published scientific literature using established methodologies as outlined in the Agency for Healthcare Research and Quality’s (AHRQ) Methods Guide for Comparative Effectiveness Reviews.^6^

## AHRQ Task Order Officer

The Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO facilitated a common understanding among all parties involved in the project, resolved ambiguities, and fielded all EPC queries regarding the scope and processes of the project. The TOO and other staff at AHRQ reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## External Expert Input

The EPC convened a group of experts in the epidemiology and treatment of prostate cancer to form the Technical Expert Panel (TEP). Members of the TEP provided clinical and methodological expertise and input to help interpret the Key Questions guiding this review, identify important issues, and define parameters for the review of evidence. Discussions between the EPC, TOO, and the TEP occurred during a series of teleconferences and via email. In addition, input from the TEP was sought during compilation of the report when questions arose about the scope of the review. See Acknowledgement for the list of TEP members, and title page for our local domain experts.

## Key Questions

The Key Questions listed in the Introduction were provided by the NIH Consensus Development Program (CDP). The Key Questions have not been altered for the review.

## Analytic Framework

To guide this systematic review and facilitate the interpretation of the Key Questions, we developed an analytic framework (Figure 1) that depicts the logical progression and interconnection of all five Key Questions of interest. The relevant population is patients with localized prostate cancer. Key Question 1 addresses changes in the last 30 years with respect to patient, tumor, and system-level characteristics at diagnosis, as well as trends in the diagnostic strategies employed. Key Question 2 examines the definitions of active surveillance (AS) and other observational strategies in terms of common metrics and followup protocols, as they have been implemented in clinical research. Patients diagnosed with localized prostate cancer are faced with a decision to either enter an AS monitoring protocol or receive immediate treatment with curative intent. Key Question 3 addresses the patient-, physician-, and system-level factors that influence this decision, in term of the offer and acceptance of, or adherence to AS. Key Question 4 addresses the short- and long-term outcomes and costs associated with AS versus immediate treatment with curative intent. Outcomes of interest include prostate specific- and all-cause mortality, morbidity of primary treatment, incidence of metastatic disease, quality of life, and cost. Key Question 5 addresses future research needs across the spectrum of Key Questions 1 through 4.

Figure 1 Analytic framework that depicts the five Key Questions (KQs) that examine the role of active surveillance in the management of men with clinically localized prostate cancer

ADT = androgen deprivation therapy; AS = active surveillance, KQ = key question.

*ADT alone is a management strategy that is not reviewed in this review.

Figure A and Figure 1 are the same flowchart that depicts the logical progression and interconnection of all five Key Questions and patients with localized prostate cancer. Key Question 1--changes in the last 30 years (patient, tumor, and system-level characteristics at diagnosis, diagnostic strategies). Key Question 2--definitions of active surveillance (AS) and other observational strategies. Patients enter an AS monitoring protocol, receive immediate treatment with curative intent, or androgen deprivation therapy alone (not reviewed in this report). Key Question 3--factors that affect adherence to AS. Key Question 4--the short- and long-term outcomes associated with AS versus immediate treatment with curative intent. Outcomes: prostate specific- and all-cause mortality, morbidity of primary treatment, incidence of metastatic disease, quality of life, and cost. Key Question 5--future research needs.

## Literature Searches

Studies included in this review were identified through multiple literature searches using terms relevant to prostate cancer or observational management strategies (including AS and WW) (provided in Appendix A). Specifically, we performed a search for systematic reviews and meta-analyses in the MEDLINE database (from 1996 through December week 4, 2010). We did not search for systematic reviews and meta-analyses published earlier to ensure the results would be applicable to current clinical practice. We performed an additional search of the MEDLINE database (from inception through August, 2011) using terms for specific databases (such as the Surveillance Epidemiology and End Results (SEER) database and the Cancer of the Prostate Strategic Urologic Research Endeavor (CaPSURE) database) along with terms for prostate cancer. This search was supplemented by a MEDLINE search (from inception through August, 2011) combining terms relevant to observational management strategies (e.g., WW, AS, expectant management) along with terms for prostate cancer; the search strategy was based on expanding a previously published set of keywords.^7^ We also performed a targeted literature search for economic evaluations using the Cost-Effectiveness Analysis Registry^a^, a curated database of cost-effectiveness analyses maintained by the Center for the Evaluation of Value and Risk in Health at Tufts Medical Center (the search was performed on November 2, 2011; at that time the registry contained data up to 2010).

a Available at https://research.tufts-nemc.org/cear4/SearchingtheCEARegistry/SearchtheCEARegistry.aspx; last accessed October 31, 2011.

Additional citations were provided by members of the TEP and were reviewed against the same inclusion and exclusion criteria that were used for studies identified through the database searches. We also perused the reference lists of the eligible primary studies and relevant review articles to identify additional potentially relevant studies.

For the question (Key Question 3) related to factors affecting AS, we did not do a targeted search of the individual factors, instead we relied on primary studies and systematic reviews already identified via the above searches.

We did not include unpublished data (such as abstracts or meeting proceedings) for this review.

After running each search, abstracts were entered in an electronic database and nonoverlapping sets of citations were screened by a single investigator.

We identified ongoing studies (provided in Appendix B) through perusal of reference lists, review articles and citations from the TEP.

## Study Selection and Eligibility Criteria

Based on input from the TEP and the TOO, we developed selection criteria for identifying studies for each Key Question. These criteria were different for systematic reviews and primary research studies and are summarized below. For all Key Questions we excluded editorials, letters to the editor, narrative reviews, and any other publications not presenting research results or describing the protocols of primary research studies. We only considered English language studies.

### Systematic Reviews, Evidence Reports, Economic Evaluations

We defined systematic reviews as studies using explicit methods to search, identify and synthesize primary research studies. Reviews utilizing both qualitative or quantitative (meta-analysis) methods to synthesize the available evidence were considered eligible, as long as they provided information considered relevant to the Key Questions.

For Key Question 1, in addition to systematic reviews we also reviewed the latest version of the Cancer Statistics report prepared annually by the American Cancer Society^1^, a recent SEER Survival Monograph^2^, the 2009/2010 update of the Cancer Trends Progress Report^3^, and data available on the SEER Web site.^b^

b Available at http://seer.cancer.gov/faststats/; last accessed September 30, 2011.

For Key Question 2, we only used the reference lists of relevant systematic reviews to identify additional primary studies providing definitions of observational management strategies.

For Key Question 3, we reported relevant findings from existing systematic reviews and we also perused the reviews’ references to identify potentially eligible studies.

For Key Question 4 we mainly relied on two AHRQ evidence reports.^8,9^ For treatment-related costs, we considered economic evaluations (cost components of cost-effectiveness or cost-utility analyses, and model-based cost-minimization or cost-consequence analyses) of AS only. We did not include the effectiveness components of cost-effectiveness or cost-utility analyses because they did not provide additional comparative treatment information beyond that provided by the AHRQ reports and our own literature searches.

For all Key Questions, when necessary, the evidence summarized in previously published systematic reviews and evidence reports was supplemented with studies identified through our own literature searches

### Primary Research Studies

#### Key Question 1 (Trends in Incidence, Mortality/Survival and Features at Diagnosis)

For Key Question 1 we included studies utilizing large databases sourced from the U.S. population (e.g., the SEER database or its component registries; the CaPSURE database; or the National Cancer Database [NCDB]). We excluded studies conducted in other countries. We required the reported patient data to be within the time period 1980 to 2011. Studies had to have analyzed data from at least 1000 patients and to report numerical data informing on changes of the parameters of interest (incidence, mortality/survival, patient-, tumor- or system-level characteristics at diagnosis, treatment patterns).

We required that studies reported changes over time or stratified by time periods (with or without an associated statistical test). Thus, we excluded studies of single years. We included studies that treated time as continuous variable (e.g., year of diagnosis) or as a categorical variable (e.g., “before 2000” versus “after 2000”). Studies reporting only qualitative descriptions were excluded. We also excluded studies that only reported on prostate cancer patients who were selected based on the treatment modality they received (e.g., we did not include studies where patients had to have received radical prostatectomy or studies excluding patients receiving AS/WW), studies enrolling patients exclusively diagnosed through transurethral resection of the prostate performed for benign prostatic hyperplasia, and single-center studies. The latter were excluded to maximize the applicability of the included studies to the U.S. population.

Because differences in patient selection criteria or underlying populations can confound temporal trends, we only considered studies where trend data were obtained from within the same database, and we avoided inferences on temporal trends across manuscripts or databases.

#### Key Question 2 (Definitions of Observational Management Strategies)

We considered studies reporting on observational management strategies (i.e., no immediate active treatment with curative intent), enrolling patients based on predefined eligibility criteria, and using prespecified protocols for followup. We considered both studies where the aim of observational management was to offer curative treatments when disease progression meets predefined laboratory and clinical parameters in a monitoring protocol (AS) and studies where the aim of observational management was to offer palliative treatments when patients become clinically symptomatic (WW). Both prospective and retrospective studies of any design were considered eligible. We evaluated only the descriptions of the observational management strategies.

When a center or research group had published multiple studies reporting on potentially overlapping patient populations, the publication that provided the most complete information on eligibility criteria and followup protocols (i.e., the study that was most informative regarding the components relevant to Key Question 2) was used as the primary source of information for this report. We also considered additional publications from the same cohort when they reported important changes (e.g., in cases where papers explicitly reported changes in the study protocol that affected the definition of the observational strategy). When all articles from the same center or research team used the same observational strategy (i.e., when the same definition was consistently used in all publications), we generally referenced the article with the earliest publication date. We included studies from any country.

#### Key Question 3 (Factors Affecting the Offer of, Acceptance of, and Adherence to Observational Management Strategies)

We considered three types of studies relevant to Key Question 3: (1) studies of any design that used multivariable methods to predict the offer, acceptance, or adherence of observational management; (2) studies that used qualitative research methods to identify such factors; and (3) experimental studies that examined a factor of interest addressing the same issues, when applicable (e.g., decision aids). We included studies from any country. For each type of study we employed different criteria:

##### Studies Using Quantitative Methods to Predict Offer, Acceptance or Adherence

For this category, we considered studies reporting on factors predicting the offer of, acceptance of, or adherence to observational management strategies (including AS and WW). We excluded studies explicitly reporting that patients receiving androgen deprivation therapy (ADT) were considered together with patients receiving no treatment (WW or AS). We also excluded studies defining observational management strategies as the lack of surgical treatment or radiotherapy, without providing information on how other treatments (such as ADT) were handled in the analyses. However, studies that provided no definition of the observational strategy employed (e.g., “expectant management” with no other information on how treatment groups were defined) were included.

Both prospective and retrospective studies of any design were eligible, so long as one treatment group was managed using observational management strategies. We required that studies used multivariable methods (e.g., multivariable regression or analysis of covariance) to adjust for potential confounders. At a minimum we required adjustment for age and tumor stage (if the analysis was not limited to patients with localized cancer).

##### Studies Using Qualitative Methods

For this category, we considered studies using qualitative research methods (e.g., focus groups or surveys) to obtain information on factors that affect the offer of, acceptance of, or adherence to AS or WW. Eligible studies had to use a predefined approach to collect information (e.g., a structured or semi-structured interview, a questionnaire).

##### Experimental Studies

For this category, we included studies of any design that evaluated any tool (such as a decision aid) or other intervention designed specifically to have an impact on acceptance of AS.

#### Key Question 4 (Comparative Effectiveness of Observational Management Strategies and Active Treatment)

We considered studies that fulfilled the following criteria:

Population. Men with clinically localized prostate cancer (T1-T2), without (or unable to assess) either regional lymph nodes involvement (N0-X) or metastases (M0-X), regardless of age, histologic grade, Gleason score, or prostate-specific antigen (PSA) concentration. Studies that enrolled mixed populations of clinically localized and more advanced disease were included only if men with more advanced disease stages represented less than 20 percent of the study sample, or if they reported separate treatment effect estimates for the clinically localized subgroup of patients.

Intervention. Observational (no immediate active treatment) management strategies, including both WW and AS strategies. We excluded studies where the observational management group was combined with the group of patients receiving either medical or surgical ADT (i.e., orchiectomy). We also excluded studies defining observational management strategies as the lack of surgical treatment or radiotherapy, without providing information on how other treatments (such as ADT) were handled in the analyses. However, studies that provided no definition of the observational strategy employed (e.g., “expectant management” with no other information on how treatment groups were defined) were included.

Comparators. Radical prostatectomy (RP), external beam radiation therapy (EBRT), or brachytherapy (BT), all with or without ADT. Based on input from the TEP and AHRQ representatives, ADT was not considered a potentially curative treatment and studies that compared observational management strategies only with ADT monotherapy were excluded.

Outcomes. Outcomes of interest included prostate cancer-specific mortality, all-cause mortality, morbidity of primary treatment (including the frequency of procedures to address treatment-related morbidity), development of metastatic disease, quality of life (QoL, including satisfaction with treatment), and costs. Eligible studies had to report or provide sufficient data to allow the estimation of the treatment effect (e.g., hazard ratios, odds ratios, risk differences, or risk ratios along with sufficient statistics to calculate the uncertainty around these estimates) or provide the P value from a test of association of the treatments examined with the outcomes of interest. For treatment-related costs, we considered estimates from primary studies of actual patient costs (i.e., based on data collected during patient followup) of any observational management strategy (AS and WW).

Study design and analysis. We considered both randomized controlled trials, and prospective or retrospective nonrandomized comparative studies with longitudinal followup from any country. We excluded cross-sectional and case-control studies. Eligible observational studies had to be conducted in a multicenter setting in any country or to have utilized databases sourced from the U.S. population (such as SEER, CaPSURE, the Prostate Cancer Outcomes Study [PCOS], the Patterns of Care Study [POCS], or Veterans Administration studies). Nonrandomized comparative studies also had to use multivariable methods (regression or propensity-score based) or instrumental variable methods to estimate treatment effects. Operationally, we required adjustment at least for patient age for all observational studies; when such studies reported on mixed populations (localized mixed with more advanced disease), we also required adjustment for at least one marker of disease severity (e.g., disease stage, tumor grade, Gleason score).

For all Key Questions, potentially eligible studies identified through screening titles and abstracts (see previous section) were retrieved in full text and were reviewed by a single investigator using the above listed criteria.

#### Key Question 5 (Research Needs)

We did not perform a separate literature search for this Key Question, but instead reviewed the evidence for Key Questions 1 to 4 to identify research gaps.

## Data Extraction and Summaries

We considered primary research studies of diverse designs, including published systematic reviews of primary research studies. We list here the information that was extracted from these types of evidence. The summary Tables are provided in Appendix C.

### Primary Research Studies

We extracted bibliographic information, eligibility criteria, enrollment years, study duration, and the number of patients included in the final analytic sample. We also extracted additional information from primary research studies considered relevant to each Key Question.

#### Key Question 1 (Trends in Incidence, Mortality and Features at Diagnosis)

From each study that provided information on temporal trends we extracted information that allowed the reconstruction of trends over time in incidence, mortality/survival, patient-, tumor-, and system-level characteristics at diagnosis. For parsimony, we grouped the extracted information in 5-year bins covering the time period of interest (1980–2010/11). When a study reported multiple estimates of the parameters of interest within a single 5-year bin, we only extracted information for the year closest to the mid-point of the bin (e.g., if a study reported incidence rate data for all years between 1980 and 1985, we extracted the incidence rates for the years 1982 only).

From studies reporting statistical tests for change of the parameters of interest over time, we extracted the following information (when available): the specific method used for statistical analysis of trend data, estimates of trend statistics, and p-values for changes in parameters of interest over time.

#### Key Question 2 (Definitions of Observational Management Strategies)

To describe the definitions of observational management strategies used in published studies of such strategies, we extracted information on patient- and tumor-level characteristics used as eligibility criteria, followup or monitoring parameters, or specific triggers for intervention (active therapy). We also extracted details on the definition of disease progression used in each study. We took particular care to identify changes in the observational protocols used by research teams that had published more than one paper providing information relevant to Key Question 2.

#### Key Question 3 (Factors Affecting the Offer, Acceptance and Adherence to Observational Management Strategies)

For studies using multivariable models to identify factors associated with the offer, acceptance or adherence of WW or AS, we extracted information on the definition of the observational strategy evaluated in each study, the statistical analysis methods used to identify factors of interest, and the main findings as related to Key Question 3.

For studies using qualitative methods to identify factors associated with the offer, acceptance or adherence of WW or AS, we extracted information on the research methods used, the definition of the observational strategy addressed in each study, and a qualitative summary of key study findings.

#### Key Question 4 (comparative effectiveness of observational management strategies and active treatment)

From each eligible comparative treatment study we extracted the following information: detailed descriptions of the interventions being compared, the source populations of each study, details of the eligibility criteria used, sample size information, study start and end dates, followup duration, baseline characteristics of the enrolled patient populations, measurement instruments, the definitions of specific outcomes, and estimates of the treatment effect.

### Systematic Reviews

For systematic reviews, we extracted information on the data sources used, the dates covered by the literature searches, the inclusion and exclusion criteria used, the number of eligible studies identified, whether quantitative synthesis (meta-analysis) was performed, and a description of key study findings.

## Quality Assessment

### Primary Research Studies

We assessed the methodological quality of only observational and randomized studies included for Key Question 4. The EPC, in consultation with the TOO, decided that formal quality assessment was unlikely to be informative for Key Questions 1–3 because it was not deemed well applicable to the descriptive literature summarized for these Key Questions. For Key Question 4, quality assessment was performed by the team member doing the primary data extraction. The quality grade was confirmed by at least one other team member.

We assessed the methodological quality of studies based on predefined criteria. We used a three-category grading system (A, B, or C) to denote the methodological quality of each study as described in the AHRQ methods guide.^6^ This grading system has been used in most of the previous evidence reports generated by our EPC. This system defines a generic grading scheme that is applicable to varying study designs including RCTs, nonrandomized comparative trials, cohort, and case-control studies. For RCTs, we primarily considered the methods used for randomization, allocation concealment, and blinding as well as the use of intention-to-treat analysis, the report of dropout rate, and the extent to which valid primary outcomes were described as well as clearly reported. Only RCTs and prospective comparative studies could receive an A grade. Retrospective studies could be graded either B or C. For all studies, we used (as applicable): the report of eligibility criteria, the similarity of the comparative groups in terms of baseline characteristics and prognostic factors, the report of intention-to-treat analysis, important differential loss to followup between the comparative groups or overall high loss to followup, and the validity and adequacy of the description of outcomes and results.

A (good) Quality A studies have the least likelihood of bias, and their results are considered most valid. They generally possess the following: a clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; clear reporting of dropouts and a dropout rate less than 20 percent; and no obvious bias. Only prospective studies may receive a grade of A.
B (fair/moderate) Quality B studies are susceptible to some bias, but not sufficiently to invalidate results. They do not meet all the criteria in category A due to some deficiencies, but none likely to introduce major bias. Quality B studies may be missing information, making it difficult to assess limitations and potential problems.
C (poor) Quality C studies have been adjudged to carry a substantial risk of bias that may invalidate the reported findings. These studies have serious errors in design, analysis, or reporting and contain discrepancies in reporting or have large amounts of missing information.

### Systematic Reviews

Our assessment of systematic reviews was based on methodological guidelines for reviews of studies of therapeutic interventions^10^ or epidemiological studies.^11^ We also assessed the quality of reviews by extracting information on the items included in the Assessment of Multiple Systematic Reviews (AMSTAR) checklist.^12,13^ Because AMSTAR was developed for typical published systematic reviews (and not evidence reports where often the use of specific methods or reporting practices is not at the discretion of the investigators) we did not use this checklist to assess the quality of evidence reports considered as sources of evidence for this review (i.e., the AHRQ reviews on prostate cancer treatments).

## Data Synthesis and Presentation

We summarized all included studies in narrative form as well as in summary tables (see below) that condense the important features of the study populations, design, intervention, outcomes, and results. For Key Questions 1–4 we synthesized the extracted information qualitatively. Because there was extensive heterogeneity in reporting information for most variables and substantial potential for population overlap between studies for all Key Questions (e.g., the majority of epidemiologic studies considered eligible for Key Question 1 were based on the SEER and CaPSURE databases and covered overlapping periods of time), we did not perform additional quantitative analyses (meta-analyses).

When appropriate we summarized the characteristics of eligible studies using summary statistics (means, medians, ranges and standard deviations).^14^ For Key Question 1, we created line graphs depicting trends over time using publicly available information from the SEER Web site (http://seer.cancer.gov/; last accessed September 30, 2011). For Key Question 2, we generated bar graphs showing the number of AS cohorts employing each specific criterion for patient selection or as part of their followup protocol, to demonstrate items for which heterogeneity was most prominent across cohorts.

## Summary Tables

Summary tables succinctly report measures of the main outcomes evaluated. We included information regarding population selection, country (when relevant), study design, interventions, age data, study setting, prostate cancer stage and grade, sample size, study duration, years of intervention, dropout rate, and study quality (for Key Question 4). For continuous outcomes, we included the mean outcome values, their 95 percent confidence intervals (CI), standard deviations (SD) or other measures of variability and when available, the mean difference (between groups) and its corresponding P value, or CI, as appropriate. For categorical (dichotomous) outcomes, we reported the number of events and total number of patients for each intervention and relative risk metrics (odds ratios, risk ratios or hazard ratios) with their corresponding 95 percent CI and associated P value.

## Grading the Body of Evidence for Key Question 4

We graded the strength of the body of evidence for each analysis within Key Question 4 as per the AHRQ methods guide^6^ and an updated methods paper,^15^ with modifications as described below. Risk of bias was assessed using a three-category grading system (A, B, or C) which corresponds to low, medium or high risk of bias (see Quality Assessment). We assessed the consistency of the data as either “no inconsistency” or “inconsistency present” (or “not applicable” if only one study). The direction, magnitude, and statistical significance of all studies were evaluated in assessing consistency, and logical explanations were provided in the presence of equivocal results. Studies with limited relevance either included populations which related poorly to the general population of men in the United States with localized prostate cancer or contained substantial problems with the measurement of the outcome(s) of interest. We also assessed the precision and sparseness of the evidence. We considered evidence to be sparse if only one study addressed the analysis.

We rated the strength of evidence with one of the following four strengths (as per the AHRQ methods guide): High, Moderate, Low, and Insufficient. Ratings were assigned based on our level of confidence that the evidence reflected the true effect for the major comparisons of interest. Ratings were defined as follows:

High There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect. No important scientific disagreement exists across studies. At least two quality A studies are required for this rating. In addition, there must be evidence regarding objective clinical outcomes.
Moderate There is moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate. Little disagreement exists across studies. Moderately rated bodies of evidence contain fewer than two quality A studies or such studies are inconsistent or lack long-term outcomes of relevant populations.
Low There is low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. Underlying studies may report conflicting results. Low rated bodies of evidence could contain either quality B or C studies.
Insufficient Evidence is either unavailable or does not permit a conclusion. There are sparse or no data. In general, when only one study has been published, the evidence was considered insufficient, unless the study was particularly large, robust, and of good quality.

These ratings provide a shorthand description of the strength of evidence supporting the major questions we addressed. However, they by necessity may oversimplify the many complex issues involved in appraising a body of evidence. It is important to remember that the individual studies involved in formulating the composite rating differed in their design, reporting, and quality. The strengths and weaknesses of the individual reports, as described in detail in the text and tables, should also be taken into consideration.

## Peer Review and Public Commentary

As part of a newly instituted process at AHRQ, the initial draft report was prereviewed by the TOO and an AHRQ Associate Editor (a senior member of a sister EPC). Following revisions, the draft report was sent to invited peer reviewers and was simultaneously uploaded to the AHRQ Web site where it was available for public comment for 30 days. All reviewer comments (both invited and from the public) were collated and individually addressed. The authors of the report had final discretion as to how the report was revised based on the reviewer comments, with oversight by the TOO and Associate Editor.