# Appendix Tables for Key Questions 1–4

Appendix Table C1.1 Descriptive characteristics of the epidemiologic studies considered relevant to KQ1

Appendix Table C1.2 Trends in prostate cancer incidence rates (per 100,000 unless otherwise stated)

Appendix Table C1.3 Trends in mortality rates (per 100,000 person-yr unless otherwise stated) or survival

Appendix Table C1.4 Patient characteristics—age

Appendix Table C1.5 Patient characteristics—comorbidity

Appendix Table C1.6 Patient characteristics—race/ethnicity

Appendix Table C1.7 Tumor characteristics—stage

Appendix Table C1.8 Tumor characteristics—Gleason score

Appendix Table C1.9 Tumor characteristics—PSA

Appendix Table C1.10 Diagnostic strategies—biopsy frequency

Appendix Table C1.11 Diagnostic strategies— number of cores

Appendix Table C1.12 Gofrit 2007, systematic review of the effect of histopathologic grading changes

Appendix Table C1.13 System characteristics—including, differences in geographical access, insurance, physician types, etc.

Appendix Table C1.14 Treatment characteristics—changes in treatment patterns over time

Appendix Table C2.1 Eligibility criteria, follow-up protocols, triggers for intervention and definition of progression in cohorts of active surveillance/ watchful waiting/other observational management strategies

Appendix Table C3.1 Studies on offer, acceptance, and adherence of active surveillance

Appendix Table C3.2 KQ3 multivariable analyses

Appendix Table C3.3 Lin 2009, systematic review of patient decision aids

Appendix Table C4.1 Descriptive characteristics of the randomized controlled trials and comparative cohort studies considered relevant to KQ4

Appendix Table C4.2 Comparison between watchful waiting and radical prostatectomy

Appendix Table C4.3 Comparison between watchful waiting and radiation therapy

Appendix Table C4.4 Comparison between watchful waiting and other active treatments

Appendix Table C4.5 Cost comparisons of watchful waiting with active treatments

Appendix Table C5.1 Proportion of patients on AS who went on to receive active treatments