# Ongoing Randomized Studies Comparing Observational Management Strategies With Active Treatment Strategies for the Treatment of Clinically Localized Disease

Study name [Registration] Country | N centers (planned enrollment) [enrollment period] | Population | Intervention | Comparator(s) | Outcomes | Current status
PIVOT [Clinical Trials.gov, NCT00007644] USA | 31 (731) [1994–2002] | Clinically localized prostate cancer, within 6 mo of diagnosis, ≤75 yr | WW (expectant management with palliative therapy) | RP | OS (primary); prostate cancer-specific mortality, DFS, PFS, morbidity, QoL, and CE | Preliminary results presented at the 2011 AUA meeting
START [Clinical Trials.gov, NCT00499174] Canada, USA, UK | 13 (2130) [2007–2011] | Histologically confirmed adenocarcinoma of the prostate, within 6 mo of diagnosis, clinical stage T1b-T2b, Gleason score ≤ 6, PSA ≤10 ng/mL, physical examination, DRE and transrectal US within 6 mo of randomization, radiographic studies, (if indicated) negative for metastasis, LE >10 yr | AS (PSA testing, repeat biopsy and DRE; radical intervention at biochemical, histological, or clinical progression) | RP or RT, based on patient and physician preference | Prostate cancer-specific mortality (primary); OS, QoL, distant DFS, PSA relapse/progression after radical intervention, initiation of ADT, proportion of patients on the AS arm who receive radical intervention, prognostic significance of PSA doubling-time prior to diagnosis, prognostic significance of molecular biomarkers | Terminated early (not meeting accrual target)
ProtecT [Clinical Trials.gov, NCT00632983] UK | 10 (2050) [2001-ongoing] | clinically localized disease prostate cancer (T1-T2, NX, M0), 50–69 yr, PSA 3.0–19.99 ng/mL, no skeletal metastases by isotope bone scan, LE ≥10 yr | AS (repeat PSA testing q3 mo in the first year and then q 6 mo thereafter; annual review appointment with DRE, if indicated) | RP and 3d-CRT (with or without ADT) (2 comparator arms) | OS (primary); disease progression, treatment complications, general health status, anxiety, depression, and psychological state, urinary symptoms, QoL, sexual function, qualitative evaluation of outcome by indepth interviews | Followup phase

3d-CRT = 3-dimentional conformal radiotherapy; ADT = androgen deprivation therapy; AS = active surveillance; AUA = American Urological Association; CE = cost-effectiveness; DFS = disease-free survival; DRE = digital rectal examination; LE = life expectancy; mo = month; PIVOT = Prostate Cancer Intervention Versus Observation Trial; NR = not reported; OS = overall survival; PFS, progression-free survival; ProtecT = Prostate Testing for Cancer and Treatment; PSA = prostate specific antigen; QoL = quality of life; RP = radical prostatectomy; RT = radiation therapy; START = Active Surveillance Therapy Against Radical Treatment in Patients Diagnosed With Favorable Risk Prostate Cancer trial; US = ultrasound; yr = year.