# Search Strategies

## A.1 Search Strategy for Systematic Reviews

Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to December 2010>, EBM Reviews - Health Technology Assessment <4th Quarter 2010>, Ovid MEDLINE(R) <1996 to December Week 4 2010>

Search Strategy:

1. meta-analysis.pt.
2. systematic$ review$.mp.
3. (systematic$ adj9 overview$).mp.
4. (meta-analys$ or meta analys$ or metaanalys$).mp.
5. evidence review$.mp.
6. or/1–5
7. prostate cancer.mp.
8. watchful waiting.mp.
9. active surveillance.mp.
10. or/7–9
11. 6 and 10

## A.2 Search Strategy for Large Databases

Database: Ovid MEDLINE(R) (1996 to August Week 1 2011)

Search Strategy:

1. ("Surveillance, Epidemiology and End Results" or "SEER" or "National Cancer Data Base" or "NCDB" or "Cooperative Studies Program" or "CSP" or "CaPSURE").mp.
2. prostate cancer.mp. or exp Prostatic Neoplasms/
3. 1 and 2
4. ("Prostate Cancer Outcomes Study" or "PCOS").mp.
5. 2 and 4
6. 5 not 3

## A.3 Search Strategy for AS or WW

Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations (August 16, 2011), EBM Reviews - Cochrane Database of Systematic Reviews (2005 to July 2011), EBM Reviews - Cochrane Central Register of Controlled Trials (3rd Quarter 2011), EBM Reviews - Health Technology Assessment (3rd Quarter 2011), Ovid MEDLINE(R) without Revisions (1996 to August Week 1 2011)

Search Strategy:

1. watchful waiting.mp.
2. active surveillance.mp.
3. conservative management.mp.
4. expectant management.mp.
5. deferred treatment.mp.
6. ((expectant$ adj5 manage$) or (conservative$ adj5 manage$) or (active adj5 surveillance) or (watchful adj5 waiting) or (watch adj5 wait) or (watchful adj5 observation) or (active$ adj5 monitor$) or (defer$ adj5 treatment)).tw.
7. prostate cancer.mp. or exp Prostatic Neoplasms/
8. ((prostat$ adj5 neoplas$) or (prostat$ adj5 cancer$)).tw.
9. 1 or 2 or 3 or 4 or 5 or 6
10. 7 or 8
11. 9 and 10
12. limit 11 to English language
13. limit 12 to yr="1987-Current"
14. (expectant$ adj5 treatment).tw.
15. 10 and 14
16. limit 15 to yr="1987-Current"
17. 16 not 13

## A.4 Search Strategy for the Cost-Effectiveness Analysis Registry

We identified all studies with the words “prostate” OR “prostatic” in the database. The search was performed on October 31, 2011. At that time the database contained records up to and including 2010.