# Appendixes

Appendix A Search Strategies

Appendix B Ongoing Randomized Studies Comparing Observational Management Strategies With Active Treatment Strategies for the Treatment of Clinically Localized Disease

Appendix C Appendix Tables for Key Questions 1–4